# Appendixes

Appendix A Technical Expert Panel Members

Appendix B Exact Search Strings

Appendix C: Abstraction Forms

Appendix D Evidence Tables and Figures