# List of Excluded Studies

## References

1 Adams J. Exploring yoga to relieve menopausal symptoms. Holist Nurs Pract. 2003;17(3):166-167. [pmid: 12784901].
2 Adamson D L, Webb C M, Collins P. Esterified estrogens combined with methyltestosterone improve emotional well-being in postmenopausal women with chest pain and normal coronary angiograms.[see comment]. Menopause. 2001;8(4):233-238. [pmid: 11449079].
3 Adashi E Y. The climacteric ovary as a functional gonadotropin-driven androgen-producing gland. Fertil Steril. 1994;62:20. [pmid: 8005293].
4 Adena M A, Gallagher H G. Cigarette smoking and the age at menopause. Annals of Human Biology. 1982;9(2):121-130. [pmid: 7081945].
5 Akahoshi M, Soda M, Nakashima E, et al. The effects of body mass index on age at menopause. International Journal of Obesity & Related Metabolic Disorders: Journal of the International Association for the Study of Obesity. 2002;26(7):961-968. [pmid: 12080450].
6 Aksel S, Schomberg D W, Tyrey L, Hammond C B. Vasomotor symptoms, serum estrogens, and gonadotropin levels in surgical menopause. Am J Obstet Gynecol. 1976;126(2):165-169. [pmid: 961757].
7 Albertazzi P, Bottazzi M, Purdie D W. Gabapentin for the management of hot flushes: a case series. Menopause. 2003;10(3):214-217. [pmid: 12792292].
8 Albertazzi P, Natale V, Barbolini C, Teglio L, Di Micco R. The effect of tibolone versus continuous combined norethisterone acetate and oestradiol on memory, libido and mood of postmenopausal women: A pilot study. Maturitas. 2000;36(3):223-229. [pmid: 11063905].
9 Alcoff J M, Campbell D, Tribble D, Oldfield B, Cruess D. Double-blind, placebo-controlled, crossover trial of propranolol as treatment for menopausal vasomotor symptoms. Clinical Therapeutics. 1981;3(5):356-364. [pmid: 7471131].
10 Altshuler LL, Cohen LS, Moline ML, et al. The Expert Consensus Guideline Series. Treatment of depression in women. Postgraduate Medicine. 2001(Spec No):1–107.
11 Altshuler L L, Cohen L S, Moline M L, et al. Treatment of depression in women: A summary of the expert consensus guidelines. Journal of Psychiatric Practice. 2001;7(3):185-208. [pmid: 15990522].
12 American College of O, Gynecologists Committee on Practice B-G. ACOG Practice Bulletin. Clinical Management Guidelines for Obstetrician-Gynecologists. Use of botanicals for management of menopausal symptoms. Obstetrics & Gynecology. 2001;97(6):suppl 1–11.
13 Amigoni S, Morelli P, Chatenoud L, Parazzini F. Cross-sectional study of determinants of menopausal age and hormone replacement therapy use in Italian women. Climacteric. 2000;3(1):25-32. [pmid: 11910606].
14 Amundsen D W, Diers C J. The age of menopause in classical Greece and Rome. Human Biology. 1970;42(1):79-86.
15 Anarte M, Cuadros J, Herrera J. Hormonal and psychological treatment: Therapeutic alternative for menopausal women?. Maturitas. 1998;29(3):203-213. [pmid: 9699191].
16 Anasti J, Leonetti H, Wilson K J. Topical progesterone cream has antiproliferative effect on estrogen-stimulated endometrium. Obstetrics & Gynecology. 2001;97(4supp1):S10.
17 Andersen F S, Transbol I, Christiansen C. Is cigarette smoking a promotor of the menopause?. Acta Medica Scandinavica. 1982;212(3):137-139. [pmid: 7148504].
18 Andersen J, Poulsen H S. Immunohistochemical analysis of estrogen receptors (ER) using formalin-fixed paraffin-embedded breast cancer tissue: correlation with clinical endocrine response. Journal of Steroid Biochemistry. 1988;30(16):337-339. [pmid: 3386262].
19 Anderson D, Posner N. Relationship between psychosocial factors and health behaviours for women experiencing menopause. International Journal of Nursing Practice. 2002;8(5):265-273. [pmid: 12225353].
20 Andreen L, Bixo M, Nyberg S, Sundstrom-Poromaa I, Backstrom T. Progesterone effects during sequential hormone replacement therapy. European Journal of Endocrinology. 2003;148(5):571-577. [pmid: 12720542].
21 Andreyko J L, Monroe S E, Marshall L A, Fluker M R, Nerenberg C A, Jaffe R B. Concordant suppression of serum immunoreactive luteinizing hormone (LH), follicle-stimulating hormone, alpha subunit, bioactive LH, and testosterone in postmenopausal women by a potent gonadotropin releasing hormone antagonist (detirelix). J Clin Endocrinol Metab. 1992;74(2):399-405. [pmid: 1370507].
22 Anonymous. Clonidine in treatment of menopausal flushing. Acta Obstet Gynecol Scand Suppl. 1985;132:1–35.
23 Anonymous. What determines the age at the menopause? BMJ. 1991;302(6791):1540.
24 Anonymous. Breast cancer and hormone replacement therapy: collaborative reanalysis of data from 51 epidemiological studies of 52,705 women with breast cancer and 108,411 women without breast cancer. Collaborative Group on Hormonal Factors in Breast Cancer.[see comment][erratum appears in Lancet 1997 Nov 15;350(9089):1484]. Lancet. 1997;350(9084):1047–1059.
25 Anonymous. Treatment of estrogen deficiency symptoms in women surviving breast cancer. Part 6: Executive summary and consensus statement. Proceedings of a conference held at Boar's Head Inn, Charlottesville, Virginia, September 21–23, 1997. Oncology (Huntington). 1999;13(6):859–861, 865-856, 871-852 passim.
26 Anonymous. Treatment of estrogen deficiency symptoms in women surviving breast cancer. Part 1: Defining the problem. Proceedings of a conference held at the Boar's Head Inn Charlottesville, Virginia. September 21–23, 1997. Oncology (Huntington). 1999;13(1):109–115, 119–120, 123-104 passim.
27 Anonymous. Treatment of estrogen deficiency symptoms in women surviving breast cancer. Part 2: Hormone replacement therapy and breast cancer. Oncology (Huntington). 1999;13(2):245–248, 251-244, 257 passim.
28 Anonymous. Treatment of estrogen deficiency symptoms in women surviving breast cancer. Part 4: Urogenital atrophy, vasomotor instability, sleep disorders, and related symptoms. Oncology (Huntington). 1999;13(4):551–554, 557–560, 563 passim.
29 Anonymous. Treatment of estrogen deficiency symptoms in women surviving breast cancer. Part 5: Selective estrogen receptor modulators and hormone replacement therapy. Proceedings of a conference. Charlottesville, Virginia, USA. September 21–23, 1997. Oncology (Huntington). 1999;13(5):721–724, 727–728, 731-722 passim.
30 Anonymous. Million Women Study Collaborators. Breast cancer, hormone replacement therapy in the Million Women Study. Lancet. 2003;362:419–422.
31 Anonymous. Isoflavone supplements no better than placebo for reducing hot flushes. Pharmaceutical Journal. 2003;271(7258):76.
32 Argyroudis E M, Iatrakis G, Kourkoubas A, et al. Tibolone in the treatment of psychosomatic symptoms in menopause. Clinical & Experimental Obstetrics & Gynecology. 1997;24(3):167-168.
33 Arpels J C. The female brain hypoestrogenic continuum from the premenstrual syndrome to menopause. A hypothesis and review of supporting data. J Reprod Med. 1996;41(9):633-639. [pmid: 8887186].
34 Avis N E, McKinlay S M. A longitudinal analysis of women's attitudes toward the menopause: results from the Massachusetts Women's Health Study. Maturitas. 1991;13(1):65-79. [pmid: 1861643].
35 Avis N E, McKinlay S M. The Massachusetts Women's Health Study: an epidemiologic investigation of the menopause. Journal of the American Medical Womens Association. 1995;50(2):45-49. 63.
36 Aygen E, Ekmekcioglu O, Serin S. The relationship between the duration of menopause and lower urinary tract symptoms in women aged 40 to 59. Int J Fertil Womens Med. 2001;46(1):16-22. [pmid: 11294616].
37 Bachmann G A, Leiblum S R. The impact of hormones on menopausal sexuality: a literature review. Menopause. 2004;11(1):120-130. [pmid: 14716193].
38 Bachmann G A, Timmons M C, Abernethy W D. Breakthrough bleeding patterns in two continuous combined estrogen/progestogen hormone replacement therapies, one of which included androgens. Journal of Women's Health. 1996;5(3):205-212.
39 Baird D D, Umbach D M, Lansdell L, et al. Dietary intervention study to assess estrogenicity of dietary soy among postmenopausal women. J Clin Endocrinol Metab. 1995;80(5):1685-1690. [pmid: 7745019].
40 Baker A, Simpson S, Dawson D. Sleep disruption and mood changes associated with menopause. Journal of Psychosomatic Research. 1997;43(4):359-369. [pmid: 9330235].
41 Ballinger C. Subjective sleep disturbance at the menopause. Journal of Psychosomatic Research. 1976;20(5):509-513. [pmid: 1003373].
42 Ballinger C. Psychiatric aspects of the menopause. British Journal of Psychiatry. 1990;156:773-787. [pmid: 2207508].
43 Ballinger C B. Psychiatric morbidity and the menopause; screening of general population sample. British Medical Journal. 1975;3(5979):344-346. [pmid: 1156748].
44 Ballinger S. Stress as a factor in lowered estrogen levels in the early postmenopause. Annals of the New York Academy of Sciences. 1990;592:95-113. discussion 123–133. [pmid: 2197957].
45 Ballinger S. Stress as a factor in lowered estrogen levels in the early postmenopause. Flint, Marcha (Ed); Kronenberg, Fredi (Ed); et al (1990) Multidisciplinary perspectives on menopause Annals of the New York Academy of Sciences, Vol 592 (pp 95–113) xii, 488pp; 1990.
46 Barentsen R, van de Weijer P H, van Gend S, Foekema H. Climacteric symptoms in a representative Dutch population sample as measured with the Greene Climacteric Scale. Maturitas. 2001;38(2):123-128. [pmid: 11306200].
47 Barlow D H, Grosset K A, Hart H, Hart D M. A study of the experience of Glasgow women in the climacteric years. Br J Obstet Gynaecol. 1989;96(10):1192-1197. [pmid: 2590654].
48 Barnhart KT, Freeman E, Grisso JA, Neslter J. The effect of DHEA replacement on well being and perimenopausal symptoms. Fertil Steril. 1998;70(3).
49 Barrett-Connor E, Kritz-Silverstein D. Gender differences in cognitive function with age: The Rancho Bernardo Study. Journal of the American Geriatrics Society. 1999;47(2):159-164. [pmid: 9988286].
50 Barrett-Connor E, Timmons C, Young R, Wiita B. Interim safety analysis of a two-year study comparing oral estrogen-androgen and conjugated estrogens in surgically menopausal women. Journal of Women's Health. 1996;5(6):593-602.
51 Barrett-Connor E, von Muehlen D, Laughlin G A, Kripke A. Endogenous levels of dehydroepaindrosterone sulfate, but no other sex hormones are associated with depressed mood in older women: The Rancho Bernardo Study. Journal of the American Geriatrics Society. 1999;47(6):685-691. [pmid: 10366167].
52 Barton D, La V B, Loprinzi C, Novotny P, Wilwerding M B, Sloan J. Venlafaxine for the control of hot flashes: results of a longitudinal continuation study. Oncol Nurs Forum. 2002;29(1):33-40. [pmid: 11817491].
53 Barton D, Loprinzi C, Wahner-Roedler D. Hot flashes: aetiology and management. Drugs & Aging. 2001;18(8):597-606. [pmid: 11587246].
54 Barton D L. Pilot evaluations of newer antidepressants for hot flashes. Proc Am Soc Clin Oncol. 2002;21:366a.
55 Barton D L. Pilot evaluation of citalopram for the relief of hot flashes. J Support Oncol. 2003;1:47-52. [pmid: 15352642].
56 Barton D L, Loprinzi C, Gostout B. Current management of menopausal symptoms in cancer patients. Oncology (Huntington). 2002;16(1):67-72. 74; discussion 75-66, 79–80.
57 Basaria S, Nguyen T, Rosenson R S, Dobs A S. Effect of methyl testosterone administration on plasma viscosity in postmenopausal women. Clin Endocrinol. 2002;57(2):209-214.
58 Beal M W. Women's use of complementary and alternative therapies in reproductive health care. Journal of Nurse-Midwifery. 1998;43(3):224-234. [pmid: 9674352].
59 Beardsworth S A, Kearney C E, Purdie D W. Prevention of postmenopausal bone loss at lumbar spine and upper femur with tibolone: a two-year randomised controlled trial. Br J Obstet Gynaecol. 1999;106(7):678-683. [pmid: 10428524].
60 Bebbington P, Dunn G, Jenkins R, et al. The influence of age and sex on the prevalence of depression conditions: Report from the National Survey of Psychiatric Morbidity. Psychol Med. 1998;28(1):9-19. [pmid: 9483679].
61 Bebbington P, Dunn G, Jenkins R, et al. The influence of age and sex on the prevalence of depressive conditions: A report from the National Survey of Psychiatric Morbidity. International Review of Psychiatry. 2003;15(12):74-83. [pmid: 12745313].
62 Belsey E M, Pinol A P. Menstrual bleeding patterns in untreated women. Task Force on Long-Acting Systemic Agents for Fertility Regulation. Contraception. 1997;55(2):57-65. [pmid: 9071513].
63 Bengtsson C, Lindquist O, Redvall L. Menstrual status and menopausal age of middle-aged Swedish women. A population study of women in Goteborg 1968-69 and 1974-75. Acta Obstet Gynecol Scand. 1981;60(3):269-275. [pmid: 7270096].
64 Berendsen H H. The role of serotonin in hot flushes. Maturitas. 2000;36(3):155-164. [pmid: 11063896].
65 Berg J A. The perimenopausal transition of Filipino American midlife women: Biopsychosociocultural dimensions. Nursing Research. 1999;48(2):71-77. [pmid: 10190833].
66 Berg J A, Taylor D L. Symptom experience of Filipino American midlife women.[see comment]. Menopause. 1999;6(2):105-114. [pmid: 10374216].
67 Berg J A, Taylor D L. Symptom responses of midlife Filipina Americans.[see comment]. Menopause. 1999;6(2):115-121. [pmid: 10374217].
68 Bernhard L A, Sheppard L. Health, symptoms, self-care, and dyadic adjustment in menopausal women. JOGNN - Journal of Obstetric, Gynecologic, & Neonatal Nursing. 1993;22(5):456-461.
69 Berning B, Kuijk C V, Kuiper J W, Bennink H J, Kicovic P M, Fauser B C. Effects of two doses of tibolone on trabecular and cortical bone loss in early postmenopausal women: a two-year randomized, placebo-controlled study. Bone. 1996;19(4):395-399. [pmid: 8894146].
70 Berning B, van Kuijk C, Kuiper J W, Coelingh Bennink H J, Fauser B C. Increased loss of trabecular but not cortical bone density, 1 year after discontinuation of 2 years hormone replacement therapy with Tibolone. Maturitas. 1999;31(2):151-159. [pmid: 10227009].
71 Bertelli G, Venturini M, Del Mastro L, al. e. Depot intramuscular medroxyprogesterone acetate (MAP) Vs. oral megestrol acetate (MA) for the treatment of hot flashes in breast cancer survivors: results of GONO (Gruppo Oncologico Nord Ovest) MIG-4 Phase III Trial. American Society of Clinical Oncology. 1999:abst 2286.
72 Beser E, Aydemir V, Bozkaya H. Body mass index and age at natural menopause. Gynecologic & Obstetric Investigation. 1994;37(1):40-42. [pmid: 8125407].
73 Beyene Y. Cultural significance and physiological manifestations of menopause. A biocultural analysis. Culture, Medicine & Psychiatry. 1986;10(1):47-71.
74 Bider D, Mashiach S, Serr D M, Ben-Rafael Z. Endocrinological basis of hot flushes. Obstetrical & Gynecological Survey. 1989;44(7):495-499. [pmid: 2662075].
75 Biglia N, Cozzarella M, Cacciari F, et al. Menopause after breast cancer: a survey on breast cancer survivors. Maturitas. 2003;45(1):29-38. [pmid: 12753941].
76 Bines J, Oleske D M, Cobleigh M A. Ovarian function in premenopausal women treated with adjuvant chemotherapy for breast cancer.[see comment]. J Clin Oncol. 1996;14(5):1718-1729. [pmid: 8622093].
77 Biron-Shental T, Tepper R, Fishman A, Shapira J, Cohen I. Recurrent endometrial polyps in postmenopausal breast cancer patients on tamoxifen. Gynecol Oncol. 2003;90(2):382-386. [pmid: 12893204].
78 Bjarnason N H, Bjarnason K, Haarbo J, Rosenquist C, Christiansen C. Tibolone: prevention of bone loss in late postmenopausal women.[comment]. J Clin Endocrinol Metab. 1996;81(7):2419-2422. [pmid: 8675554].
79 Bjorn I, Bixo M, Nojd K S, et al. The impact of different doses of medroxyprogesterone acetate on mood symptoms in sequential hormonal therapy. Gynecol Endocrinol. 2002;16(1):1-8. [pmid: 11915576].
80 Bjorn I, Bixo M, Nojd K S, Nyberg S, Backstrom T. Negative mood changes during hormone replacement therapy: a comparison between two progestogens. Am J Obstet Gynecol. 2000;183(6):1419-1426. [pmid: 11120505].
81 Bloedon L T, Jeffcoat A R, Lopaczynski W, et al. Safety and pharmacokinetics of purified soy isoflavones: single-dose administration to postmenopausal women. American Journal of Clinical Nutrition. 2002;76(5):1126-1137. [pmid: 12399289].
82 Bloom J R, Stewart S L, Chang S, Banks P J. Then and now: quality of life of young breast cancer survivors. Psycho-Oncology. 2004;13(3):147-160. [pmid: 15022150].
83 Blumenthal J A, Fredrikson M, Matthews K A, et al. Stress reactivity and exercise training in premenopausal and postmenopausal women. Health Psychology. 1991;10(6):384-391. [pmid: 1765033].
84 Blumenthal J A, Matthews K, Fredrikson M, et al. Effects of exercise training on cardiovascular function and plasma lipid, lipoprotein, and apolipoprotein concentrations in premenopausal and postmenopausal women. Arteriosclerosis & Thrombosis. 1991;11(4):912-917. [pmid: 2065042].
85 Bodnar S, Catterill T. Amitriptyline in emotional states associated with the climacteric. Psychosomatics. 1972;13(2):117-119. [pmid: 4604078].
86 Boldsen J L, Jeune B. Distribution of age at menopause in two Danish samples. Human Biology. 1990;62(2):291-300.
87 Borrelli F, Mascolo N, Russo A, Capasso R, Ernst E. Cimicifuga racemosa: a systematic review of its clinical and pharmacological effects. Focus on Alternative and Complementary Therapies. 2002;7(1):86.
88 Bosworth H B, Bastian L A, Kuchibhatla M N, et al. Depressive symptoms, menopausal status, and climacteric symptoms in women at midlife. Psychosomatic Medicine. 2001;63(4):603-608. [pmid: 11485114].
89 Botsis D, Kalogirou D, Kassanos D, Antoniou G, Kalogirou O. Clinical Trial of Vaginally Administered Conjugated Estrogens and Tibolone in Postmenopausal Women. 8th International Congress on the Menopause.96.
90 Boulot P, Viala J L. [A multicenter comparison of veralipride versus placebo in the vasomotor flushes of menopause. An evaluation of the prolonged effect]. [French]. Revue Francaise de Gynecologie et d Obstetrique. 1988;83(12):823-827. [pmid: 3064254].
91 Bower J E, Ganz P A, Desmond K A, Rowland J H, Meyerowitz B E, Belin T R. Fatigue in breast cancer survivors: occurrence, correlates, and impact on quality of life. J Clin Oncol. 2000;18(4):743-753. [pmid: 10673515].
92 Brambilla D J, McKinlay S M. A prospective study of factors affecting age at menopause.[erratum appears in J Clin Epidemiol 1990;43(5):537]. J Clin Epidemiol. 1989;42(11):1031-1039. [pmid: 2809660].
93 Brambilla D J, McKinlay S M, Johannes C B. Defining the perimenopause for application in epidemiologic investigations. Am J Epidemiol. 1994;140(12):1091-1095. [pmid: 7998591].
94 Brejnak C. Mechanisms of menopausal hot flashes: The role of catechol estrogens and diet, Wayne State U, US, 1.; 1999.
95 Brett K M, Cooper G S. Associations with menopause and menopausal transition in a nationally representative US sample. Maturitas. 2003;45(2):89-97. [pmid: 12787967].
96 Broeckel J A, Thors C L, Jacobsen P B, Small M, Cox C E. Sexual functioning in long-term breast cancer survivors treated with adjuvant chemotherapy. Breast Cancer Research & Treatment. 2002;75(3):241-248. [pmid: 12353813].
97 Bromberger J T, Matthews K A. A longitudinal study of the effects of pessimism, trait anxiety, and life stress on depressive symptoms in middle-aged women. Psychology & Aging. 1996;11(2):207-213. [pmid: 8795049].
98 Bromberger J T, Matthews K A, Kuller L H, Wing R R, Meilahn E N, Plantinga P. Prospective study of the determinants of age at menopause. Am J Epidemiol. 1997;145(2):124-133. [pmid: 9006309].
99 Buckler H M, Evans C A, Mamtora H, Burger H G, Anderson D C. Gonadotropin, steroid, and inhibin levels in women with incipient ovarian failure during anovulatory and ovulatory rebound cycles. J Clin Endocrinol Metab. 1991;72(1):116-124. [pmid: 1824706].
100 Buckler H M, McElhone K, Durrington P N, Mackness M I, Ludlam C A, Wu F C. The effects of low-dose testosterone treatment on lipid metabolism, clotting factors and ultrasonographic ovarian morphology in women.[see comment]. Clin Endocrinol. 1998;49(2):173-178.
101 Bullock J L, Massey F M, Gambrell R D Jr. Use of medroxyprogesterone acetate to prevent menopausal symptoms. Obstetrics & Gynecology. 1975;46(2):165-168. [pmid: 1153148].
102 Bungay G T, Vessey M P, McPherson C K. Study of symptoms in middle life with special reference to the menopause. British Medical Journal. 1980;281(6234):181-183. [pmid: 6447529].
103 Burger H, Hailes J, Nelson J, Menelaus M. Effect of combined implants of oestradiol and testosterone on libido in postmenopausal women. British Medical Journal Clinical Research Ed. 1987;294(6577):936-937. [pmid: 3107663].
104 Burger H G, Hailes J, Menelaus M, Nelson J, Hudson B, Balazs N. The management of persistent menopausal symptoms with oestradiol-testosterone implants: clinical, lipid and hormonal results. Maturitas. 1984;6(4):351-358. [pmid: 6442755].
105 Burstein H J, Winer E P. Primary care for survivors of breast cancer.[see comment]. N Engl J Med. 2000;343(15):1086-1094. [pmid: 11027744].
106 Busch H, Barth-Olofsson A S, Rosenhagen S, Collins A. Menopausal transition and psychological development. Menopause. 2003;10(2):179-187. [pmid: 12627045].
107 Cagnacci A, Melis G B, Paoletti A M, Soldani R, Fioretti P. Interaction between veralipride and the endogenous opioid system in the regulation of body temperature in postmenopausal women. Life Sciences. 1988;42(5):547-553. [pmid: 3339948].
108 Cagnacci A, Neri I, Tarabusi M, Volpe A, Facchinetti F. Effect of long-term local or systemic hormone replacement therapy on post-menopausal mood disturbances. Influences of socio-economic and personality factors. Maturitas. 1999;31(2):111-116. [pmid: 10227003].
109 Cairney J, Wade T J. The influence of age on gender differences in depression: further population-based evidence on the relationship between menopause and the sex difference in depression. Social Psychiatry & Psychiatric Epidemiology. 2002;37(9):401-408. [pmid: 12242615].
110 Calvaresi E, Bryan J. Symptom experience in Australian men and women in midlife. Maturitas. 2003;44(3):225-236. [pmid: 12648886].
111 Carpenter J S, Andrykowski M A. Menopausal symptoms in breast cancer survivors. Oncol Nurs Forum. 1999;26(8):1311-1317. [pmid: 10497770].
112 Carranza-Lira S, Cortes-Fuentes E. Modification of vasomotor symptoms after various treatment modalities in the postmenopause. Int J Gynaecol Obstet. 2001;73(2):169-171. [pmid: 11336741].
113 Castelo-Branco C, Casals E, Figueras F, et al. Two-year prospective and comparative study on the effects of tibolone on lipid pattern, behavior of apolipoproteins AI and B. Menopause. 1999;6(2):92-97. [pmid: 10374214].
114 Castelo-Branco C, Vicente J J, Figueras F, et al. Comparative effects of estrogens plus androgens and tibolone on bone, lipid pattern and sexuality in postmenopausal women. Maturitas. 2000;34(2):161-168. [pmid: 10714911].
115 Celentano E, Galasso R, Berrino F, et al. Correlates of age at natural menopause in the cohorts of EPIC-Italy. Tumori. 2003;89(6):608-614. [pmid: 14870825].
116 Celik H, Ayar A, Tug N, Cikim G, Kilic N, Parmaksiz C. Effects of tibolone on plasma homocysteine levels in postmenopausal women. Fertil Steril. 2002;78(2):347-350. [pmid: 12137873].
117 Chaby L, Grinsztein A, Weitzman J J, de Bodinat C, Dagens V. [Anxiety-related and depressive disorders in women during the premenopausal and menopausal period. Study of the efficacy and acceptability of tianeptine versus maprotiline]. [French]. Presse Medicale. 1133;22(24):1133-1138.
118 Chakravarti S, Collins W P, Forecast J D, Newton J R, Oram D H, Studd J W. Hormonal profiles after the menopause. British Medical Journal. 1976;2(6039):784-787. [pmid: 974609].
119 Chavez M L, Spitzer M F. Herbals and other dietary supplements for premenstrual syndrome and menopause. Psychiatric Annals. 2002;32(1):61-71.
120 Chen L C, Tsao Y T, Yen K Y, Chen Y F, Chou M H, Lin M F. A pilot study comparing the clinical effects of Jia-Wey Shiau-Yau San, a traditional Chinese herbal prescription, and a continuous combined hormone replacement therapy in postmenopausal women with climacteric symptoms. Maturitas. 2003;44(1):55-62. [pmid: 12568736].
121 Chen Y C, Chen G D, Hu S W, Lin T L, Lin L Y. Is the occurrence of storage and voiding dysfunction affected by menopausal transition or associated with the normal aging process?. Menopause. 2003;10(3):203-208. [pmid: 12792290].
122 Cherrington A, Lewis C E, McCreath H E, Herman C J, Richter D L, Byrd T. Association of complementary and alternative medicine use, demographic factors, and perimenopausal symptoms in a multiethnic sample of women: The ENDOW study. Family & Community Health. 2003;26(1):74-83. [pmid: 12802130].
123 Chiazze L Jr, Brayer F T, Macisco J J Jr, Parker M P, Duffy B J. The length and variability of the human menstrual cycle. JAMA. 1968;203(6):377-380. [pmid: 5694118].
124 Chiechi L M, Putignano G, Guerra V, Schiavelli M P, Cisternino A M, Carriero C. The effect of a soy rich diet on the vaginal epithelium in postmenopause: a randomized double blind trial. Maturitas. 2003;45(4):241-246. [pmid: 12927310].
125 Chlebowski R T, Kim J A, Col N F. Estrogen deficiency symptom management in breast cancer survivors in the changing context of menopausal hormone therapy. Seminars in Oncology. 2003;30(6):776-788. [pmid: 14663778].
126 Chlebowski R T, McTiernan A. Elements of informed consent for hormone replacement therapy in patients with diagnosed breast cancer. J Clin Oncol. 1999;17(1):130-142. [pmid: 10458226].
127 Chopin Lucks B. The Vitex agnus castus dilemma: ethical management of a double-edged oil. Aromatheraphy Today. 2003;27:24-27.
128 Christodoulakos G E, Lambrinoudaki I V, Vourtsi A D, Panoulis K P, Kelekis D A, Creatsas G C. Mammographic changes associated with raloxifene and tibolone therapy in postmenopausal women: a prospective study.[comment]. Menopause. 2002;9(2):110-116. [pmid: 11875329].
129 Cicinelli E, Petruzzi D, Scorcia P, Resta L. Effects of progesterone administered by nasal spray on the human postmenopausal endometrium. Maturitas. 1993;18(1):65-72. [pmid: 8107618].
130 Cittadini J, Ben J, Badano A R, et al. [Use of a new steroid (Org OD 14) in the climacteric syndrome]. [Spanish]. Reproduccion. 1982;6(2):69-79. [pmid: 6814971].
131 Clayden J R. Effect of clonidine on menopausal flushing. Lancet. 1972;2(7791):1361. [pmid: 4118219].
132 Clayden J R, Bell J W. Control of menopausal flushes. British Medical Journal. 1973;4:44.
133 Cobleigh M. Estrogen replacement therapy in breast cancer surviviors. JAMA. 1994;272:540-545. [pmid: 8046809].
134 Colacurci N, Fornaro F, De Franciscis P, Palermo M, del Vecchio W. Effects of different types of hormone replacement therapy on mammographic density. Maturitas. 2001;40(2):159-164. [pmid: 11716994].
135 Colacurci N, Mele D, De Franciscis P, Costa V, Fortunato N, De Seta L. Effects of tibolone on the breast. European Journal of Obstetrics, Gynecology, & Reproductive Biology. 1998;80(2):235-238.
136 Collins A, Landgren B M. Reproductive health, use of estrogen and experience of symptoms in perimenopausal women: a population-based study. Maturitas. 1994;20(23):101-111. [pmid: 7715461].
137 Conboy L, Domar A, O'Connell E. Women at mid-life: symptoms, attitudes, and choices, an internet based survey. Maturitas. 2001;38(2):129-136. [pmid: 11306201].
138 Cooke D, Greene J. Types of life events in relation to symptoms at the climacterium. Journal of Psychosomatic Research. 1981;25(1):5-11. [pmid: 7277267].
139 Cooper A, Spencer C, Whitehead M I, Ross D, Barnard G J, Collins W P. Systemic absorption of progesterone from Progest cream in postmenopausal women. [Letter]. Lancet. 1998;351:1255-1256.
140 Cooper G S, Baird D D, Darden F R. Measures of menopausal status in relation to demographic, reproductive, and behavioral characteristics in a population-based study of women aged 35–49 years. Am J Epidemiol. 2001;153(12):1159-1165. [pmid: 11415950].
141 Cooper G S, Baird D D, Weinberg C R, Ephross S A, Sandler D P. Age at menopause and childbearing patterns in relation to mortality. Am J Epidemiol. 2000;151(6):620-623. [pmid: 10733044].
142 Cooper G S, Sandler D P. Age at natural menopause and mortality. Annals of Epidemiology. 1998;8(4):229-235. [pmid: 9590601].
143 Coppen A, Bishop M, Beard R J, Barnard G J, Collins W P. Hysterectomy, hormones, and behaviour. A prospective study. Lancet. 1981;1(8212):126-128. [pmid: 6109801].
144 Coulam C B, Adamson S C, Annegers J F. Incidence of premature ovarian failure. Obstetrics & Gynecology. 1986;67(4):604-606. [pmid: 3960433].
145 Couzi R J, Helzlsouer K J, Fetting J H. Prevalence of menopausal symptoms among women with a history of breast cancer and attitudes toward estrogen replacement therapy. J Clin Oncol. 1995;13(11):2737-2744. [pmid: 7595732].
146 Cowan M M, Gregory L W. Responses of pre- and post-menopausal females to aerobic conditioning. Medicine & Science in Sports & Exercise. 1985;17(1):138-143. [pmid: 3982268].
147 Cramer D W, Xu H. Predicting age at menopause. Maturitas. 1996;23(3):319-326. [pmid: 8794427].
148 Creidi P, Faivre B, Agache P, Richard E, Haudiquet V, Sauvanet J P. Effect of a conjugated oestrogen (Premarin) cream on aging facial skin. A comparative study with a placebo cream. Maturitas. 1994;19(3):211-223. [pmid: 7799828].
149 Crona N, Samsioe G, Lindberg U B, Silfverstolpe G. Treatment of climacteric complaints with Org OD 14: a comparative study with oestradiol valerate and placebo. Maturitas. 1988;9(4):303-308. [pmid: 3288845].
150 Cummings S R, Duong, et al. Serum estradiol level and risk of breast cancer during treatment with raloxifene. JAMA. 2002;287(2):216-220. [pmid: 11779264].
151 Cummings J A, Brizendine L. Comparison of physical and emotional side effects of progesterone or medroxyprogesterone in early postmenopausal women. Menopause. 2002;9(4):253-263. [pmid: 12082361].
152 Cutler W B, Garcia C R, McCoy N. Perimenopausal sexuality. Archives of Sexual Behavior. 1987;16(3):225-234. [pmid: 3606379].
153 Daly E, Gray A, Barlow D, McPherson K, Roche M, Vessey M. Measuring the impact of menopausal symptoms on quality of life.[see comment]. BMJ. 1993;307(6908):836-840. [pmid: 8401125].
154 Daly R C, Danaceau M A, Rubinow D R, Schmidt P J. Concordant Restoration of Ovarian Function and Mood in Perimenopausal Depression. Am J Psychiatry. 2003;160(10):1842-1846. [pmid: 14514500].
155 Dancey D R, Hanly P J, Soong C, Lee B, Hoffstein V. Impact of menopause on the prevalence and severity of sleep apnea. Chest. 2001;120(1):151-155. [pmid: 11451831].
156 Danforth D R, Arbogast L K, Mroueh J, et al. Dimeric inhibin: a direct marker of ovarian aging. Fertil Steril. 1998;70(1):119-123. [pmid: 9660432].
157 Davis J M, Sargent R G, Brayboy T D, Bartoli W P. Thermogenic effects of pre-prandial and post-prandial exercise in obese females. Addictive Behaviors. 1992;17(2):185-190. [pmid: 1585845].
158 Davis M C, Matthews K A, Meilahn E N, Kiss J E. Are job characteristics related to fibrinogen levels in middle-aged women?. Health Psychology. 1995;14(4):310-318. [pmid: 7556034].
159 Davis R. Physiatry -- The Practice of Physical Therapy by a Physician. Dynamic Chiropractic. 1993;11(25).
160 Davis S. Testosterone and sexual desire in women. Journal of Sex Education & Therapy. 2000;25(1):25-32.
161 Davis S R. The clinical use of androgens in female sexual disorders. Journal of Sex & Marital Therapy. 1998;24(3):153-163. [pmid: 9670121].
162 Davis S R. Menopause: new therapies. Med J Aust. 2003;178(12):634-637. [pmid: 12797852].
163 Davis S R, Goldstat R, Newman A, et al. Differing effects of low-dose estrogen-progestin therapy and pravastatin in postmenopausal hypercholesterolemic women. Climacteric. 2002;5(4):341-350. [pmid: 12626213].
164 Davis S R, McCloud P, Strauss B J, Burger H. Testosterone enhances estradiol's effects on postmenopausal bone density and sexuality. Maturitas. 1995;21(3):227-236. [pmid: 7616872].
165 Davis S R, Walker K Z, Strauss B J. Effects of estradiol with and without testosterone on body composition and relationships with lipids in postmenopausal women. Menopause. 2000;7(6):395-401. [pmid: 11127762].
166 de Aloysio D, Fabiani A G, Mauloni M, Bottiglioni F. Analysis of the climacteric syndrome.[erratum appears in Maturitas 1989 Jun;11(2):169]. Maturitas. 1989;11(1):43-53. [pmid: 2725336].
167 de Beer F, Smelt A H, van Vark L C, Hoogerbrugge N, Havekes L M, Gevers Leuven J A. The effect of tibolone on the lipoprotein profile of postmenopausal women with type III hyperlipoproteinemia. J Intern Med. 2002;251(2):148-155. [pmid: 11908467].
168 de Novaes Soares C, Almeida O P. Depression during the perimenopause. Arch Gen Psychiatry. 2001;58(3):306.
169 de Vries E, den Tonkelaar I, van Noord P A, van der Schouw Y T, te Velde E R, Peeters P H. Oral contraceptive use in relation to age at menopause in the DOM cohort. Human Reproduction. 2001;16(8):1657-1662. [pmid: 11473959].
170 Deeks A A, McCabe M P. Well-being and menopause: an investigation of purpose in life, self- acceptance and social role in premenopausal, perimenopausal and postmenopausal women. Qual Life Res. 2004;13(2):389-398. [pmid: 15085911].
171 Demetrio F N, Reno J Jr, Goncves M A, et al. Conjugated estrogens therapy and mood in postmenopausal women: Preliminary results. Revista de Psiquiatria Clinica. 2001;28(2):89-93.
172 den Tonkelaar I, te Velde E R, Looman C W. Menstrual cycle length preceding menopause in relation to age at menopause. Maturitas. 1998;29(2):115-123. [pmid: 9651900].
173 Denham A, Green J, Hawkey S, Ingram J. Choice of an outcome measure for a pilot randomized controlled trial into the treatment by herbal practitioners of symptoms associated with the menopause. Focus on Alternative and Complementary Therapies. 2003;8(4):493.
174 Dennerstein L. Depression in the menopause. Obstetrics & Gynecology Clinics of North America. 1987;14(1):33-48. [pmid: 3627657].
175 Dennerstein L, Burrows G D. Hormone replacement therapy and sexuality in women. Clinics in Endocrinology & Metabolism. 1982;11(3):661-679. [pmid: 6814799].
176 Dennerstein L, Dudley E C, Guthrie J R. Predictors of declining self-rated health during the transition to menopause. Journal of Psychosomatic Research. 2003;54(2):147-153. [pmid: 12573736].
177 Dennerstein L, Lehert P, Burger H, Dudley E. Factors affecting sexual functioning of women in the mid-life years. Climacteric. 1999;2(4):254-262. [pmid: 11910659].
178 Desgor J. Menopause. Homeopath Int. 1989;3(2):14.
179 Dias R, Kerr-Correa F, Moreno RA, et al. Hrt with androgen as a strategy to treat postmenopausal depression: preliminary results. International Journal of Neuropsychopharmacology. 2002;5(Suppl 1).
180 Diers C J. Historical trends in the age at menarche and menopause. Psychological Reports. 1974;34(3):931-937. [pmid: 4603116].
181 Dixon J M. Hormone replacement therapy and the breast. Surgical Oncology. 2003;12(4):251-263. [pmid: 14998565].
182 Do K A, Treloar S A, Pandeya N, et al. Predictive factors of age at menopause in a large Australian twin study. Human Biology. 1998;70(6):1073-1091.
183 Dog T, Riley D, Carter T. An integrative approach to menopause. Alternative Therapies in Health and Medicine. 2001;7(4):45-55. quiz 56-47. [pmid: 11452567].
184 Doren M, Rubig A, Coelingh Bennink H J, Holzgreve W. Impact on uterine bleeding and endometrial thickness: tibolone compared with continuous combined estradiol and norethisterone acetate replacement therapy. Menopause. 1999;6(4):299-306. [pmid: 10614676].
185 Doren M, Rubig A, Coelingh Bennink H J, Holzgreve W. Differential effects on the androgen status of postmenopausal women treated with tibolone and continuous combined estradiol and norethindrone acetate replacement therapy. Fertil Steril. 2001;75(3):554-559. [pmid: 11239541].
186 Dow M G, Hart D M, Forrest C A. Hormonal treatments of sexual unresponsiveness in postmenopausal women: a comparative study. Br J Obstet Gynaecol. 1983;90(4):361-366. [pmid: 6682336].
187 Dowsett M, Cantwell B, Lal A, Jeffcoate S L, Harris A L. Suppression of postmenopausal ovarian steroidogenesis with the luteinizing hormone-releasing hormone agonist goserelin. J Clin Endocrinol Metab. 1988;66(4):672-677. [pmid: 2964454].
188 Duffy C, Cyr M. Phytoestrogens: potential benefits and implications for breast cancer survivors. Journal of Women's Health. 2003;12(7):617-631.
189 Dunn L B, Damesyn M, Moore A A, Reuben D B, Greendale G A. Does estrogen prevent skin aging? Results from the First National Health and Nutrition Examination Survey (NHANES I). Arch Dermatol. 1997;133:339-342. [pmid: 9080894].
190 Eden J A. Oestrogen and the breast. 2. The management of the menopausal woman with breast cancer. Med J Aust. 1992;157(4):247-250. [pmid: 1435440].
191 Egarter C, Eppel W, Vogel S, Wolf G. A pilot study of hormone replacement therapy with tibolone in women with mastopathic breasts. Maturitas. 2001;40(2):165-171. [pmid: 11716995].
192 Egarter C, Sator M, Huber J. Effects of tibolone on cell adhesion molecules in postmenopausal women. Menopause. 2003;10(3):218-221. [pmid: 12792293].
193 Engel N S. Menopausal stage, current life change, attitude toward women's roles, and perceived health status. Nursing Research. 1987;36(6):353-357. [pmid: 3671122].
194 Ernst E, White A. Life-threatening adverse reactions after acupuncture? A systematic review. Pain. 1997;71:123-126. [pmid: 9211472].
195 Everson R B, Sandler D P, Wilcox A J, Schreinemachers D, Shore D L, Weinberg C. Effect of passive exposure to smoking on age at natural menopause. British Medical Journal Clinical Research Ed. 1986;293(6550):792. [pmid: 3094660].
196 Everson S A, Matthews K A, Guzick D S, Wing R R, Kuller L H. Effects of surgical menopause on psychological characteristics and lipid levels: the Healthy Women Study. Health Psychology. 1995;14(5):435-443. [pmid: 7498115].
197 Facchinetti F, Nappi R E, Tirelli A, Polatti F, Nappi G. Hormone supplementation differently affects migraine in postmenopausal women. Headache. 2002;42(9):924-929. [pmid: 12390622].
198 Faddy M J, Gosden R G, Gougeon A, Richardson S J, Nelson J F. Accelerated disappearance of ovarian follicles in mid-life: implications for forecasting menopause. Human Reproduction. 1992;7(10):1342-1346. [pmid: 1291557].
199 Farish E, Barnes J F, Fletcher C D, Ekevall K, Calder A, Hart D M. Effects of tibolone on serum lipoprotein and apolipoprotein levels compared with a cyclical estrogen/progestogen regimen. Menopause. 1999;6(2):98-104. [pmid: 10374215].
200 Ferrell B R, Grant M M, Funk B, Otis-Green S, Garcia N. Quality of life in breast cancer survivors as identified by focus groups. Psycho-Oncology. 1997;6(1):13-23. [pmid: 9126712].
201 Finck G, Barton D L, Loprinzi C L, Quella S K, Sloan J A. Definitions of hot flashes in breast cancer survivors. Journal of Pain & Symptom Management. 1998;16(5):327-333. [pmid: 9846028].
202 Finset A, Overlie I, Holte A. Musculo-skeletal pain, psychological distress, and hormones during the menopausal transition. Psychoneuroendocrinology. 2004;29(1):49-64. [pmid: 14575729].
203 Fistonic I, Srecko C, Marina F, Ivan S. Menopause in Croatia. Socio-demographic characteristics, women's attitudes and source of information, compliance with HRT. Maturitas. 2004;47(2):91-98. [pmid: 14757267].
204 Fitzpatrick L A, Santen R J. Hot flashes: the old and the new, what is really true?[comment]. Mayo Clinic Proceedings. 2002;77(11):1155-1158. [pmid: 12440549].
205 Flint M, Kronenberg F, Utian W, eds. Multidisciplinary perspectives on menopause: (1990). xii, 488pp.; 1990. Annals of the New York Academy of Sciences, Vol 592.
206 Force USPST. Postmenopausal hormone replacement therapy for primary prevention of chronic conditions: recommendations and rationale.[summary for patients in Ann Intern Med. 2002 Nov 19;137(10):I48; PMID: 12435233]. Ann Intern Med. 2002;137(10):834–839.
207 Foster D C, Palmer M, Marks J. Effect of vulvovaginal estrogen on sensorimotor response of the lower genital tract: a randomized controlled trial. Obstetrics & Gynecology. 1999;94(2):232-237. [pmid: 10432134].
208 Fraumeni J F Jr, Lloyd J W, Smith E M, Wagoner J K. Cancer mortality among nuns: role of marital status in etiology of neoplastic disease in women. J Natl Cancer Inst. 1969;42(3):455-468. [pmid: 5777491].
209 Freedman R R, Dinsay R. Clonidine raises the sweating threshold in symptomatic but not in asymptomatic postmenopausal women. Fertil Steril. 2000;74(1):20-23. [pmid: 10899491].
210 Freedman R R, Norton D, Woodward S, Cornelissen G. Core body temperature and circadian rhythm of hot flashes in menopausal women. J Clin Endocrinol Metab. 1995;80(8):2354-2358. [pmid: 7629229].
211 Freedman R R, Woodward S. Behavioral treatment of menopausal hot flushes: evaluation by ambulatory monitoring. Am J Obstet Gynecol. 1992;167(2):436-439. [pmid: 1497048].
212 Freedman R R, Woodward S, Sabharwal S C. Alpha 2-adrenergic mechanism in menopausal hot flushes. Obstetrics & Gynecology. 1990;76(4):573-578. [pmid: 2170883].
213 Freeman E W, Grisso J A, Berlin J, Sammel M, Garcia-Espana B, Hollander L. Symptom reports from a cohort of African American and white women in the late reproductive years. Menopause. 2001;8(1):33-42. [pmid: 11201513].
214 Freeman E W, Sammel M D, Grisso J A, Battistini M, Garcia-Espagna B, Hollander L. Hot flashes in the late reproductive years: risk factors for Africa American and Caucasian women. J Womens Health Gender Based Med. 2001;10(1):67-76.
215 Frey G. Oversights detract from CME article on menopause. Alternative Therapies in Health and Medicine. 2001;7(6):20-21.
216 Friebely J S, Shifren J L, Schiff I, Regestein Q R. Preliminary observations on differing psychological effects of conjugated and esterified estrogen treatments. J Womens Health Gender Based Med. 2001;10(2):181-187.
217 Friedlander M, Thewes B. Counting the costs of treatment: the reproductive and gynaecological consequences of adjuvant therapy in young women with breast cancer. Internal Medicine Journal. 2003;33(8):372-379. [pmid: 12895170].
218 Fu S Y, Anderson D, Courtney M. Cross-cultural menopausal experience: comparison of Australian and Taiwanese women. Nursing & Health Sciences. 2003;5(1):77-84. [pmid: 12603724].
219 Fuh J L, Wang S J, Lu S R, Juang K D, Lee S J. Alterations in cognitive function during the menopausal transition. Journal of the American Geriatrics Society. 2003;51(3):431-432. [pmid: 12588594].
220 Fuh J-L, Wang S-J, Lu S-R, Juang K-D, Lee S-J. Alterations in cognitive function during the menopausal transition. Journal of the American Geriatrics Society. 2003;51(3):431-432. [pmid: 12588594].
221 Gallagher J C, Baylink D J, Freeman R, McClung M. Prevention of bone loss with tibolone in postmenopausal women: results of two randomized, double-blind, placebo-controlled, dose-finding studies. J Clin Endocrinol Metab. 2001;86(10):4717-4726. [pmid: 11600531].
222 Gambacciani M, Ciaponi M, Cappagli B, et al. A longitudinal evaluation of the effect of two doses of tibolone on bone density and metabolism in early postmenopausal women. Gynecol Endocrinol. 2004;18(1):9-16. [pmid: 15106359].
223 Gannon L. Endocrinology of menopause. Formanek, Ruth (Ed) (1990) The meanings of menopause: Historical medical and clinical perspectives (pp 179–237) xxv, 322pp; 1990.
224 Gannon L, Hansel S, Goodwin J. Correlates of menopausal hot flashes. Journal of Behavioral Medicine. 1987;10(3):277-285. [pmid: 3612784].
225 Gannon L, Stevens J. Portraits of menopause in the mass media. Women & Health. 1998;27(3):1-15.
226 Ganz P A. Menopause and breast cancer: symptoms, late effects, and their management. Seminars in Oncology. 2001;28(3):274-283. [pmid: 11402437].
227 Ganz P A, Greendale G A, Petersen L, Kahn B, Bower J E. Breast cancer in younger women: reproductive and late health effects of treatment. J Clin Oncol. 2003;21(22):4184-4193. [pmid: 14615446].
228 Ganz P A, Rowland J H, Desmond K, Meyerowitz B E, Wyatt G E. Life after breast cancer: understanding women's health-related quality of life and sexual functioning. J Clin Oncol. 1998;16(2):501-514. [pmid: 9469334].
229 Garcia Fantini M, Saavedra J, Garcia Alba M, Garcia M. Lipoprotein (A) and homocysteine after 12 months treatment with tibolone compared to raloxifene and no treatment in postmenopausal women (abstract). Climacteric. 2002;5(Supplement 1).
230 Garnett T, Studd J, Watson N, Savvas M, Leather A. The effects of plasma estradiol levels on increases in vertebral and femoral bone density following therapy with estradiol and estradiol with testosterone implants. Obstetrics & Gynecology. 1992;79(6):968-972. [pmid: 1579324].
231 Garrido-Latorre F, Lazcano-Ponce E C, Lopez-Carrillo L, Hernandez-Avila M. Age of natural menopause among women in Mexico City. Int J Gynaecol Obstet. 1996;53(2):159-166. [pmid: 8735297].
232 Gath D, Osborn M, Bungay G, et al. Psychiatric disorder and gynaecological symptoms in middle aged women: a community survey. British Medical Journal Clinical Research Ed. 1987;294(6566):213-218. [pmid: 3101815].
233 Genazzani A R, Petraglia F, Facchinetti F, et al. Effects of Org OD 14 on pituitary and peripheral beta-endorphin in castrated rats and post-menopausal women. Maturitas. Suppl. 1987;1:35-48.
234 Georgiadis AE, Siganos E, Papadimitrou G, Megapanos E. Comparison of tibolone and estrogens on their effect on postmenopausal bone loss over 5 years. Acta Obstet Gynecol Scand. 1997;76(Suppl 167(3).
235 Gigliotti B, Multinu A, Lai V R. Role of pivagabine in the treatment of climacteric syndrome. Arzneimittel-Forschung. 1997;47(11A):1317-1321. [pmid: 9450156].
236 Ginsberg J. What determines the age at the menopause?[see comment]. BMJ. 1991;302(6788):1288-1289. [pmid: 2059681].
237 Gitlin M J, Pasnau R O. Psychiatric syndromes linked to reproductive function in women: a review of current knowledge.[see comment]. Am J Psychiatry. 1989;146(11):1413-1422. [pmid: 2488677].
238 Gitlin N, Korner P, Yang H M. Liver function in postmenopausal women on estrogen-androgen hormone replacement therapy: a meta-analysis of eight clinical trials. Menopause. 1999;6(3):216-224. [pmid: 10486791].
239 Glass S, Shapiro M. Androgen-Estrogen Treatment in the Menopause. GP: General Practitioner. 1951;3(3):39-42.
240 Glazier M G, Bowman M A. A review of the evidence for the use of phytoestrogens as a replacement for traditional estrogen replacement therapy. Arch Intern Med. 2001;161(9):1161-1172. [pmid: 11343439].
241 Gokdeniz R, Taskin O, Atmaca R, Burak F, Wheeler JM. The impact of Hormone Replacement Therapy (HRT) and tibolone (OD) on urodynamic function in postmenopausal women: a randomized controlled study. Fertil Steril. 1999;72(Supplement 1).
242 Gold E B, Bromberger J, Crawford S, et al. Factors associated with age at natural menopause in a multiethnic sample of midlife women. Am J Epidemiol. 2001;153(9):865-874. [pmid: 11323317].
243 Goodman M J, Grove J S, Gilbert F Jr. Age at menopause in relation to reproductive history in Japanese, Caucasian, Chinese and Hawaiian women living in Hawaii. Journal of Gerontology. 1978;33(5):688-694. [pmid: 299558].
244 Goodman M J, Stewart C J, Gilbert F Jr. Patterns of menopause: a study of certain medical and physiological variables among Caucasian and Japanese women living in Hawaii. Journal of Gerontology. 1977;32(3):291-298. [pmid: 850056].
245 Gosden R G. Follicular status at the menopause. Hum Reprod. 1987;2(7):617-621. [pmid: 3316270].
246 Gottlieb N. Nonhormonal agents show promise against hot flashes. J Natl Cancer Inst. 2000;92(14):1118-1120. [pmid: 10904081].
247 Gougeon A, Ecochard R, Thalabard J C. Age-related changes of the population of human ovarian follicles: increase in the disappearance rate of non-growing and early-growing follicles in aging women. Biol Reprod. 1994;50(3):653-663. [pmid: 8167237].
248 Graf M C, Geller P A. Treating hot flashes in breast cancer survivors: a review of alternative treatments to hormone replacement therapy. Clinical Journal of Oncology Nursing. 2003;7(6):637-640. [pmid: 14705478].
249 Grattarola R. Androgens in breast cancer. I. Atypical endometrial hyperplasia and breast cancer in married premenopausal women. Am J Obstet Gynecol. 1973;116(3):423-428. [pmid: 4707544].
250 Greenblatt R B, Barfield W E, Garner J F, Calk G L, Harrod J P. Evaluation of an estrogen, androgen, estrogen-androgen combination and a placebo in the treatment of the menopause. J Clin Endocrinol. 1950;10:1547-1558.
251 Greenblatt R B, Bruneteau D W. Menopausal headaches--psychogenic or metabolic?. Journal of the American Geriatrics Society. 1974;22(4):186-190. [pmid: 4817748].
252 Greendale G A, Judd H L. The menopause: health implications and clinical management. Journal of the American Geriatrics Society. 1993;41(4):426-436. [pmid: 8463532].
253 Greendale G A, Lee N P, Arriola E R. The menopause. Lancet. 1999;353(9152):571-580. [pmid: 10028999].
254 Greendale G A, Petersen L, Zibecchi L, Ganz P A. Factors related to sexual function in postmenopausal women with a history of breast cancer. Menopause. 2001;8(2):111-119. [pmid: 11256871].
255 Greene J G, Cooke D J. Life stress and symptoms at the climacterium. British Journal of Psychiatry. 1980;136:486-491. [pmid: 7388253].
256 Grisso J A, Freeman E W, Maurin E, Garcia-Espana B, Berlin J A. Racial differences in menopause information and the experience of hot flashes. Journal of General Internal Medicine. 1999;14(2):98-103. [pmid: 10051780].
257 Groeneveld F, Bareman F, Barentsen R, Dokter H. Vasomotor symptoms and well-being in the climacteric years. Maturitas. 1996;23(3):293-299. [pmid: 8794423].
258 Grube B, Walper A, Wheatley D. St. John's Wort extract: efficacy for menopausal symptoms of psychological origin. Adv Ther. 1999;16(4):177-186. [pmid: 10623319].
259 Gruber D M, Sator M O, Kirchengast S, Joura E A, Huber J C. Effect of percutaneous androgen replacement therapy on body composition and body weight in postmenopausal women. Maturitas. 1998;29(3):253-259. [pmid: 9699197].
260 Guidozzi F. Estrogen replacement therapy in breast cancer survivors. Int J Gynaecol Obstet. 1999;64(1):59-63. [pmid: 10190671].
261 Haarbo J, Hassager C, Jensen S B, Riis B J, Christiansen C. Serum lipids, lipoproteins, and apolipoproteins during postmenopausal estrogen replacement therapy combined with either 19-nortestosterone derivatives or 17-hydroxyprogesterone derivatives. Am J Med. 1991;90(5):584-589. [pmid: 1827568].
262 Hackbert L, Heiman J R. Acute dehydroepiandrosterone (DHEA) effects on sexual arousal in postmenopausal women. J Womens Health Gender Based Med. 2002;11(2):155-162.
263 Haggans C J, Hutchins A M, Olson B A, Thomas W, Martini M C, Slavin J L. Effect of flaxseed consumption on urinary estrogen metabolites in postmenopausal women. Nutrition & Cancer. 1999;33(2):188-195. [pmid: 10368815].
264 Hagstad A. Gynecology and sexuality in middle-aged women. Women & Health. 1988;13(34):57-80.
265 Hahn P M, Wong J, Reid R L. Menopausal-like hot flashes reported in women of reproductive age. Fertil Steril. 1998;70(5):913-918. [pmid: 9806575].
266 Hahn RA, Eaker E, Rolka H. Reliability of reported age at menopause.[erratum appears in Am J Epidemiol 1999 Jan 15;149(2):201]. Am J Epidemiol. 1997;146(9):771–775.
267 Hale G E, Hughes C L, Robboy S J, Agarwal S K, Bievre M. A double-blind randomized study on the effects of red clover isoflavones on the endometrium. Menopause. 2001;8(5):338-346. [pmid: 11528360].
268 Hammar M, Berg G. Clonidine in the treatment of menopausal flushing. A review of clinical studies. Acta Obstet Gynecol Scand Suppl. 1985;132:29-31. [pmid: 3895809].
269 Hammar M, Berg G, Lindgren R. Does physical exercise influence the frequency of postmenopausal hot flushes?. Acta Obstet Gynecol Scand. 1990;69(5):409-412. [pmid: 2270766].
270 Hanggi W, Lippuner K, Jaeger P, Birkhauser M H, Horber F F. Differential impact of conventional oral or transdermal hormone replacement therapy or tibolone on body composition in postmenopausal women. Clin Endocrinol. 1998;48(6):691-699.
271 Hanggi W, Lippuner K, Riesen W, Jaeger P, Birkhauser M H. Long-term influence of different postmenopausal hormone replacement regimens on serum lipids and lipoprotein(a): a randomised study. Br J Obstet Gynaecol. 1997;104(6):708-717. [pmid: 9197875].
272 Harbour KE. The use of medroxyprogesterone acetate versus micronized progesterone in postmenopausal women: Neuropsychological and psychological implications, California School Of Professional Psychology - Berkeley/Alameda, US, 1.; 1999.
273 Hardy R, Kuh D, Wadsworth M. Smoking, body mass index, socioeconomic status and the menopausal transition in a British national cohort. International Journal of Epidemiology. 2000;29(5):845-851. [pmid: 11034967].
274 Harlow B L, Cohen L S, Otto M W, Spiegelman D, Cramer D W. Prevalence and predictors of depressive symptoms in older menopausal women: The Harvard study of moods and cycles. Arch Gen Psychiatry. 1999;56(5):418-424. [pmid: 10232296].
275 Harlow B L, Cramer D W, Annis K M. Association of medically treated depression and age at natural menopause. Am J Epidemiol. 1995;141(12):1170-1176. [pmid: 7771455].
276 Harlow B L, Signorello L B. Factors associated with early menopause. Maturitas. 2000;35(1):3-9. [pmid: 10802394].
277 Harlow B L, Wise L A, Otto M W, Soares C N, Cohen L S. Depression and its influence on reproductive endocrine and menstrual cycle markers associated with perimenopause: the Harvard Study of Moods and Cycles. Arch Gen Psychiatry. 2003;60(1):29-36. [pmid: 12511170].
278 Harris P F, Remington P L, Trentham-Dietz A, Allen C I, Newcomb P A. Prevalence and treatment of menopausal symptoms among breast cancer survivors. Journal of Pain & Symptom Management. 2002;23(6):501-509. [pmid: 12067774].
279 Harrison R F. Ethamsylate in the treatment of climacteric flushing. Maturitas. 1981;3(1):31-37. [pmid: 6789032].
280 Hee J, MacNaughton J, Bangah M, Burger H G. Perimenopausal patterns of gonadotrophins, immunoreactive inhibin, oestradiol and progesterone. Maturitas. 1993;18(1):9-20. [pmid: 8107620].
281 Hemminki E, Topo P, Kangas I. Experience and opinions of climacterium by Finnish women. European Journal of Obstetrics, Gynecology, & Reproductive Biology. 1995;62(1):81-87.
282 Henderson V W, Paganini-Hill A, Miller B L, et al. Estrogen for Alzheimer's disease in women: randomized, double-blind, placebo-controlled trial. Neurology. 2000;54(2):295-301. [pmid: 10668686].
283 Heudens-Mast H. Hot flashes. New England Journal of Homeopathy. 1994;3(4):11.
284 Heuser I. Depression, endocrinologically a syndrome of premature aging?. Maturitas. 2002;41(Suppl 1):S19-23. [pmid: 11955792].
285 Hlatky M A, Boothroyd D, Vittinghoff E, et al. Quality-of-life and depressive symptoms in postmenopausal women after receiving hormone therapy: results from the Heart and Estrogen/Progestin Replacement Study (HERS) trial.[see comment]. JAMA. 2002;287(5):591-597. [pmid: 11829697].
286 Hoda D, Perez D G, Loprinzi C L. Hot flashes in breast cancer survivors. Breast Journal. 2003;9(5):431-438. [pmid: 12968972].
287 Hoegler N. St. John's Wort Relieves Menopause Symptoms. Herbalgram. 2000;50:27-28.
288 Hogervorst E, Williams J, Budge M, Riedel W, Jolles J. The nature of the effect of female gonadal hormone replacement therapy on cognitive function in post-menopausal women: a meta-analysis. Neuroscience. 2000;101(3):485-512. [pmid: 11113299].
289 Holte A. Influences of natural menopause on health complaints: a prospective study of healthy Norwegian women.[see comment]. Maturitas. 1992;14(2):127-141. [pmid: 1565021].
290 Holte A, Mikkelsen A. Psychosocial determinants of climacteric complaints. Maturitas. 1991;13(3):205-215. [pmid: 1943828].
291 Holte A, Mikkelsen A. The menopausal syndrome: a factor analytic replication. Maturitas. 1991;13(3):193-203. [pmid: 1943827].
292 Huerta R, Mena A, Malacara J M, de Leon J D. Symptoms at the menopausal and premenopausal years: their relationship with insulin, glucose, cortisol, FSH, prolactin, obesity and attitudes towards sexuality. Psychoneuroendocrinology. 1995;20(8):851-864. [pmid: 8834092].
293 Huerta R, Mena A, Malacara J M, Diaz de Leon J. Symptoms at perimenopausal period: Its association with attitudes toward sexuality, life-style, family function, and FSH levels. Psychoneuroendocrinology. 1995;20(2):135-148. [pmid: 7899534].
294 Hulka B S, Meirik O. Research on the menopause. Maturitas. 1996;23(2):109-112.
295 Hunskar S, Brugio K, Diokno A, Herzog A R, Hjalmas K, Lapitan M C. Epidemiology and natural history of urinary incontinence in women. Urology. 2003;62(4 Suppl 1):16-23. [pmid: 14550833].
296 Hunter A. Cimicifuga racemosa: pharmacology, clinical trials and clinical use. European Journal of Herbal Medicine. 1999;5(1):19-25.
297 Hunter M. The south-east England longitudinal study of the climacteric and postmenopause.[see comment]. Maturitas. 1992;14(2):117-126. [pmid: 1565020].
298 Hunter M, Battersby R, Whitehead M. Relationships between psychological symptoms, somatic complaints and menopausal status. Maturitas. 1986;8(3):217-228. [pmid: 3784918].
299 Hunter M S. Psychological and somatic experience of the menopause: a prospective study. Psychosomatic Medicine. 1990;52(3):357-367. [pmid: 2367623].
300 Huntley A. Complementary therapies for the relief of menopausal symptoms. Focus on Alternative and Complementary Therapies. 2002;7(2):121-125.
301 Huntley A. Complementary therapies for menopausal symptoms. Focus on Alternative and Complementary Therapies. 2003;8(1):143.
302 Huntley A, Ernst E. A systematic review of plant-based products for the treatment of menopausal symptoms. Focus on Alternative and Complementary Therapies. 2002;7(1):96.
303 Huntley A, Ernst E. A Systematic Review of Plant-Based Products for the Treatment of Menopausal Symptoms. Journal of Herbal Pharmacotherapy. 2003;3/1:33–34.
304 Irvin JHA. The effects of relaxation response training on the frequency and intensity of menopausal hot flash symptoms: Dissertation Abstracts International: Section B: the Sciences & Engineering. Vol 55(6-B), 1994, 2391, US: Univ Microfilms International., U Kentucky, KY, US, 1.; 1994.
305 Jackson B B, Taylor J, Pyngolil M. How age conditions the relationship between climacteric status and health symptoms in African American women. Res Nurs Health. 1991;14(1):1-9. [pmid: 2017577].
306 Jacobs P A, Hyland M E, Ley A. Self-rated menopausal status and quality of life in women aged 40–63 years. British Journal of Health Psychology. 2000;5(Part4):395-411.
307 Janson P O, Dennefors B, Hamberger L. The ageing ovary. Acta Obstet Gynecol Scand Suppl. 1981;106:7-9. [pmid: 6804560].
308 Ji P, Ma R H, Wang Z X. Body acupuncture plus ear pressing in the treatment of menopausal syndrome. International Journal of Clinical Acupuncture. 1998;9(4):471-473.
309 Jiroutek M R, Chen M H, Johnston C C, Longcope C. Changes in reproductive hormones and sex hormone-binding globulin in a group of postmenopausal women measured over 10 years. Menopause. 1998;5(2):90-94. [pmid: 9689202].
310 Joffe H, Hall J E, Soares C N, et al. Vasomotor symptoms are associated with depression in perimenopausal women seeking primary care.[see comment]. Menopause. 2002;9(6):392-398. [pmid: 12439097].
311 Johnston S L. Associations with age at natural menopause in Blackfeet women. American Journal of Human Biology. 2001;13(4):512-520. [pmid: 11400222].
312 Johnston S L. Menopause in Blackfeet women--a life span perspective. Collegium Antropologicum. 2003;27(1):57-66. [pmid: 12974133].
313 Jokinen K, Rautava P, Makinen J, Ojanlatva A, Sundell J, Helenius H. Experience of climacteric symptoms among 42–46 and 52–56-year-old women. Maturitas. 2003;46(3):199-205. [pmid: 14585522].
314 Jones C R, Czajkowski L. Evaluation and management of insomnia in menopause. Clinical Obstetrics & Gynecology. 2000;43(1):184-197. [pmid: 10694999].
315 Judd H L, Judd G E, Lucas W E, Yen S S. Endocrine function of the postmenopausal ovary: concentration of androgens and estrogens in ovarian and peripheral vein blood. J Clin Endocrinol Metab. 1974;39(6):1020-1024. [pmid: 4430702].
316 Judd H L, Shamonki I M, Frumar A M, Lagasse L D. Origin of serum estradiol in postmenopausal women. Obstetrics & Gynecology. 1982;59(6):680-686. [pmid: 7078905].
317 Kaleli B, Yildirim B, Demir S, Alatas E. Effects of low-dose 17-beta-estradiol plus norethisterone acetate and tibolone on fasting plasma homocysteine levels in postmenopausal women. Acta Obstet Gynecol Scand. 2003;82(12):1107-1111. [pmid: 14616255].
318 Kapetanakis E, Dmowski W P, Auletta F, Scommegna A. Endocrine and clinical effects of estradiol and testosterone pellets used in long-term replacement therapy. Int J Gynaecol Obstet. 1982;20(5):387-399. [pmid: 6128271].
319 Kaufert P A, Gilbert P. The context of menopause: psychotropic drug use and menopausal status. Soc Sci Med. 1986;23(8):747-755. [pmid: 3798154].
320 Kemeter P, Feichtinger W. Prednisolone supplementation to Clomid and/or gonadotropin stimulation for in-vitro fertilization - A prospective randomized trial. Hum Reprod. 1986;1(7):441-444. [pmid: 2952668].
321 Kerr M M. Amitriptyline in emotional states at the menopause. New Zealand Medical Journal. 1970;72(461):243-245. [pmid: 4922592].
322 Kessler R C, McGonagle K A, Swartz M, Blazer D G, Nelson C B. Sex and depression in the National Comorbidity Survey. I: Lifetime prevalence, chronicity and recurrence. Journal of Affective Disorders. 1993;29(23):85-96. [pmid: 8300981].
323 Kicovic P M, Cortes-Prieto J, Luisi M, Milojevic S, Franchi F. Placebo-controlled cross-over study of effects of Org OD 14 in menopausal women. Reproduction. 1982;6(2):81-91.
324 Kimmick GG, Lovato J, McQuellon R, Robinson E, Muss H. Randomized, placebo-controlled study of sertraline (Zoloft TM) for the treatment of hot flashes in women with early stage breast cancer taking tamoxifen. Proc Am Soc Clin Oncol. 2001;20(397a):abst 1585.
325 Kirkham C, Hahn P M, Van Vugt D A, Carmichael J A, Reid R L. A randomized, double-blind, placebo-controlled, cross-over trial to assess the side effects of medroxyprogesterone acetate in hormone replacement therapy. Obstetrics & Gynecology. 1991;78(1):93-97. [pmid: 1828550].
326 Klein N A, Illingworth P J, Groome N P, McNeilly A S, Battaglia D E, Soules M R. Decreased inhibin B secretion is associated with the monotropic FSH rise in older, ovulatory women: a study of serum and follicular fluid levels of dimeric inhibin A and B in spontaneous menstrual cycles. J Clin Endocrinol Metab. 1996;81(7):2742-2745. [pmid: 8675606].
327 Klein P, Versi E, Herzog A. Mood and the menopause. Br J Obstet Gynaecol. 1999;106(1):1-4.
328 Knobf M T. The menopausal symptom experience in young mid-life women with breast cancer. Cancer Nursing. 2001;24(3):201-210. quiz 210-201. [pmid: 11409064].
329 Koninckx P R, Lauweryns J M, Cornillie F J. Endometrial effects during hormone replacement therapy with a sequential oestradiol valerate/cyproterone acetate preparation. Maturitas. 1993;16(2):97-110. [pmid: 8387151].
330 Kopernik G, Shoham Z. Tools for making correct decisions regarding hormone therapy. Part II. Organ response and clinical applications. Fertil Steril. 2004;81(6):1458-1477. [pmid: 15193461].
331 Kornstein S G, Schatzberg A F, Thase M E, et al. “Gender differences in treatment response to sertraline versus imipramine in chronic depression”: Reply. Am J Psychiatry. 2001;158(9):1532-1533.
332 Koster A. Change-of-life anticipations, attitudes, and experiences among middle-aged Danish women. Health Care Women Int. 1991;12(1):1-13. [pmid: 1989954].
333 Kotsopoulos D, Dalais F S, Liang Y L, McGrath B P, Teede H J. The effects of soy protein containing phytoestrogens on menopausal symptoms in postmenopausal women.[see comment]. Climacteric. 2000;3(3):161-167. [pmid: 11910617].
334 Kraft K, Coulon S. Acupuncture may temporarily relieve climacteric symptoms (Der Einflub einer standardisierten Akupunkturbehandlung auf Beschwerden, Blutdruck und Serumlipide hypertensiver, postmenopausaler Frauen.). Forsch Komplementarmed. 1999;6:74-79. [pmid: 10352369].
335 Krailo M D, Pike M C. Estimation of the distribution of age at natural menopause from prevalence data. Am J Epidemiol. 1983;117(3):356-361. [pmid: 6829563].
336 Kratz KE. The cognitive effects of DHEA supplementation in postmenopausal women, Fuller Theological Seminary, School Of Psychology, US, 1.; 2000.
337 Kreijkamp-Kaspers S, Kok L, Grobbee D E, et al. Effect of soy protein containing isoflavones on cognitive function, bone mineral density, and plasma lipids in postmenopausal women. JAMA. 2004;292(1):65-74. [pmid: 15238592].
338 Kritz-Silverstein D, Goldani Von Muhlen D, Barrett-Connor E. Prevalence and clustering of menopausal symptoms in older women by hysterectomy and oophorectomy status. J Womens Health Gender Based Med. 2000;9(7):747-755.
339 Kroboth P D, McAuley J W. Progesterone: Does it affect response to drug?. Psychopharmacology Bulletin. 1997;33(2):297-301. [pmid: 9230647].
340 Kronenberg F. Hot flashes: epidemiology and physiology. Annals of the New York Academy of Sciences. 1990;592:52-86. discussion 123–133. [pmid: 2197954].
341 Kronenberg F, Fugh-Berman A. Complementary and alternative medicine for menopausal symptoms: a review of randomized, controlled trials.[see comment]. Ann Intern Med. 2002;137(10):805-813. [pmid: 12435217].
342 Kudielka B M, Schmidt-Reinwald A K, Hellhammer D H, Kirschbaum C. Psychological and endocrine responses to psychosocial stress and dexamethasone/corticotropin-releasing hormone in healthy postmenopausal women and young controls: the impact of age and a two-week estradiol treatment. Neuroendocrinology. 1999;70(6):422-430. [pmid: 10657735].
343 Kuller L H, Matthews K A, Meilahn E N. Estrogens and women's health: interrelation of coronary heart disease, breast cancer and osteoporosis. Journal of Steroid Biochemistry & Molecular Biology. 2000;74(5):297-309. [pmid: 11162938].
344 Kuller L H, Simkin-Silverman L R, Wing R R, Meilahn E N, Ives D G. Women's Healthy Lifestyle Project: A randomized clinical trial: results at 54 months. Circulation. 2001;103(1):32-37. [pmid: 11136682].
345 Kurabayashi T, Okada M, Tanaka K. Eicosapentaenoic acid effect on hyperlipidemia in menopausal Japanese women. The Niigata Epadel Study Group. Obstetrics & Gynecology. 2000;96(4):521-528. [pmid: 11004352].
346 Kurpius S E, Nicpon M F, Maresh S E. Mood, marriage and menopause. Journal of Counseling Psychology. 2001;48(1):77-84.
347 Kuzuya F, Kono K. Pharmacotherapy in later life: Eastern principles. Bergener, Manfred (Ed); Hasegawa, Kazuo (Ed); et al (1992) Aging and mental disorders: International perspectives (pp 239–252) xv, 426pp; 1992.
348 Kwawukume E Y, Ghosh T S, Wilson J B. Menopausal age of Ghanaian women. Int J Gynaecol Obstet. 1993;40(2):151-155. [pmid: 8094686].
349 Laan E, van Lunsen R H, Everaerd W. The effects of tibolone on vaginal blood flow, sexual desire and arousability in postmenopausal women. Climacteric. 2001;4(1):28-41. [pmid: 11379375].
350 Labrie F, Belanger A, Cusan L, Gomez J L, Candas B. Marked decline in serum concentrations of adrenal C19 sex steroid precursors and conjugated androgen metabolites during aging. J Clin Endocrinol Metab. 1997;82(8):2396-2402. [pmid: 9253307].
351 Labrie F, Diamond P, Cusan L, Gomez J L, Belanger A, Candas B. Effect of 12-month dehydroepiandrosterone replacement therapy on bone, vagina, and endometrium in postmenopausal women. J Clin Endocrinol Metab. 1997;82(10):3498-3505. [pmid: 9329392].
352 Lagrelius A, Fredricsson B, Hirt M, Weintraub L. Clinical experience with a low-dose combination of estradiol valerate and levonorgestrel. Double-blind comparative study between SH D 386 F and Cyclabil. Effects on symptoms, lipids and endometrial condition. Acta Obstet Gynecol Scand Suppl. 1986;134:97-101. [pmid: 3101396].
353 Lamlertkittikul S, Chandeying V. Efficacy and safety of Pueraria mirifica (Kwao Kruea Khao) for the treatment of vasomotor symptoms in perimenopausal women: Phase II Study. Journal of the Medical Association of Thailand. 2004;87(1):33-40. [pmid: 14971532].
354 Larsson-Cohn U, Hammar M, Chirstau S, Nathorst-Boos J, Rud T, Garre K. A double-blind, randomized study comparing the effects of Livial and Kliogest in postmenopausal women with climacteric complaints. Paper presented at: British Menopause Society; 11.9.04, Exeter 1996.
355 Lasco A, Frisina N, Morabito N, et al. Metabolic effects of dehydroepiandrosterone replacement therapy in postmenopausal women. European Journal of Endocrinology. 2001;145(4):457-461. [pmid: 11581005].
356 Laufer L R, Erlik Y, Meldrum D R, Judd H L. Effect of clonidine on hot flashes in postmenopausal women. Obstetrics & Gynecology. 1982;60(5):583-586. [pmid: 7145250].
357 Lebherz T B, French L. Nonhormonal treatment of the menopausal syndrome. A double-blind evaluation of an autonomic system stabilizer. Obstetrics & Gynecology. 1969;33(6):795-799. [pmid: 4890348].
358 Ledesert B, Ringa V, Breart G. Menopause and perceived health status among the women of the French GAZEL cohort. Maturitas. 1994;20(23):113-120. [pmid: 7715462].
359 Lee J. Use of Pro-Gest cream in postmenopausal women. Lancet. 1998;352:905. [pmid: 9743010].
360 Leidy L E. Timing of menopause in relation to body size and weight change. Human Biology. 1996;68(6):967-982.
361 Lennon M C. The psychological consequences of menopause: The importance of timing of a strange life event. Journal of Health & Social Behavior. 1982;23(4):353-366. [pmid: 7161474].
362 Lennon M C. Is menopause depressing? An investigation of three perspectives. Sex Roles. 1987;17(12):1-16.
363 Lenton E A, Landgren B M, Sexton L, Harper R. Normal variation in the length of the follicular phase of the menstrual cycle: effect of chronological age. Br J Obstet Gynaecol. 1984;91(7):681-684. [pmid: 6743609].
364 Lerner J. TCM/Kampo therapy also efficacious for menopause. Alternative Therapies in Health and Medicine. 2001;7(6):21.
365 Levy T, Gurevitch S, Bar-Hava I, et al. Pharmacokinetics of natural progesterone administered in the form of a vaginal tablet. Hum Reprod. 1999;14(3):606-610. [pmid: 10221683].
366 Lewis J G, McGill H, Patton V M, Elder P A. Caution on the use of saliva measurements to monitor absorption of progesterone from transdermal creams in postmenopausal women. Maturitas. 2002;41(1):1-6. [pmid: 11809337].
367 Li C, Samsioe G, Borgfeldt C, Lidfeldt J, Agardh C D, Nerbrand C. Menopause-related symptoms: what are the background factors? A prospective population-based cohort study of Swedish women (The Women's Health in Lund Area study). Am J Obstet Gynecol. 2003;189(6):1646-1653. [pmid: 14710092].
368 Liao K L, Hunter M S. Preparation for menopause: prospective evaluation of a health education intervention for mid-aged women. Maturitas. 1998;29(3):215-224. [pmid: 9699192].
369 Linzmayer L, Semlitsch H V, Saletu B, et al. Double-blind, placebo-controlled psychometric studies on the effects of a combined estrogen-progestin regimen versus estrogen alone on performance, mood and personality of menopausal syndrome patients. Arzneimittel-Forschung. 2001;51(3):238-245. [pmid: 11304940].
370 Liske E, Hanggi W, Henneicke-von Zepelin H H, Boblitz N, Wustenberg P, Rahlfs V W. Physiological investigation of a unique extract of black cohosh (Cimicifugae racemosae rhizoma): a 6-month clinical study demonstrates no systemic estrogenic effect. J Womens Health Gender Based Med. 2002;11(2):163-174.
371 Liu P, He F F, Bai W P, et al. Menopausal depression: comparison of hormone replacement therapy and hormone replacement therapy plus fluoxetine. Chin Med J. 2004;117(2):189-194. [pmid: 14975200].
372 Longcope C, Jaffee W, Griffing G. Production rates of androgens and oestrogens in post-menopausal women. Maturitas. 1981;3(34):215-223. [pmid: 7334933].
373 Loprinzi C, Quella SK, Sloan J, al. e. Preliminary data from a randomized evaluation of fluoxetine (Prozac) for treating hot flashes in breast cancer survivors. Breast Cancer Research and Treatment. 1999;57:abstract.
374 Loprinzi CL, Kugler JW, Sloan J. Venlafaxine alleviates hot flashes: an NCCTG trial. Proc Am Soc Clin Oncol. 2000;19:abst 4.
375 Loprinzi C L, Peethambaram P P. Management of menopausal symptoms in breast cancer patients. Ann Med. 1995;27(6):653-656. [pmid: 8652144].
376 Loprinzi C L, Pisansky T M, Fonseca R, et al. Pilot evaluation of venlafaxine hydrochloride for the therapy of hot flashes in cancer survivors. J Clin Oncol. 1998;16(7):2377-2381. [pmid: 9667254].
377 Loprinzi L, Barton D L, Sloan J A, et al. Pilot evaluation of gabapentin for treating hot flashes.[see comment]. Mayo Clinic Proceedings. 2002;77(11):1159-1163. [pmid: 12440550].
378 Lovejoy J C, Bray G A, Bourgeois M O, et al. Exogenous androgens influence body composition and regional body fat distribution in obese postmenopausal women--a clinical research center study. J Clin Endocrinol Metab. 1996;81(6):2198-2203. [pmid: 8964851].
379 Luciano AA, Miller BE, Sequenzia LC, Benadiva CA, Slade KL. The pharmacokinetics of the sublingual administration of micronized estradiol, progesterone and testosterone in postmenopausal women. Fertil Steril. 1998;70(3).
380 Luckas M J, Gleeve T, Biljan M M, et al. The effect of progestagens on the carotid artery pulsatility index in postmenopausal women on oestrogen replacement therapy. European Journal of Obstetrics, Gynecology, & Reproductive Biology. 1998;76(2):221-224.
381 Lucks B. Vitex agnus castus essential oil and menopausal balance: a research update [Complementary Therapies in Nursing and Midwifery 8 (2003) 148.154]. Complementary Therapies in Nursing & Midwifery. 2003;9(3):157-160. [pmid: 12852933].
382 Lucks B C. The Vitex agnus castus dilemma: ethical management of a double-edged oil. Aromatheraphy Today. 2003;27:24-27.
383 Lundstrom E, Christow A, Kersemaekers W, et al. Effects of tibolone and continuous combined hormone replacement therapy on mammographic breast density. Am J Obstet Gynecol. 2002;186(4):717-722. [pmid: 11967497].
384 Lyritis G P, Karpathios S, Basdekis K, et al. Prevention of post-oophorectomy bone loss with Tibolone. Maturitas. 1995;22(3):247-253. [pmid: 8746883].
385 Maartens L W, Leusink G L, Knottnerus J A, Pop V J. Hormonal substitution during menopause: what are we treating?. Maturitas. 2000;34(2):113-118. [pmid: 10714905].
386 MacNaughton J, Banah M, McCloud P, Hee J, Burger H. Age related changes in follicle stimulating hormone, luteinizing hormone, oestradiol and immunoreactive inhibin in women of reproductive age. Clin Endocrinol. 1992;36(4):339-345.
387 Mahady G B, Fabricant D, Chadwick L R, Dietz B. Black cohosh: an alternative therapy for menopause?. Nutrition in Clinical Care. 2002;5(6):283-289. [pmid: 12557811].
388 Mahavni V, Buller R E. Estrogen replacement therapy in endometrial and breast cancer survivors. Clinical Obstetrics & Gynecology. 1999;42(4):863-875. [pmid: 10572699].
389 Maheux R, Naud F, Rioux M, et al. A randomized, double-blind, placebo-controlled study on the effect of conjugated estrogens on skin thickness. Am J Obstet Gynecol. 1994;170(2):642-649. [pmid: 8116726].
390 Mansfield P K, Koch P B, Voda A M. Midlife women's attributions for their sexual response changes. Health Care Women Int. 2000;21(6):543-559. [pmid: 11235285].
391 Manzella D, Fornaro F, Carbonella M, Picardi C, Paolisso G, Colacurci N. Effect of tibolone administration on heart rate variability and free fatty acid levels in postmenopausal women. Fertil Steril. 2002;78(5):1005-1009. [pmid: 12413985].
392 Marchesoni D, Mozzanega B, Maggino T, Nardelli G B. Postmenopausal hot flushes: Endocrine correlations and progestinic treatment. Double blind crossed clinical trial using MPA versus placebo. Journal of Gynaecological Endocrinology. 1985;1(12):63-69.
393 Maresi M P, Baldi L, Balatresi L, et al. A non-hormonal therapeutic alternative in cervico-vaginal dystrophies. Annali di Ostetricia, Ginecologia, Medicina Perinatale. 1990;111(6):393-399.
394 Mariella AM. Longitudinal patterns of depressive symptoms in midlife women, U Washington, US, 1.; 2002.
395 Marsden J. The menopause, hormone replacement therapy and breast cancer. Journal of Steroid Biochemistry & Molecular Biology. 2002;83(15):123-132. [pmid: 12650709].
396 Martin P L, Burnier A M, Segre E J, Huix F J. Graded sequential therapy in the menopause: a double-blind study. Am J Obstet Gynecol. 1971;111(2):178-186. [pmid: 4938602].
397 Matthews K A, Kuller L H, Wing R R, Meilahn E N. Biobehavioral aspects of menopause: lessons from the Healthy Women Study. Exp Gerontol. 1994;29(34):337-342. [pmid: 7925753].
398 Matthews K A, Wing R R, Kuller L H, Meilahn E N, Plantinga P. Influence of the perimenopause on cardiovascular risk factors and symptoms of middle-aged healthy women. Arch Intern Med. 1994;154(20):2349-2355. [pmid: 7944857].
399 Mazer N A. Testosterone deficiency in women: etiologies, diagnosis, and emerging treatments. Int J Fertil Womens Med. 2002;47(2):77-86. [pmid: 11991434].
400 Mazer N A, Shifren J L. Transdermal testosterone for women: a new physiological approach for androgen therapy. Obstetrical & Gynecological Survey. 2003;58(7):489-500. [pmid: 12832941].
401 McCarthy T, Dramusic V, Carter R, Costales A, Ratnam S S. Randomized cross-over study of a 21-day versus a 28-day hormone replacement therapy (HRT). Maturitas. 1995;22(1):13-23. [pmid: 7666812].
402 McKinlay J B, McKinlay S M, Brambilla D J. Health status and utilization behavior associated with menopause. Am J Epidemiol. 1987;125(1):110-121. [pmid: 3788939].
403 Meirow D. Reproduction post-chemotherapy in young cancer patients. Molecular & Cellular Endocrinology. 2000;169(12):123-131. [pmid: 11155944].
404 Meldrum D R, Davidson B J, Tataryn I V, Judd H L. Changes in circulating steroids with aging in postmenopausal women. Obstetrics & Gynecology. 1981;57(5):624-628. [pmid: 7219911].
405 Melis G B, Cagnacci A, Bruni V, et al. Salmon calcitonin plus intravaginal estriol: An effective treatment for the menopause. Maturitas. 1996;24(12):83-90. [pmid: 8794438].
406 Mendoza N, Alamo F, Alvarez M, Hortas ML, Martinez L. Lipid Effects, Safety and Acceptability of Tibolone Versus Transdermic 17B-Estradiol for Hormone Replacement Therapy in Women with Surgical Menopause. Acta Obstet Gynecol Scand. 1997;76(Supplement).
407 Menkes D B, Thomas M C, Phipps R F. Moclobemide for menopausal flushing. Lancet. 1994;344(8923):691-692.
408 Messina M, Hughes C. Efficacy of soyfoods and soybean isoflavone supplements for alleviating menopausal symptoms is positively related to initial hot flush frequency. Journal of Medicinal Food. 2003;6(1):1-11. [pmid: 12804015].
409 Messina M J, Loprinzi C L. Soy for breast cancer survivors: a critical review of the literature. Journal of Nutrition. 2001;131(11 Suppl):3095S-3108S. [pmid: 11694655].
410 Metcalf M G. The approach of menopause: a New Zealand study. New Zealand Medical Journal. 1988;101(841):103-106. [pmid: 3132662].
411 Metcalf M G, Livesay J H. Gonadotropin excretion in fertile women: effect of age and the onset of the menopausal transition. Journal of Endocrinology. 1985;105:357. [pmid: 3923150].
412 Metzl J M, Angel J. Assessing the impact of SSRI antidepressants on popular notions of women's depressive illness. Soc Sci Med. 2004;58(3):577-584. [pmid: 14652053].
413 Miller B E, De Souza M J, Slade K, Luciano A A. Sublingual administration of micronized estradiol and progesterone, with and without micronized testosterone: effect on biochemical markers of bone metabolism and bone mineral density. Menopause. 2000;7(5):318-326. [pmid: 10993031].
414 Miller K, Corcoran C, Armstrong C, et al. Transdermal testosterone administration in women with acquired immunodeficiency syndrome wasting: a pilot study. J Clin Endocrinol Metab. 1998;83(8):2717-2725. [pmid: 9709937].
415 Miller L G. Promising results of Piper methysticum on mood parameters in perimenopausal women. Focus on Alternative & Complementary Therapies. 2003;8(3):310-311.
416 Milner M, Kelly A, Harrison RF. Controlled Study of Metabolic Effects of Estrogen-Progestogen and Tibolone Over 2 Years on Postmenopausal Women. 8th International Congress on the Menopause.96.
417 Modelska K, Cummings S. Tibolone for postmenopausal women: systematic review of randomized trials. J Clin Endocrinol Metab. 2002;87(1):16-23. [pmid: 11788614].
418 Montgomery JC. Treatment of Decreased Libido in Climacteric Women: Effects of Oestradiol Implants Alone and in Combination with Testosterone. Journal of Obstetrics & Gynaecology. 1991;11(4).
419 Montgomery J C, Appleby L, Brincat M, et al. Effect of oestrogen and testosterone implants on psychological disorders in the climacteric. Lancet. 1987;1(8528):297-299. [pmid: 2880114].
420 Moore H C. Managing menopause after breast cancer: balancing risks and benefits. Cleveland Clinic Journal of Medicine. 2001;68(3):243-248. [pmid: 11263852].
421 Moore R A. Livial: a review of clinical studies. Br J Obstet Gynaecol. 1999;106(Suppl 19):1-21. [pmid: 10890791].
422 Morales AJ, Nolan JJ, Nelson JC, Yen SS. Effects of replacement dose of dehydroepiandrosterone in men and women of advancing age.[erratum appears in J Clin Endocrinol Metab 1995 Sep;80(9):2799]. J Clin Endocrinol Metab. 1360;78(6):1360–1367.
423 Mortimer J E. Hormone replacement therapy and beyond. The clinical challenge of menopausal symptoms in breast cancer survivors. Geriatrics. 2002;57(9):25-31. [pmid: 12271826].
424 Munster K, Schmidt L, Helm P. Length and variation in the menstrual cycle--a cross-sectional study from a Danish county. Br J Obstet Gynaecol. 1992;99(5):422-429. [pmid: 1622917].
425 Murray M J, Meyer W R, Lessey B A, Oi R H, DeWire R E, Fritz M A. Soy protein isolate with isoflavones does not prevent estradiol-induced endometrial hyperplasia in postmenopausal women: a pilot trial. Menopause. 2003;10(5):456-464. [pmid: 14501608].
426 Myers L S, Dixen J, Morrissette D, Carmichael M, Davidson J M. Effects of estrogen, androgen, and progestin on sexual psychophysiology and behavior in postmenopausal women. J Clin Endocrinol Metab. 1990;70(4):1124-1131. [pmid: 1690746].
427 Nash H A, Alvarez-Sanchez F, Mishell D R Jr, Fraser I S, Maruo T, Harmon T M. Estradiol-delivering vaginal rings for hormone replacement therapy. Am J Obstet Gynecol. 1999;181(6):1400-1406. [pmid: 10601920].
428 Nevinny-Stickel J. Double-blind cross-over study with Org OD 14 and placebo in postmenopausal patients. Archives of Gynecology. 1983;234(1):27-31. [pmid: 6660926].
429 Nguyen TT, Wisniewski AB, Dobs AS. Influence of estrogen with or without methyl-testosterone therapy on cognitive functions in post-menopausal women. Fertil Steril. 1999;72(Supplement 1).
430 Nguyen T V, Wong F W. The effects of Chinese medicinal herbs on postmenopausal vasomotor symptoms of Australian women. Med J Aust. 2001;175(4):230.
431 Nihira M A, Henderson N. Epidemiology of urinary incontinence in women. Current Women's Health Reports. 2003;3(4):340-347.
432 North American Menopause S. Treatment of menopause-associated vasomotor symptoms: position statement of The North American Menopause Society. Menopause. 2004;11(1):11-33. [pmid: 14716179].
433 Obermeyer C M. Menopause across cultures: a review of the evidence. Menopause. 2000;7(3):184-192. [pmid: 10810964].
434 Obillo E, Eleazar J, Demeterio J. Maprotiline for Depression during Menopause: A Philippine Menopause Clinic Experience CONFERENCE ABSTRACT. XXth Collegium Internationale Neuro psychopharmacologicum Melbourne, Australia 23rd 27th June. 1996.
435 O'Bryant S E, Palav A, McCaffrey R J. A review of symptoms commonly associated with menopause: implications for clinical neuropsychologists and other health care providers. Neuropsychology Review. 2003;13(3):145-152. [pmid: 14584909].
436 O'Connor A M, Tugwell P, Wells G A, et al. Randomized trial of a portable, self-administered decision aid for postmenopausal women considering long-term preventive hormone therapy. Medical Decision Making. 1998;18(3):295-303. [pmid: 9679994].
437 O'Connor A M, Wells G A, Tugwell P, Laupacis A, Elmslie T, Drake E. The effects of an ‘explicit’ values clarification exercise in a woman's decision aid regarding postmenopausal hormone therapy. Health Expectations. 1999;2(1):21-32. [pmid: 11281872].
438 Oldenhave A, Jaszmann L J, Haspels A A, Everaerd W T. Impact of climacteric on well-being. A survey based on 5213 women 39 to 60 years old. Am J Obstet Gynecol. 1993;168(3 Pt 1):772-780. [pmid: 8456878].
439 Owens J F, Matthews K A. Sleep disturbance in healthy middle-aged women. Maturitas. 1998;30(1):41-50. [pmid: 9819782].
440 Ozsoy M, Oral B, Ozsoy D. Clinical equivalence of intranasal estradiol and oral estrogens for postmenopausal symptoms. Int J Gynaecol Obstet. 2002;79(2):143-146. [pmid: 12427399].
441 Palmer J R, Rosenberg L, Wise L A, Horton N J, Adams-Campbell L L. Onset of natural menopause in African American women. American Journal of Public Health. 2003;93(2):299-306. [pmid: 12554590].
442 Paoletti A M, Floris S, Mannias M, et al. Evidence that cyproterone acetate improves psychological symptoms and enhances the activity of the dopaminergic system in postmenopause. J Clin Endocrinol Metab. 2001;86(2):608-612. [pmid: 11158017].
443 Papps F A. Therapeutic use and associated biochemistry of Cimicifuga racemosa in the treatment of menopausal symptoms. Australian Journal of Medical Herbalism. 2000;12(1):22-26.
444 Parazzini F, Colli E, Origgi G, et al. Risk factors for urinary incontinence in women. European Urology. 2000;37(6):637-643.
445 Parazzini F, Progretto Menopausa Italia Study G. Menopausal status, hormone replacement therapy use and risk of self-reported physician-diagnosed osteoarthritis in women attending menopause clinics in Italy. Maturitas. 2003;46(3):207-212. [pmid: 14585523].
446 Parker M, Bosscher J, Barnhill D, Park R. Ovarian management during radical hysterectomy in the premenopausal patient.[see comment]. Obstetrics & Gynecology. 1993;82(2):187-190. [pmid: 8336862].
447 Parlee M B. Psychological aspects of the climacteric in women. Psychiatric Opinion. 1978;15(10):36-40.
448 Parlee MB. Integrating biological and social scientific research on menopause. Flint, Marcha (Ed); Kronenberg, Fredi (Ed); et al (1990) Multidisciplinary perspectives on menopause Annals of the New York Academy of Sciences, Vol 592 (pp 379–389) xii, 488pp; 1990.
449 Parry B L. Reproductive factors affecting the course of affective illness in women. Psychiatric Clinics of North America. 1989;12(1):207-220. [pmid: 2652109].
450 Parry B L, Newton R P. Chronobiological basis of female-specific mood disorders. Neuropsychopharmacology. 2001;25(5 Suppl):S102-108. [pmid: 11682284].
451 Pasquali R, Casimirri F, Labate A M, et al. Body weight, fat distribution and the menopausal status in women. The VMH Collaborative Group. International Journal of Obesity & Related Metabolic Disorders: Journal of the International Association for the Study of Obesity. 1994;18(9):614-621. [pmid: 7812415].
452 Pearce J, Hawton K, Blake F. Psychological and sexual symptoms associated with the menopause and the effects of hormone replacement therapy. British Journal of Psychiatry. 1995;167(2):163-173. [pmid: 7582665].
453 Pearce J, Hawton K, Blake F, et al. Psychological effects of continuation versus discontinuation of hormone replacement therapy by estrogen implants: a placebo-controlled study. Journal of Psychosomatic Research. 1997;42(2):177-186. [pmid: 9076645].
454 Pearlstein T B. Hormones and depression: what are the facts about premenstrual syndrome, menopause, and hormone replacement therapy?. Am J Obstet Gynecol. 1995;173(2):646-653. [pmid: 7645647].
455 Penotti M, Fabio E, Rinaldi M, Omodei U, Bacchi Modena A. Effects of soy-derived isoflavones on hot flushes and vascular reactivity (abstract). Climacteric. 2002;5(Supplement 1):104.
456 Persky H, Dreisbach L, Miller W R, et al. The relation of plasma androgen levels to sexual behaviors and attitudes of women. Psychosomatic Medicine. 1982;44(4):305-319. [pmid: 6216492].
457 Petitti D B, Buckwalter J, Crooks V C, Chiu V. Prevalence of dementia in users of hormone replacement therapy as defined by prescription data. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2002;57A(8):M532-M538.
458 Petre-Quadens O. Hormones and sleep [proceedings]. Journal of Physiology. 1979;295:70P-71P.
459 Petropoulos P, Karayiannis V, Tzafettas J, Tsimas V, Petropoulou V, Mamopoulos M. A randomised trial comparing the effects of tibolone and the continuous administration of conjugated estrogens and MPA as HRT in postmenopausal women with menopausal symptoms (abstract). Gynecol Endocrinol. 2000;14(Supplement 2).
460 Pfeiffer E, Davis G C. Determinants of sexual behavior in middle and old age. Journal of the American Geriatrics Society. 1972;20(4):151-158. [pmid: 5016632].
461 Pham K T, Grisso J A, Freeman E W. Ovarian aging and hormone replacement therapy. Hormonal levels, symptoms, and attitudes of African-American and white women. Journal of General Internal Medicine. 1997;12(4):230-236. [pmid: 9127227].
462 Philip H. Hot flashes - a review of the literature on alternative and complementary treatment approaches. Alternative Medicine Review. 2003;8(3):284-302. [pmid: 12946239].
463 Phillips S M, Sherwin B B. Effects of estrogen on memory function in surgically menopausal women. Psychoneuroendocrinology. 1992;17(5):485-495. [pmid: 1484915].
464 Pinto B M, Maruyama N C. Exercise in the rehabilitation of breast cancer survivors. Psycho-Oncology. 1999;8(3):191-206. [pmid: 10390732].
465 Pisani G, Facioni L, Fiorani F. Psychological and sexual disturbances in menopause: <ORIGINAL> PROBLEMATICHE PSICOSESSUALI IN MENOPAUSA. Minerva Ginecologica. 1998;50(3):77-81. [pmid: 9595919].
466 Pitt B. Depression in middle-aged women. British Journal of Hospital Medicine. 1987;38(1):26-28. 30, 32. [pmid: 3304493].
467 Pittler M H. Chinese medicinal herbs are no more effective than placebo in reducing vasomotor symptoms in postmenopausal women. Focus on Alternative & Complementary Therapies. 2001;6(2):117-118.
468 Plumb J M, Guest J F. Economic impact of tibolone compared with continuous-combined hormone replacement therapy. In the management of postmenopausal women with climacteric symptoms in the UK. Pharmacoeconomics. 2000;18(5):477-486. [pmid: 11151401].
469 Polis NS. Aerobic exercise: effects on selected health variables in menopausal women (women). Health Sciences Case Western Reserve University. 1989.
470 Polo-Kantola P, Erkkola R, Irjala K, Helenius H, Pullinen S, Polo O. Climacteric symptoms and sleep quality. Obstetrics & Gynecology. 1999;94(2):219-224. [pmid: 10432131].
471 Polo-Kantola P, Portin R, Koskinen T, Polo O, Irjala K, Erkkola R. Climacteric symptoms do not impair cognitive performances in postmenopause. Maturitas. 1997;27(1):13-23. [pmid: 9158073].
472 Pop V J, Maartens L H, Leusink G, et al. Are autoimmune thyroid dysfunction and depression related?. J Clin Endocrinol Metab. 1998;83(9):3194-3197. [pmid: 9745425].
473 Pornel B. Efficacy and safety of Menorest in two positive-controlled studies. European Journal of Obstetrics, Gynecology, & Reproductive Biology. 1996;64(Suppl):S35-37.
474 Porzio G, Trapasso T, Martelli S, et al. Acupuncture in the treatment of menopause-related symptoms in women taking tamoxifen. Tumori. 2002;88(2):128-130. [pmid: 12088252].
475 Prelevic G M, Bartram C, Wood J, Okolo S, Ginsburg J. Comparative effects on bone mineral density of tibolone, transdermal estrogen and oral estrogen/progestogen therapy in postmenopausal women. Gynecol Endocrinol. 1996;10(6):413-420. [pmid: 9032569].
476 Prior J C. The ageing female reproductive axis II: ovulatory changes with perimenopause. Novartis Foundation Symposium. 2002;242:172-186. discussion 186–192. [pmid: 11855687].
477 Pritchard K I, Khan H, Levine M. Steering Committee on Clinical Practice Guidelines for the C, Treatment of Breast C. Clinical practice guidelines for the care and treatment of breast cancer: 14. The role of hormone replacement therapy in women with a previous diagnosis of breast cancer. CMAJ. 2002;166(8):1017-1022. [pmid: 12002977]. [pmcid: 100875].
478 Progetto Menopausa Italia Study G. Risk of low bone density in women attending menopause clinics in Italy. Maturitas. 2002;42(2):105-111. [pmid: 12065169].
479 Progetto Menopausa Italia Study G. Premature ovarian failure: frequency and risk factors among women attending a network of menopause clinics in Italy. BJOG. 2003;110(1):59-63. [pmid: 12504937].
480 Progetto Menopausa Italia Study G. Determinants of body mass index in women around menopause attending menopause clinics in Italy. Climacteric. 2003;6(1):67-74. [pmid: 12776693].
481 Quella S K, L L C, Barton D L, Knost J A, Sloan J A, LaVasseur B I, et al. Evaluation of soy phytoestrogens for the treatment of hot flashes in breast cancer survivors: a North Central Cancer Treatment Group trial. J Clin Oncol. 2000;18:1068-1074. [pmid: 10694559].
482 Quitkin F M, Stewart J W, McGrath P J. “Gender differences in treatment response to sertraline versus imipramine in chronic depression”: Comment. Am J Psychiatry. 2001;158(9):1531-1533. [pmid: 11532756].
483 Quitkin F M, Stewart J W, McGrath P J, et al. Are there differences between women's and men's antidepressant responses?. Am J Psychiatry. 2002;159(11):1848-1854. [pmid: 12411218].
484 Rabinerson D, Avrech O, Kaplan B, Braslavsky D, Goldman G A, Neri A. Endometrioma of the vagina in menopause. Acta Obstet Gynecol Scand. 1996;75(5):506-507. [pmid: 8677781].
485 Randolph J F Jr, Sowers M, Bondarenko I V, Harlow S D, Luborsky J L, Little R J. Change in estradiol and follicle-stimulating hormone across the early menopausal transition: effects of ethnicity and age. J Clin Endocrinol Metab. 2004;89(4):1555-1561. [pmid: 15070912].
486 Rannestad T, Eikeland O-J, Helland H, Qvarnstroem U. Are the physiologically and psychosocially based symptoms in women suffering from gynecological disorders alleviated by means of hysterectomy?. J Womens Health Gender Based Med. 2001;10(6):579-587.
487 Rannevik G, Jeppsson S, Johnell O, Bjerre B, Laurell-Borulf Y, Svanberg L. A longitudinal study of the perimenopausal transition: altered profiles of steroid and pituitary hormones, SHBG and bone mineral density. Maturitas. 1995;21(2):103-113. [pmid: 7752947].
488 Rasgon Natalie L, Dunkin J, Altshuler Lori L, Rapkin A. Estrogen-replacement therapy: cognition and depression in postmenopausal women. 155th Annual Meeting of the American Psychiatric Association. 2002.
489 Ravnikar V. Physiology and treatment of hot flushes. Obstetrics & Gynecology. 1990;75(4 Suppl):3S-8S. discussion 15S–17S. [pmid: 2179788].
490 Raz R, Stamm W E. A controlled trial of intravaginal estriol in postmenopausal women with recurrent urinary tract infections.[see comment]. N Engl J Med. 1993;329(11):753-756. [pmid: 8350884].
491 Reay Jones N H, Healy J C, King L J, Saini S, Shousha S, Allen-Mersh T G. Pelvic connective tissue resilience decreases with vaginal delivery, menopause and uterine prolapse. British Journal of Surgery. 2003;90(4):466-472. [pmid: 12673750].
492 Rebar R W, Spitzer I B. The physiology and measurement of hot flushes. Am J Obstet Gynecol. 1987;156(5):1284-1288. [pmid: 3578449].
493 Regestein Q R, Friebely J, Shifren J, Schiff I. Neuropsychological effects of methyltestosterone in women using menopausal hormone replacement. J Womens Health Gender Based Med. 2001;10(7):671-676.
494 Reginster J Y, Deroisy R, Paul I, Hansenne M, Ansseau M. Depressive vulnerability is not an independent risk factor for osteoporosis in postmenopausal women. Maturitas. 1999;33(2):133-137. [pmid: 10597877].
495 Reinhard-Hennch B. Phytoestrogenes in the menopause: A review Review. Schweizerische Zeitschrift fur Ganzheitsmedizin. 2004;16(3):164-167.
496 Resnick S M, Metter E, Zonderman A B. Estrogen replacement therapy and longitudinal decline in visual memory: A possible protective effect?. Neurology. 1997;49(6):1491-1497. [pmid: 9409335].
497 Reti L L, Rome R M Jr, Brown J B, Fortune D W. Urinary oestrogen and pregnanediol excretion, endometrial and ovarian pathology and body weight in women with postmenopausal bleeding. Br J Obstet Gynaecol. 1978;85(11):857-861. [pmid: 718810].
498 Reyes F I, Winter J S, Faiman C. Pituitary-ovarian relationships preceding the menopause. I. A cross-sectional study of serum follice-stimulating hormone, luteinizing hormone, prolactin, estradiol, and progesterone levels. Am J Obstet Gynecol. 1977;129(5):557-564. [pmid: 910845].
499 Reynolds F. Psychological responses to menopausal hot flushes: Implications of a qualitative study for counselling interventions. Counselling Psychology Quarterly. 1997;10(3):309-321.
500 Reynolds F. Some relationships between perceived control and women's reported coping strategies for menopausal hot flushes. Maturitas. 1999;32(1):25-32. [pmid: 10423713].
501 Reynolds F. Relationships between catastrophic thoughts, perceived control and distress during menopausal hot flushes: exploring the correlates of a questionnaire measure. Maturitas. 2000;36(2):113-122. [pmid: 11006498].
502 Reynolds F. Exploring self-image during hot flushes using a semantic differential scale: associations between poor self-image, depression, flush frequency and flush distress. Maturitas. 2002;42(3):201-207. [pmid: 12161044].
503 Reynolds F. Exploring the long-term experience of vasomotor instability: A 5 year follow-up study of distress, perceived control and catastrophizing. Counselling Psychology Quarterly. 2002;15(1):73-83.
504 Rice K, Morse C. Measuring cognition in menopause research: a review of test use. Climacteric. 2003;6(1):2-22. [pmid: 12725660].
505 Rice M M, Graves A B, McCurry S M, et al. Postmenopausal estrogen and estrogen-progestin use and 2-year rate of cognitive change in a cohort of older Japanese American women: The Kame Project. Arch Intern Med. 2000;160(11):1641-1649. [pmid: 10847257].
506 Richards M, Kuh D, Hardy R, Wadsworth M. Lifetime cognitive function and timing of the natural menopause. Neurology. 1999;53(2):308-314. [pmid: 10430419].
507 Richards-Kustan C J, Kase N G. Diagnosis and management of perimenopausal and postmenopausal bleeding. Obstetrics & Gynecology Clinics of North America. 1987;14(1):169-189. [pmid: 3306518].
508 Richardson S J, Senikas V, Nelson J F. Follicular depletion during the menopausal transition: evidence for accelerated loss and ultimate exhaustion. J Clin Endocrinol Metab. 1987;65(6):1231-1237. [pmid: 3119654].
509 Richelle M, Pridmore-Merten S, Bodenstab S, Enslen M, Offord E A. Hydrolysis of isoflavone glycosides to aglycones by beta-glycosidase does not alter plasma and urine isoflavone pharmacokinetics in postmenopausal women. Journal of Nutrition. 2002;132(9):2587-2592. [pmid: 12221213].
510 Richter D L, Corwin S J, Rheaume C E, McKeown R E. Perceptions of alternative therapies available for women facing hysterectomy or menopause. Journal of Women & Aging. 2001;13(4):21-37.
511 Richters J M. Menopause in different cultures. J Psychosom Obstet Gynaecol. 1997;18(2):73-80. [pmid: 9219102].
512 Roberts J, Chambers L F, Blake J, Webber C. Psychosocial adjustment in post-menopausal women. Canadian Journal of Nursing Research. 1992;24(4):29-46. [pmid: 1306400].
513 Rock E, DeMichele A. Nutritional approaches to late toxicities of adjuvant chemotherapy in breast cancer survivors. Journal of Nutrition. 2003;133(11 Suppl 1):3785S-3793S. [pmid: 14608115].
514 Rodstrom K, Bengtsson C, Milsom I, Lissner L, Sundh V, Bjourkelund C. Evidence for a secular trend in menopausal age: a population study of women in Gothenburg. Menopause. 2003;10(6):538-543. [pmid: 14627863].
515 Rohr U D. The impact of testosterone imbalance on depression and women's health. Maturitas. 2002;41(Suppl 1):S25-46. [pmid: 11955793].
516 Rosner G L, Hargis J B, Hollis D R, et al. Relationship between toxicity and obesity in women receiving adjuvant chemotherapy for breast cancer: results from cancer and leukemia group B study 8541. J Clin Oncol. 1996;14(11):3000-3008. [pmid: 8918498].
517 Rostom A, O'Connor A, Tugwell P, Wells G. A randomized trial of a computerized versus an audio-booklet decision aid for women considering post-menopausal hormone replacement therapy. Patient Educ Couns. 2002;46(1):67-74. [pmid: 11804772].
518 Rothert M L, Holmes-Rovner M, Rovner D, et al. An educational intervention as decision support for menopausal women. Res Nurs Health. 1997;20(5):377-387. [pmid: 9334792].
519 Rousseau M. Women's midlife health. Reframing menopause. Journal of Nurse-Midwifery. 1998;43(3):208-223. [pmid: 9674351].
520 Ryan N, Rosner A. Quality of life and costs associated with micronized progesterone and medroxyprogesterone acetate in hormone replacement therapy for nonhysterectomized, postmenopausal women. Clinical Therapeutics. 2001;23(7):1099-1115. [pmid: 11519773].
521 Ryhammer A M, Laurberg S, Djurhuus J C, Hermann A P. No relationship between subjective assessment of urinary incontinence and pad test weight gain in a random population sample of menopausal women. Journal of Urology. 1998;159(3):800-803. [pmid: 9474152].
522 Rymer J, Chapman M, Fogelman I, Wilson P. A study of the effect of tibolone on the vagina in postmenopausal women. Maturitas. 1994;18(2):127-133. [pmid: 8177093].
523 Rymer J, Chapman M G, Fogelman I. Effect of tibolone on postmenopausal bone loss. Osteoporosis International. 1994;4(6):314-319. [pmid: 7696824].
524 Rymer J, Robinson J, Fogelman I. Effects of 8 years of treatment with tibolone 2.5 mg daily on postmenopausal bone loss. Osteoporosis International. 2001;12(6):478-483. [pmid: 11446564].
525 Sammel M D, Grisso J A, Freeman E W, et al. Weight gain among women in the late reproductive years. Fam Pract. 2003;20(4):401-409. [pmid: 12876110].
526 Sanchez F E, Urdinola J M, Onatra W H, Posso H V, Sanchez J A, Alwers R C. Clinical manifestations in menopause with modifications to hormone replacement therapy. Multicentre Clinical trial comparing mixed hormones (conjugated estrogens plus medroxyprogesterone vs. estradiol valerate plus cyproterone acetate. Revista Colombiana de Obstetricia y Ginecologia. 1996;47(4):263-272.
527 Sands R H, Studd J W, Jones J, Alaghband-Zadeh J. Comparison of the biochemical effects of testosterone and estrogen on bone markers in surgically menopausal women. Gynecol Endocrinol. 2000;14(5):382-387. [pmid: 11109978].
528 Sands RH, Studd JWW, Catalan J, Alaghband Zadeh J. Effect of testosterone replacement therapy in surgically menopausal women. Fertil Steril. 1998;70(3).
529 Santoro N, Brown J R, Adel T, Skurnick J H. Characterization of reproductive hormonal dynamics in the perimenopause. J Clin Endocrinol Metab. 1495;81(4):1495-1501.
530 Sarrel P, Dobay B, Wiita B. Estrogen and estrogen-androgen replacement in postmenopausal women dissatisfied with estrogen-only therapy. Sexual behavior and neuroendocrine responses. J Reprod Med. 1998;43(10):847-856. [pmid: 9800666].
531 Schindler B A. The psychiatric disorders of midlife. Medical Clinics of North America. 1987;71(1):71-85. [pmid: 3543544].
532 Schmidt P J, Murphy J H, Haq N, Danaceau M A, St Clair L. Basal plasma hormone levels in depressed perimenopausal women. Psychoneuroendocrinology. 2002;27(8):907-920. [pmid: 12383452].
533 Schmidt PJ, Roca CA, Rubinow DR. Depression in the perimenopausal woman. 152nd Annual Meeting of the American Psychiatric Association Washington DC, USA. 1999.
534 Schmidt P J, Rubinow D R. Menopause-related affective disorders: a justification for further study. Am J Psychiatry. 1991;148(7):844-852. [pmid: 2053622].
535 Schneider L, Small G, Clary C. Does Estrogen Replacement Therapy Augment Response To Sertraline In Depressed Elderly Women. XXIst Collegium Internationale Neuro psychopharmacologicum, Glasgow, Scotland 12th 16th July. 1998(ABSTRACT).
536 Schneider LS, Small GW, Clary CM. Estrogen Replacement Therapy Status and Antidepressant to Sertraline. 151st Annual Meeting of the American Psychiatric Association Toronto, Ontario, Canada 30th May 4th June. 1998(NR426).
537 Schneider L S, Small G W, Hamilton S H, et al. Estrogen replacement and response to fluoxetine in a multicenter geriatric depression trial. Am J Geriatr Psychiatry. 1997;5:97-106. [pmid: 9106373].
538 Schouten J S, van den Ouweland F A, Valkenburg H A. Natural menopause, oophorectomy, hysterectomy and the risk of osteoarthritis of the dip joints. Scandinavian Journal of Rheumatology. 1992;21(4):196-200. [pmid: 1529287].
539 Seiden A M. Overview: research on the psychology of women. I. Gender differences and sexual and reproductive life. Am J Psychiatry. 1976;133(9):995-1007. [pmid: 786048].
540 Seltzer V L, Benjamin F, Deutsch S. Perimenopausal bleeding patterns and pathologic findings. Journal of the American Medical Womens Association. 1990;45(4):132-134.
541 Shainess N. Menopause: midlife crisis or milestone-marker?. Journal of the American Medical Womens Association. 1982;37(4):87-90.
542 Shangold M, Sherman C. Exercise and Menopause. A Time for Positive Changes. Physician and Sportsmedicine. 1998;26(12):45-50. 52.
543 Shangold M M. Exercise in the menopausal woman. Obstetrics & Gynecology. 1990;75(4 Suppl):53S-58S. discussion 81S–83S. [pmid: 2179791].
544 Shangold M M. An Active Menopause: Using Exercise to Combat Symptoms. Physician and Sportsmedicine. 1996;24(7):30-36. [pmid: 20087001].
545 Shargil A A. Hormone replacement therapy in perimenopausal women with a triphasic contraceptive compound: a three-year prospective study. Int J Fertil. 1985;30(1):15-28. [pmid: 2862116].
546 Sharkey K M, Bearpark H M, Acebo C, Millman R P, Cavallo A, Carskadon M A. Effects of menopausal status on sleep in midlife women. Behavioral Sleep Medicine. 2003;1(2):69-80. [pmid: 15600130].
547 Shaver J, Giblin E, Lentz M, Lee K. Sleep patterns and stability in perimenopausal women. Sleep. 1988;11(6):556-561. [pmid: 3148991].
548 Shaver J L. Women and sleep. Nursing Clinics of North America. 2002;37(4):707-718. [pmid: 12587369].
549 Shaver J L, Giblin E, Paulsen V M. Sleep quality subtypes in midlife women. Sleep. 1991;14(1):18-23. [pmid: 1811314].
550 Shaver J L, Paulsen V M. Sleep, psychological distress, and somatic symptoms in perimenopausal women. Family Practice Research Journal. 1993;13(4):373-384. [pmid: 8285088].
551 Shaver J L, Zenk S N. Sleep disturbance in menopause. J Womens Health Gender Based Med. 2000;9(2):109-118.
552 Shepherd J E. Effects of estrogen on cognition, mood, and degenerative brain diseases. Journal of the American Pharmaceutical Association. 2001;41(2):221-228. [pmid: 11297335].
553 Sherman B M, Wallace R B, Bean J A, Chang Y, Schlabaugh L. The relationship of menopausal hot flushes to medical and reproductive experience. Journal of Gerontology. 1981;36(3):306-309. [pmid: 7229276].
554 Sherman R. Lifestyle Interventions in Menopause. Complementary Health Practice Review. 2003;8(1):82.
555 Sherman S L. Premature ovarian failure among fragile X premutation carriers: parent-of-origin effect?[comment]. Am J Hum Genet. 2000;67(1):11-13. [pmid: 10848491]. [pmcid: 1287068].
556 Sherwin B. Estrogen-androgen therapy may help after surgical menopause. American Family Physician. 1994;49(5):1209-1210.
557 Sherwin B B. The impact of different doses of estrogen and progestin on mood and sexual behavior in postmenopausal women. J Clin Endocrinol Metab. 1991;72(2):336-343. [pmid: 1846872].
558 Sherwin B B. Cognitive assessment of postmenopausal women and general assessment of their mental health. Psychopharmacology Bulletin. 1998;34(3):323-326. [pmid: 9803764].
559 Sherwin B B, Gelfand M M. Effects of parenteral administration of estrogen and androgen on plasma hormone levels and hot flushes in the surgical menopause. Am J Obstet Gynecol. 1984;148(5):552-557. [pmid: 6367474].
560 Sherwin B B, Gelfand M M. Differential symptom response to parenteral estrogen and/or androgen administration in the surgical menopause. Am J Obstet Gynecol. 1985;151(2):153-160. [pmid: 3881960].
561 Sherwin B B, Gelfand M M. Sex steroids and affect in the surgical menopause: a double-blind, cross-over study. Psychoneuroendocrinology. 1985;10(3):325-335. [pmid: 3903822].
562 Sherwin B B, Gelfand M M, Brender W. Androgen enhances sexual motivation in females: a prospective, crossover study of sex steroid administration in the surgical menopause. Psychosomatic Medicine. 1985;47(4):339-351. [pmid: 4023162].
563 Sherwin B B, Gelfand M M, Schucher R, Gabor J. Postmenopausal estrogen and androgen replacement and lipoprotein lipid concentrations. Am J Obstet Gynecol. 1987;156(2):414-419. [pmid: 3826177].
564 Sherwin B B, Suranyi-Cadotte B E. Up-regulatory effect of estrogen on platelet 3H-imipramine binding sites in surgically menopausal women. Biological Psychiatry. 1990;28(4):339-348. [pmid: 2168762].
565 Shifren J L, Braunstein G D, Simon J A, et al. Transdermal testosterone treatment in women with impaired sexual function after oophorectomy.[see comment]. N Engl J Med. 2000;343(10):682-688. [pmid: 10974131].
566 Shifren J L, Nahum R, Mazer N A. Incidence of sexual dysfunction in surgically menopausal women. Menopause. 1998;5(3):189-190. [pmid: 9774766].
567 Shwayder J M. Pathophysiology of abnormal uterine bleeding. Obstetrics & Gynecology Clinics of North America. 2000;27(2):219-234. [pmid: 10857116].
568 Sidani M, Campbell J. Gynecology: select topics. Primary Care; Clinics in Office Practice. 2002;29(2):297-321. vi.
569 Sievert L L, Espinosa-Hernandez G. Attitudes toward menopause in relation to symptom experience in Puebla, Mexico. Women & Health. 2003;38(2):93-106.
570 Silberstein S D. The role of sex hormones in headache. Neurology. 1992;42(3 Suppl 2):37-42. [pmid: 1557190].
571 Simkin-Silverman L R, Wing R R, Boraz M A, Kuller L H. Lifestyle intervention can prevent weight gain during menopause: Results from a 5-year randomized clinical trial. Ann Behav Med. 2003;26(3):212-220. [pmid: 14644697].
572 Simkin-Silverman L R, Wing R R, Plantinga P, Matthews K A, Kuller L H. Lifetime weight cycling and psychological health in normal-weight and overweight women. International Journal of Eating Disorders. 1998;24(2):175-183. [pmid: 9697016].
573 Slaven L, Lee C. Mood and symptom reporting among middle-aged women: the relationship between menopausal status, hormone replacement therapy, and exercise participation. Health Psychology. 1997;16(3):203-208. [pmid: 9152697].
574 Sloan J A, Loprinzi C L, Novotny P J, Barton D L, LaVasseur B I, Windschitl H E. Methodological lessons learned from hot flash studies. J Clin Oncol. 2001;19(23):4280-4290. [pmid: 11731510].
575 Sluijmer A V, Heineman M J, De Jong F H, Evers J L. Endocrine activity of the postmenopausal ovary: the effects of pituitary down-regulation and oophorectomy. J Clin Endocrinol Metab. 1995;80(7):2163-2167. [pmid: 7608272].
576 Small G, Kornstein S, Schneider L, Clary Cathryn M. Effect of ERT with and without progesterone on clinical response to sertraline in elderly depression. 14th Annual Meeting of the American Association for Geriatric Psychiatry. 2001.
577 Smith C A, McCleary C A, Murdock G A, et al. Lifelong estrogen exposure and cognitive performance in elderly women. Brain & Cognition. 1999;39(3):203-218. [pmid: 10101041].
578 Smith G, Waters W E. An epidemiological study of factors associated with perimenopausal hot flushes. Public Health. 1983;97(6):347-351. [pmid: 6657910].
579 Snieder H, MacGregor A J, Spector T D. Genes control the cessation of a woman's reproductive life: a twin study of hysterectomy and age at menopause. J Clin Endocrinol Metab. 1998;83(6):1875-1880. [pmid: 9626112].
580 Snowdon D A, Kane R L, Beeson W L, et al. Is early natural menopause a biologic marker of health and aging?. American Journal of Public Health. 1989;79(6):709-714. [pmid: 2729468].
581 Snyder G M, Sielsch E C, Reville B. The controversy of hormone-replacement therapy in breast cancer survivors. Oncol Nurs Forum. 1998;25(4):699-706. quiz 707-698. [pmid: 9599353].
582 Soules M R, Bremner W J. The menopause and climacteric: endocrinologic basis and associated symptomatology. Journal of the American Geriatrics Society. 1982;30(9):547-561. [pmid: 7050219].
583 Sowers M, Pope S, Welch G, Sternfeld B, Albrecht G. The association of menopause and physical functioning in women at midlife. Journal of the American Geriatrics Society. 2001;49(11):1485-1492. [pmid: 11890587].
584 Sowers M R, La Pietra M T. Menopause: its epidemiology and potential association with chronic diseases. Epidemiologic Reviews. 1995;17(2):287-302. [pmid: 8654512].
585 Stadberg E, Mattsson L A, Milsom I. Womens attitudes and knowledge about the climacteric period and its treatment. A Swedish population-based study. Maturitas. 1997;27(2):109-116. [pmid: 9255745].
586 Stadberg E, Mattsson L A, Milsom I. The prevalence and severity of climacteric symptoms and the use of different treatment regimens in a Swedish population. Acta Obstet Gynecol Scand. 1997;76(5):442-448. [pmid: 9197447].
587 Stadberg E, Mattsson L A, Milsom I. Factors associated with climacteric symptoms and the use of hormone replacement therapy. Acta Obstet Gynecol Scand. 2000;79(4):286-292. [pmid: 10746844].
588 Stadel B V, Weiss N. Characteristics of menopausal women: a survey of King and Pierce counties in Washington, 1973-1974. Am J Epidemiol. 1975;102(3):209-216. [pmid: 1163526].
589 Staropoli C A, Flaws J A, Bush T L, Moulton A W. Predictors of menopausal hot flashes. Journal of Women's Health. 1998;7(9):1149-1155.
590 Stearns V, Hayes D F. Approach to menopausal symptoms in women with breast cancer. Current Treatment Options in Oncology. 2002;3(2):179-190. [pmid: 12057081].
591 Stearns V, Isaacs C, Rowland J, et al. A pilot trial assessing the efficacy of paroxetine hydrochloride (Paxil) in controlling hot flashes in breast cancer survivors.[see comment]. Ann Oncol. 2000;11(1):17-22.
592 Steffens D C, Norton M C, Plassman B L, et al. Enhanced cognitive performance with estrogen use in nondemented community-dwelling older women. Journal of the American Geriatrics Society. 1999;47(10):1171-1175. [pmid: 10522948].
593 Steger R W, Peluso J J. Sex hormones in the aging female. Endocrinology & Metabolism Clinics of North America. 1987;16(4):1027-1043. [pmid: 3322816].
594 Steinberg KK, Thacker SB, Smith SJ, et al. A meta-analysis of the effect of estrogen replacement therapy on the risk of breast cancer.[see comment][erratum appears in JAMA 1991 Sep 11;266(10):1362]. JAMA. 1991;265(15):1985–1990.
595 Stephens C, Ross N. The relationship between hormone replacement therapy use and psychological symptoms: no effects found in a New Zealand sample. Health Care Women Int. 2002;23(4):408-414. [pmid: 12148918].
596 Stevens J C, Beard C M, O'Fallon W M, Kurland L T. Conditions associated with carpal tunnel syndrome. Mayo Clinic Proceedings. 1992;67(6):541-548. [pmid: 1434881].
597 Stevenson D W, Delprato D J. Multiple component self-control program for menopausal hot flashes. Journal of Behavior Therapy & Experimental Psychiatry. 1983;14(2):137-140. [pmid: 6352742].
598 Stewart D E, Boydell K M. Psychologic distress during menopause: associations across the reproductive life cycle. International Journal of Psychiatry in Medicine. 1993;23(2):157-162. [pmid: 8359998].
599 Stewart D E, Boydell K M, Derzko C, Marshall V. Psychologic distress during the menopausal years in women attending a menopause clinic. International Journal of Psychiatry in Medicine. 1992;22(3):213-220. [pmid: 1487384].
600 Stoll B A, Parbhoo S. Treatment of menopausal symptoms in breast cancer patients. Lancet. 1988;1(8597):1278-1279. [pmid: 2897538].
601 Stoll W. Phytopharmacon influences atrophic vaginal epithelium. Double-blind study, Cimicifuga vs. estrogenic substances. Therapeutikon. 1987;1:23-31.
602 Stone S C, Mickal A, Rye P H. Postmenopausal symptomatology, maturation index, and plasma estrogen levels. Obstetrics & Gynecology. 1975;45(6):625-627. [pmid: 1095996].
603 Streckfus C F, Baur U, Brown L J, Bacal C, Metter J, Nick T. Effects of estrogen status and aging on salivary flow rates in healthy Caucasian women. Gerontology. 1998;44(1):32-39. [pmid: 9436013].
604 Studd J W, Thom M H. Ovarian failure and ageing. Clinics in Endocrinology & Metabolism. 1981;10(1):89-113. [pmid: 6784985].
605 Svartvik L, Lidfeldt J, Nerbrand C, Samsioe G, Schersten B, Nilsson P M. Dyslipidaemia and impaired well-being in middle-aged women reporting low Sense of Coherence. The Women's Health in the Lund Area (WHLA) Study. Scandinavian Journal of Primary Health Care. 2000;18(3):177-182. [pmid: 11097104].
606 Swift M, West J. Clinical effects of a standardized soy extract in postmenopausal women. [letter; comment]. Menopause. 2001;8(1):76-77. [pmid: 11201520].
607 Swyer G I M, Mortimer C H, Perry W. Skeletal effects of oestrogen and testosterone in postmenopausal women. British Medical Journal. 1988;297(6649):687-688.
608 Szklo M, Cerhan J, Diez-Roux A V, et al. Estrogen replacement therapy and cognitive functioning in the Atherosclerosis Risk in Communities (ARIC) Study. Am J Epidemiol. 1996;144(11):1048-1057. [pmid: 8942436].
609 Taffe J, Dennerstein L. Time to the final menstrual period. Fertil Steril. 2002;78(2):397-403. [pmid: 12137880].
610 Taffe J, Garamszegi C, Dudley E, Dennerstein L. Determinants of self rated menopause status. Maturitas. 1997;27(3):223-229. [pmid: 9288694].
611 Tangney C C, Young J A, Murtaugh M A, Cobleigh M A, Oleske D M. Self-reported dietary habits, overall dietary quality and symptomatology of breast cancer survivors: a cross-sectional examination. Breast Cancer Research & Treatment. 2002;71(2):113-123. [pmid: 11881909].
612 Tax L, Goorissen E M, Kicovic P M. Clinical profile of Org OD 14. Maturitas. 1987;1:3-13. [pmid: 3306290].
613 Taylor M. Psychological consequences of surgical menopause. J Reprod Med. 2001;46(3 Suppl):317-324. [pmid: 11304879].
614 Tchen N, Juffs H G, Downie F P, et al. Cognitive function, fatigue, and menopausal symptoms in women receiving adjuvant chemotherapy for breast cancer. J Clin Oncol. 2003;21(22):4175-4183. [pmid: 14615445].
615 Theroux R, Taylor K. Women's decision making about the use of hormonal and nonhormonal remedies for the menopausal transition. JOGNN - Journal of Obstetric, Gynecologic, & Neonatal Nursing. 2003;32(6):712-723.
616 Thewes B, Butow P, Girgis A, Pendlebury S. The psychosocial needs of breast cancer survivors; a qualitative study of the shared and unique needs of younger versus older survivors. Psycho-Oncology. 2004;13(3):177-189. [pmid: 15022153].
617 This P, De La Rochefordiere A, Clough K, Fourquet A, Magdelenat H. Breast Cancer Group of the Institut C. Phytoestrogens after breast cancer. Endocrine-Related Cancer. 2001;8(2):129-134. [pmid: 11397668].
618 Thompson E, Douglas D, Reilly D. The homoeopathic consultation plus remedy vs. placebo for menopausal symptoms in breast cancer survivors: a pilot randomized, double-blind, placebo-controlled trial. Focus on Alternative and Complementary Therapies. 2002;7(1):112.
619 Tode T, Kikuchi Y, Hirata J, Kita T, Nakata H, Nagata I. Effect of Korean red ginseng on psychological functions in patients with severe climacteric syndromes. Int J Gynaecol Obstet. 1999;67(3):169-174. [pmid: 10659900].
620 Torgerson D J, Avenell A, Russell I T, Reid D M. Factors associated with onset of menopause in women aged 45–49. Maturitas. 1994;19(2):83-92. [pmid: 7968648].
621 Townsend J M, Carbone C L. Menopausal syndrome: illness or social role--a transcultural analysis. Culture, Medicine & Psychiatry. 1980;4(3):229-248.
622 Treloar A E, Boynton R E, Behn B G, Brown B W. Variation of the human menstrual cycle through reproductive life. Int J Fertil. 1967;12(1 Pt 2):77-126. [pmid: 5419031].
623 Trevoux R, Dieulangard P, Blum A. Efficacy and safety of Org OD 14 in the treatment of climacteric complaints. Maturitas. 1983;5(2):89-96. [pmid: 6633272].
624 Trichopoulos D, Polychronopoulou A, Brown J, MacMahon B. Obesity, serum cholesterol, and estrogens in premenopausal women. Oncology. 1983;40(3):227-231. [pmid: 6843949].
625 Tsao L I. Relieving discomforts: the help-seeking experiences of Chinese perimenopausal women in Taiwan. Journal of Advanced Nursing. 2002;39(6):580-588. [pmid: 12207756].
626 Tsaras G, Ambrus J. Comparative clinical trial of chlordiazepoxide plus amitriptyline against maprotiline in depression with a component of anxiety. Revue Medicale de la Suisse Romande. 1981;101(6):483-486. [pmid: 7029696].
627 Tulandi T, Kinch R A, Guyda H, et al. Effect of methyldopa on menopausal flushes, skin temperature, and luteinizing hormone secretion. Am J Obstet Gynecol. 1984;150(6):709-712. [pmid: 6496591].
628 Tulandi T, Kinch R A, Lal S. Effect of guanfacine, an alpha-adrenergic agonist, on menopausal flushing. Maturitas. 1986;8(3):197-200. [pmid: 3537635].
629 Tulandi T, Lal S, Kinch R A. Effect of intravenous clonidine on menopausal flushing and luteinizing hormone secretion. Br J Obstet Gynaecol. 1983;90(9):854-857. [pmid: 6351899].
630 Tuunainen A, Kripke D F, Elliot J A, et al. Depression and endogenous melatonin in postmenopausal women. Journal of Affective Disorders. 2002;69(13):149-158. [pmid: 12103461].
631 Urban R J, Veldhuis J D. A selective serotonin reuptake inhibitor, fluoxetine hydrochloride, modulates the pulsatile release of prolactin in postmenopausal women. Am J Obstet Gynecol. 1991;164(1 Pt 1):147-152. [pmid: 1986602].
632 Ushiroyama T, Ikeda A, Ueki M. Prevalence, incidence, and awareness in the treatment of menopausal urinary incontinence. Maturitas. 1999;33(2):127-132. [pmid: 10597876].
633 Ushiroyama T, Ikeda A, Ueki M. Evidence for attenuation of gonadotropin pulse frequency in hypergonadotropic women with estradiol secretion in the menopausal transition. Psychoneuroendocrinology. 1999;24(1):85-97. [pmid: 10098221].
634 Utian W H. Vaginal function in postmenopausal women. JAMA. 1983;249(2):194-195. [pmid: 6848801].
635 Utian W H. Overview on menopause. Am J Obstet Gynecol. 1987;156(5):1280-1283. [pmid: 3578448].
636 Utian W H, Boggs P P. The North American Menopause Society 1998 Menopause Survey. Part I: Postmenopausal women's perceptions about menopause and midlife. Menopause. 1999;6(2):122-128. [pmid: 10374218].
637 Utian W H, Lederman S A, Williams B M, Vega R Y, Koltun W D, Leonard T W. Relief of hot flushes with new plant-derived 10-component synthetic conjugated estrogens. Obstetrics & Gynecology. 2004;103(2):245-253. [pmid: 14754691].
638 Van Hall E V, Verdel M, Van Der Velden J. “Perimenopausal” complaints in women and men: a comparative study. Journal of Women's Health. 1994;3:45.
639 van Keep P A, Kellerhals J M. The impact of socio-cultural factors on symptom formation. Some results of a study on ageing women in Switzerland. Psychotherapy & Psychosomatics. 1974;23(16):251-263. [pmid: 4416302].
640 van Keep PA, Kellerhals JM. The ageing woman. About the influence of some social and cultural factors on the changes in attitude and behaviour that occur during and after the menopause. Acta Obstet Gynecol Scand Suppl. 1976(51):17–27.
641 van Lith N D, Motke J C. Opipramol in the climacteric syndrome. A double-blind, placebo-controlled trial. Maturitas. 1983;5(1):17-23. [pmid: 6348485].
642 van Lunsen RHW, Laan ETM, Everaerd AM. Postmenopausal sexual response and sexual functioning are not estrogen dependent and are improved by tibolone administration. Fertil Steril. 1998;70(3).
643 van Noord P A, Dubas J S, Dorland M, Boersma H, te Velde E. Age at natural menopause in a population-based screening cohort: the role of menarche, fecundity, and lifestyle factors. Fertil Steril. 1997;68(1):95-102. [pmid: 9207591].
644 Vanwesenbeeck I, Vennix P, van de Wiel H. ‘Menopausal symptoms’: associations with menopausal status and psychosocial factors. J Psychosom Obstet Gynaecol. 2001;22(3):149-158. [pmid: 11594716].
645 Vassilopoulou-Sellin R, Klein M J. Estrogen replacement therapy after treatment for localized breast carcinoma. Patient responses and opinions.[erratum appears in Cancer 1996 Feb 15;79(4):867]. Cancer. 1996;78(5):1043-1048. [pmid: 8780542].
646 Vassilopoulou-Sellin R, Klein M J. Health care priorities for menopausal women with a history of breast cancer. Southern Medical Journal. 2002;95(11):1269-1275. [pmid: 12539992].
647 Verbeke K, Dhont K, al. e. Clinical and hormaonal effects of long-term veralipride treatment in post-menopausal women. Maturitas. 1988;10(3):225–230.
648 Vervest H A, Kiewiet de Jonge M, Vervest T M, Barents J W, Haspels A A. Micturition symptoms and urinary incontinence after non-radical hysterectomy. Acta Obstet Gynecol Scand. 1988;67(2):141-146. [pmid: 3176929].
649 Vestergaard P, Hermann A P, Stilgren L, et al. Effects of 5 years of hormonal replacement therapy on menopausal symptoms and blood pressure-a randomised controlled study. Maturitas. 2003;46(2):123-132. [pmid: 14559383].
650 Villarruel A M, Harlow S D, Lopez M, Sowers M. El cambio de vida: conceptualizations of menopause and midlife among urban Latina women. Research & Theory for Nursing Practice. 2002;16(2):91-102. [pmid: 12371435].
651 Vittinghoff E, Shlipak MG, Varosy PD, et al. Risk factors and secondary prevention in women with heart disease: the Heart and Estrogen/progestin Replacement Study.[comment][summary for patients in Ann Intern Med. 2003 Jan 21;138(2):I10; PMID: 12529114]. Ann Intern Med. 2003;138(2)81–89.
652 Vollman RF. The menstrual cycle. Vol 7. Philadephia: W.B. Saunders Company; 1977.
653 Volpe A, Zirilli E, Baralti R, et al. Conjugated estrogens, estradiol valerate, estriol and tibolone (ORG OD14) in the control of the climacteric syndrome [abstract]. Archives of Gynecology. 1985;237(Suppl).
654 von Muehlen D G, Kritz-Silverstein D, Barrett-Connor E. A community-based study of menopause symptoms and estrogen replacement in older women. Maturitas. 1995;22(2):71-78. [pmid: 8538487].
655 Vrasti R, Schreppler D, Olteanu I. Prevalence of depression at menopause. Neurologia, Psihiatria, Neurochirurgia. 1986;31(1):47-52.
656 Wade C, Kronenberg F, Cushman L. Use of CAM Among U.S. Women: Preliminary Findings From a National Multi-Ethnic Survey. Complementary Health Practice Review. 2003;8(1):81.
657 Wakamatsu M M. What affects bladder function more: menopause or age?[comment]. Menopause. 2003;10(3):191-192. [pmid: 12792287].
658 Waldman T N. Menopause: when hormone replacement therapy is not an option. Part I. Journal of Women's Health. 1998;7(5):559-565.
659 Wang M. 42 cases of climacteric syndrome treated with auricular pellet pressure. Journal of Traditional Chinese Medicine. 1991;11(3):196-198. [pmid: 1749267].
660 Ware J C, McBrayer R H, Scott J A. Influence of sex and age on duration and frequency of sleep apnea events. Sleep. 2000;23(2):165-170. [pmid: 10737333].
661 Warnock J J K, Bundren J, Morris D W. Female hypoactive sexual desire disorder due to androgen deficiency: Clinical and psychometric issues. Psychopharmacology Bulletin. 1997;33(4):761-766. [pmid: 9493489].
662 Washio M. Kami-shoyo-san is usually used for women. Psychiatry & Clinical Neurosciences. 2003;57(3):345. [pmid: 12753579].
663 Waxman J, Zatzkis S M. Fibromyalgia and menopause. Examination of the relationship. Postgraduate Medicine. 1986;80(4):165-167. 170-161.
664 Weber D. The influence of an antidepressant drug on the factorial structure of intelligence scores in climacteric depressives. Universitaetsbibliothek Graz: II. 1977;367399.
665 Weel A E, Uitterlinden A G, Westendorp I C, et al. Estrogen receptor polymorphism predicts the onset of natural and surgical menopause. J Clin Endocrinol Metab. 1999;84(9):3146-3150. [pmid: 10487678].
666 Weissman M M, Klerman G L. Sex differences and the epidemiology of depression. Arch Gen Psychiatry. 1977;34(1):98-111. [pmid: 319772].
667 Weitzner M A, Moncello J, Jacobsen P B, Minton S. A pilot trial of paroxetine for the treatment of hot flashes and associated symptoms in women with breast cancer. Journal of Pain & Symptom Management. 2002;23(4):337-345. [pmid: 11997203].
668 Welnicka-Jaskiewicz M, Jassem J. The risks and benefits of hormonal replacement therapy in healthy women and in breast cancer survivors. Cancer Treatment Reviews. 2003;29(5):355-361. [pmid: 12972354].
669 Wender MCO, Freitas FM, Castro JAS, Mattiello SS, Estery C. Effectiveness of Tibolone X Placebo in Postmenopausal Women. 8th International Congress on the Menopause.96.
670 Westlund Tam L, Parry B L. Does estrogen enhance the antidepressant effects of fluoxetine?. Journal of Affective Disorders. 2003;77(1):87-92. [pmid: 14550939].
671 Wheatley D. Evaluation of psychotropic drugs in general practice. Proceedings of the Royal Society of Medicine. 1972;65(4):317-320. [pmid: 4554250].
672 White A R. Electro-acupuncture during the menopause altered mood but not vasomotor symptoms. Focus on Alternative & Complementary Therapies. 2003;8(2):212-214.
673 Whiteman M K, Staropoli C A, Langenberg P W, McCarter R J, Kjerulff K H, Flaws J A. Smoking, body mass, and hot flashes in midlife women. Obstetrics & Gynecology. 2003;101(2):264-272. [pmid: 12576249].
674 Wiegand M. A Gentle Alternative in the Therapy of Perimenopausal Symptoms: Findings of a Multicentric Study with a Total of 657 Patients. Biological Therapy: Journal of Natural Medicine. 1994;XII(1):162-165.
675 Wijma K, Melin A, Nedstrand E, Hammar M. Treatment of menopausal symptoms with applied relaxation: A pilot study. Journal of Behavior Therapy & Experimental Psychiatry. 1997;28(4):251-261. [pmid: 9489686].
676 Wilbur J, Dan A, Hedricks C, Holm K. The relationship among menopausal status, menopausal symptoms, and physical activity in midlife women. Family & Community Health. 1990;13(3):67-78.
677 Wilbur J, Miller A, Montgomery A. The influence of demographic characteristics, menopausal status, and symptoms on women's attitudes toward menopause. Women & Health. 1995;23(3):19-39.
678 Wilbur J, Miller A M, Montgomery A, Chandler P. Sociodemographic characteristics, biological factors, and symptom reporting in midlife women. Menopause. 1998;5(1):43-51. [pmid: 9689194].
679 Williams C W. Clonidine in treatment of menopausal flushing. Lancet. 1973;1(7816):1388. [pmid: 4122774].
680 Williamson J, White A. A randomized control trial to evaluate the effects of reflexology on women experiencing menopausal symptoms. Focus on Alternative and Complementary Therapies. 2001;6(1):98.
681 Wilmoth M C, Sanders L D. Accept me for myself: African American women's issues after breast cancer. Oncol Nurs Forum. 2001;28(5):875-879. [pmid: 11421147].
682 Wing R R, Matthews K A, Kuller L H, Meilahn E N, Plantinga P. Waist to hip ratio in middle-aged women. Associations with behavioral and psychosocial factors and with changes in cardiovascular risk factors. Arteriosclerosis & Thrombosis. 1991;11(5):1250-1257. [pmid: 1911710].
683 Wisniewski A B, Nguyen T T, Dobs A S. Evaluation of high-dose estrogen and high-dose estrogen plus methyltestosterone treatment on cognitive task performance in postmenopausal women. Hormone Research. 2002;58(3):150-155. [pmid: 12218381].
684 Wolfe B M, Koval J J, Nisker J A. Impact on postmenopausal symptoms of adding continuous C-21 versus C-19 progestin to estrogen. Maturitas. 1999;33(2):153-161. [pmid: 10597880].
685 Woods N F, Mariella A, Mitchell E S. Patterns of depressed mood across the menopausal transition: approaches to studying patterns in longitudinal data. Acta Obstet Gynecol Scand. 2002;81(7):623-632. [pmid: 12190837].
686 Woods N F, Mitchell E S. Patterns of depressed mood in midlife women; observations from the Seattle Midlife Women's Health Study. Res Nurs Health. 1996;19(2):111-123. [pmid: 8606981].
687 Woods N F, Mitchell E S, Adams C. Memory functioning among midlife women: observations from the Seattle Midlife Women's Health Study. Menopause. 2000;7(4):257-265. [pmid: 10914619].
688 Woodward S, Freedman R R. The thermoregulatory effects of menopausal hot flashes on sleep. Sleep. 1994;17(6):497-501. [pmid: 7809562].
689 Wool C, Cerutti R, Marquis P, Cialdella P, Hervie C. Life IISGoQo. Psychometric validation of two Italian quality of life questionnaires in menopausal women. Maturitas. 2000;35(2):129-142. [pmid: 10924839].
690 Wren B G, McFarland K, Edwards L. Micronised transdermal progesterone and endometrial response. Lancet. 1999;354(9188):1447-1448. [pmid: 10543679].
691 Wren B G, McFarland K, Edwards L, et al. Effect of sequential transdermal progesterone cream on endometrium, bleeding pattern, and plasma progesterone and salivary progesterone levels in postmenopausal women.[see comment]. Climacteric. 2000;3(3):155-160. [pmid: 11910616].
692 Wu L, Zhou X. 300 cases of menopausal syndrome treated by acupuncture. Journal of Traditional Chinese Medicine. 1998;18(4):259-262. [pmid: 10453593].
693 Wu X. [Comparative effectiveness of Chinese H3 and liu wei di huang wan in the treatment of the female climacteric syndrome]. Zhong Xi Yi Jie He Za Zhi. 1986;6(6):336-338. 323. [pmid: 2946470].
694 Wu X. Comparative effectiveness of Chinese H3 (CH3) and liu wei di huang wan (LWDHW) in female climacteric and their mechanism of action. Journal of Traditional Chinese Medicine. 1987;7(4):266-268. [pmid: 3130527].
695 Yarnell E, Abascal K. Herbal Medicine for Treating Menopausal Symptoms. Alternative & Complementary Therapies. 2003;9(6):299-306.
696 Ylikorkala O. Clonidine in the treatment of menopausal symptoms. Annales Chirurgiae et Gynaecologiae Fenniae. 1975;64(4):242-245. [pmid: 1103700].
697 Yoon B K, Kim D K, Kang Y, Kim J W, Shin M H, Na D L. Hormone replacement therapy in postmenopausal women with Alzheimer's disease: a randomized, prospective study. Fertil Steril. 2003;79(2):274-280. [pmid: 12568834].
698 Young E, Korszun A. Psychoneuroendocrinology of depression: Hypothalamic-pituitary-gonadal axis. Psychiatric Clinics of North America. 1998;21(2):309-323. [pmid: 9670228].
699 Young M, Denny G, Young T, Luquis R. Sexual satisfaction among married women age 50 and older. Psychological Reports. 2000;86(3 Pt 2):1107-1122. [pmid: 10932565].
700 Young R L, Kumar N S, Goldzieher J W. Management of menopause when estrogen cannot be used. Drugs. 1990;40(2):220-230. [pmid: 2226213].
701 Younus J, Simpson I, Collins A, Wang X. Mind control of menopause. Womens Health Issues. 2003;13(2):74-78. [pmid: 12732444].
702 Zibecchi L, Greendale G A, Ganz P A. Continuing education: Comprehensive menopausal assessment: an approach to managing vasomotor and urogenital symptoms in breast cancer survivors. Oncol Nurs Forum. 2003;30(3):393-407. [pmid: 12719740].
703 Zumoff B. Hormonal profiles in women with breast cancer. Obstetrics & Gynecology Clinics of North America. 1994;21(4):751-772. [pmid: 7731646].
704 Zumoff B, Strain G W, Miller L K, Rosner W. Twenty-four-hour mean plasma testosterone concentration declines with age in normal premenopausal women. J Clin Endocrinol Metab. 1995;80(4):1429-1430. [pmid: 7714119].
705 Zwiens G, Sturm G, Eulenburg R. Treatment of climacteric disorders by low doses of clonidine [abstract]. Archives of Gynecology. 1985;237(Suppl):pp.252.