# References

1 North American Menopause Society. Available at: www.menopause.org. Accessed 13 Dec, 2004.
2 Soules M R, Sherman S, Parrott E, et al. Executive summary: stages of reproductive aging workshop (STRAW) Park City, Utah, July 2001. Menopause. 2001;8:402-7. [pmid: 21141649].
3 National Institutes of Health. Assessing and improving measures of hot flashes: summary of an NIH workshop. Bethesda, Maryland: Rose Li and Associates; January 20, 2004.
4 Greene J G. A factor analytic study of climacteric symptoms. Journal of Psychosomatic Research. 1976;20(5):425-30. [pmid: 1003364].
5 Beck A T, Ward C H, Mendelson M, et al. An inventory for measuring depression. Arch Gen Psychiatry. 1961;4:561-71. [pmid: 13688369].
6 McNair D M, Lorr M. An analysis of mood in neurotics. Journal of Abnormal & Social Psychology. 1964;69(6):620-27.
7 Fazio AF. A concurrent validational study of the NCHS General Well-Being schedule. Vital & Health Statistics, Series 2. No 73, Sep 1977, 53.: U Wisconsin, Milwaukee; 1977.
8 Taylor J F, Rosen R C, Leiblum S R. Self-report assessment of female sexual function: Psychometric evaluation of the Brief Index of Sexual Functioning for Women. Arch Sex Behav. 1994;23(6):627-43. [pmid: 7872859].
9 Nathorst-Boos J, Wiklund I, Mattsson L A, et al. Is sexual life influenced by transdermal estrogen therapy? A double blind placebo controlled study in postmenopausal women. Acta Obstet Gynecol Scand. 1993;72(8):656-60. [pmid: 8259754].
10 Hilditch J R, Lewis J, Peter A, et al. A menopause-specific quality of life questionnaire: Development and psychometric properties. Maturitas. 1996;24(3):161-75. [pmid: 8844630].
11 Wiklund I, Holst J, Karlberg J, et al. A new methodological approach to the evaluation of quality of life in postmenopausal women. Maturitas. 1992;14(3):211-24. [pmid: 1508061].
12 Ware J E, Sherbourne C D. The MOS 36-item short-form health survey (SF-36): I. Conceptual framework and item selection. Medical Care. 1992;30(6):473-83. [pmid: 1593914].
13 Slavin R E. Best practice synthesis: An alternative to meta-analytic and traditional reviews. Education Research. 1986;15:5-11.
14 National Center for Complementary and Alternative Medicine. http://nccam.nih.gov/health/whatiscam/. Accessed 10 Dec., 2004.
15 Nelson H D. Commonly used types of postmenopausal estrogen for treatment of hot flashes: scientific review. JAMA. 2004;291(13):1610-20. [pmid: 15069049].
16 MacLennan AH, Broadbent JL, Lester S, et al. Oral oestrogen and combined oestrogen/progestogen therapy versus placebo for hot flushes. Cochrane Database Syst Rev 2004.
17 Nelson HD, Nygren P, Freeman M, et al. Drug Class Review on Estrogens. Final report. http://www.ohsu.edu/drugeffectiveness/reports/documents/Estrogens%20Final%20Report%20u2.pdf 2004. Accessed 10 Jan. 2005.
18 Krebs E E, Ensrud K E, MacDonald R, et al. Phytoestrogens for treatment of menopausal symptoms: A systematic review. Obstet Gynecol. 2004;104(4):824-36. [pmid: 15458907].
19 Harris R P, Helfand M, Woolf S H, et al. Current methods of the third U.S. Preventive Services Task Force. Am J Prev Med. 2001;20(3S):21-35. [pmid: 11306229].
20 Avis N E, Brambilla D, McKinlay S M, et al. A longitudinal analysis of the association between menopause and depression. Results from the Massachusetts Women's Health Study. Ann Epidemiol. 1994;4(3):214-20. [pmid: 8055122].
21 Avis N E, Crawford S L, McKinlay S M. Psychosocial, behavioral, and health factors related to menopause symptomatology. Womens Health. 1997;3(2):103-20. [pmid: 9332153].
22 Avis N E, Stellato R, Crawford S, et al. Is there an association between menopause status and sexual functioning?. Menopause. 2000;7(5):297-309. [pmid: 10993029].
23 McKinlay J B, McKinlay S M, Brambilla D. The relative contributions of endocrine changes and social circumstances to depression in mid-aged women. J Health Soc Behav. 1987;28(4):345-63. [pmid: 3429805].
24 McKinlay SM, McKinlay JB. The impact of menopause and social factors on health. In: Hammond CB, Haseltine FP, Schiff I, editors. Menopause: Evaluation, treatment, and health concerns. New York: Alan R. Liss; 1989. p. 137–61.
25 McKinlay S M, Brambilla D J, Posner J G. The normal menopause transition. Maturitas. 1992;14(2):103-15. [pmid: 1565019].
26 Mitchell E S, Woods N F. Symptom experiences of midlife women: observations from the Seattle Midlife Women's Health Study. Maturitas. 1996;25(1):1-10. [pmid: 8887303].
27 Mitchell E S, Fugate Woods N. Midlife women's attributions about perceived memory changes: Observations from the Seattle Midlife Women's Health Study. J Womens Health Gender Based Med. 2001;10(4):351-62.
28 Woods N F, Mitchell E S. Pathways to depressed mood for midlife women: observations from the Seattle Midlife Women's Health Study. Res Nurs Health. 1997;20(2):119-29. [pmid: 9100742].
29 Glazer G, Zeller R, Delumba L, et al. The Ohio Midlife Women's Study. Health Care Women Int. 2002;23(67):612-30. [pmid: 12418983].
30 Busch C M, Zonderman A B, Costa P T. Menopausal transition and psychological distress in a nationally representative sample: Is menopause associated with psychological distress?. J Aging Health. 1994;6(2):209-28.
31 Sowers M, Luborsky J, Perdue C, et al. Thyroid stimulating hormone (TSH) concentrations and menopausal status in women at the mid-life: SWAN. Clin Endocrinol. 2003;58(3):340-7.
32 Sowers M, Crawford SL, Sternfeld B, et al. SWAN: A multicenter, multiethnic, community-based cohort study of women and the menopausal transition. In: Lobo RA, Kelsey J, Marcus R, editors. Menopause: Biology and pathobiology. San Diego, CA: Academic Press; 2000. p. 175–88.
33 Avis N E, Stellato R, Crawford S, et al. Is there a menopausal syndrome? Menopausal status and symptoms across racial/ethnic groups. Soc Sci Med. 2001;52(3):345-56. [pmid: 11330770].
34 Avis N E, Ory M, Matthews K A, et al. Health-related quality of life in a multiethnic sample of middle-aged women: Study of Women's Health Across the Nation (SWAN). Medical Care. 2003;41(11):1262-76. [pmid: 14583689].
35 Bromberger J T, Meyer P M, Kravitz H M, et al. Psychologic distress and natural menopause: a multiethnic community study. Am J Public Health. 2001;91(9):1435-42. [pmid: 11527777].
36 Bromberger J T, Assmann S F, Avis N E, et al. Persistent mood symptoms in a multiethnic community cohort of pre- and perimenopausal women. Am J Epidemiol. 2003;158(4):347-56. [pmid: 12915500].
37 Gold E B, Sternfeld B, Kelsey J L, et al. Relation of demographic and lifestyle factors to symptoms in a multi-racial/ethnic population of women 40–55 years of age. Am J Epidemiol. 2000;152(5):463-73. [pmid: 10981461].
38 Kravitz H M, Ganz P A, Bromberger J, et al. Sleep difficulty in women at midlife: a community survey of sleep and the menopausal transition. Menopause. 2003;10(1):19-28. [pmid: 12544673].
39 Randolph J F Jr, Sowers M, Gold E B, et al. Reproductive hormones in the early menopausal transition: relationship to ethnicity, body size, and menopausal status. J Clin Endocrinol Metab. 2003;88(4):1516-22. [pmid: 12679432].
40 Koch P B, Mansfield P K, Voda A. Predictors of sexual response changes in heterosexual midlife women. Health Values. 1995;19(1):10-20.
41 Freeman E W, Sammel M D, Liu L, et al. Hormones and menopausal status as predictors of depression in women in transition to menopause. Arch Gen Psychiatry. 2004;61(1):62-70. [pmid: 14706945].
42 Gracia C R, Sammel M D, Freeman E W, et al. Predictors of decreased libido in women during the late reproductive years. Menopause. 2004;11(2):144-50. [pmid: 15021443].
43 Rodstrom K, Bengtsson C, Lissner L, et al. A longitudinal study of the treatment of hot flushes: the population study of women in Gothenburg during a quarter of a century. Menopause. 2002;9:156-61. [pmid: 11973438].
44 Hallstrom T, Samuelsson S. Mental health in the climacteric. The longitudinal study of women in Gothenburg. Acta Obstet Gynecol Scand Suppl. 1985;130:13-8. [pmid: 3859970].
45 Milsom I, Ekelund P, Molander U, et al. The influence of age, parity, oral contraception, hysterectomy and menopause on the prevalence of urinary incontinence in women. Journal of Urology. 1993;149(6):1459-62. [pmid: 8501788].
46 Brown W J, Mishra G D, Dobson A. Changes in physical symptoms during the menopause transition. Int J Behav Med. 2002;9(1):53-67. [pmid: 12112996].
47 Mishra G D, Brown W J, Dobson A J. Physical and mental health: changes during menopause transition. Quality of Life Research. 2003;12(4):405-12. [pmid: 12797713].
48 Kuh D L, Wadsworth M, Hardy R. Women's health in midlife: the influence of the menopause, social factors and health in earlier life. Br J Obstet Gynaecol. 1997;104(8):923-33. [pmid: 9255084].
49 Kuh D, Cardozo L, Hardy R. Urinary incontinence in middle aged women: childhood enuresis and other lifetime risk factors in a British prospective cohort. Journal of Epidemiology & Community Health. 1999;53(8):453-8. [pmid: 10562862].
50 Kuh D, Hardy R, Rodgers B, et al. Lifetime risk factors for women's psychological distress in midlife. Soc Sci Med. 2002;55(11):1957-73. [pmid: 12406464].
51 Hardy R, Kuh D. Change in psychological and vasomotor symptom reporting during the menopause. Soc Sci Med. 2002;55(11):1975-88. [pmid: 12406465].
52 Dennerstein L, Dudley E, Burger H. Well-being and the menopausal transition. J Psychosom Obstet Gynaecol. 1997;18(2):95-101. [pmid: 9219105].
53 Dennerstein L, Dudley E C, Hopper J L, et al. A prospective population-based study of menopausal symptoms. Obstet Gynecol. 2000;96(3):351-8. [pmid: 10960625].
54 Dennerstein L, Lehert P, Burger H, et al. Mood and the menopausal transition. J Nerv Ment Dis. 1999;187(11):685-91. [pmid: 10579597].
55 Dennerstein L, Lehert P, Dudley E, et al. Factors contributing to positive mood during the menopausal transition. Journal of Nervous & Mental Disease. 2001;189(2):84-9. [pmid: 11225691].
56 Sherburn M, Guthrie J R, Dudley E C, et al. Is incontinence associated with menopause?. Obstet Gynecol. 2001;98(4):628-33. [pmid: 11576579].
57 Dennerstein L, Dudley E, Burger H. Are changes in sexual functioning during midlife due to aging or menopause?. Fertil Steril. 2001;76(3):456-60. [pmid: 11532464].
58 Dennerstein L, Randolph J, Taffe J, et al. Hormones, mood, sexuality, and the menopausal transition. Fertil Steril. 2002;77(Suppl 4):S42-8. [pmid: 12007901].
59 Dennerstein L, Lehert P, Guthrie J. The effects of the menopausal transition and biopsychosocial factors on well-being. Archives of Women's Mental Health. 2002;5(1):15-22.
60 Dennerstein L, Smith A M, Morse C, et al. Menopausal symptoms in Australian women. Med J Aust. 1993;159(4):232-6. [pmid: 8412889].
61 Dennerstein L, Smith A M, Morse C A, et al. Sexuality and the menopause. J Psychosom Obstet Gynaecol. 1994;15(1):59-66. [pmid: 8038890].
62 Guthrie J R, Dennerstein L, Hopper J L, et al. Hot flushes, menstrual status, and hormone levels in a population-based sample of midlife women. Obstet Gynecol. 1996;88(3):437-42. [pmid: 8752255].
63 Kaufert P A, Gilbert P, Tate R. The Manitoba Project: a re-examination of the link between menopause and depression. Maturitas. 1992;14(2):143-55. [pmid: 1565022].
64 Koster A, Davidsen M. Climacteric complaints and their relation to menopausal development--a retrospective analysis. Maturitas. 1993;17(3):155-66. [pmid: 8133790].
65 Koster A, Garde K. Sexual desire and menopausal development. A prospective study of Danish women born in 1936. Maturitas. 1993;16(1):49-60. [pmid: 8429803].
66 Koster A, Eplov L F, Garde K. Anticipations and experiences of menopause in a Danish female general population cohort born in 1936. Archives of Women's Mental Health. 2002;5(1):9-13.
67 Maartens L W, Leusink G L, Knottnerus J A, et al. Climacteric complaints in the community. Family Practice. 2001;18(2):189-94. [pmid: 11264270].
68 Maartens L W, Knottnerus J A, Pop V J. Menopausal transition and increased depressive symptomatology: a community based prospective study. Maturitas. 2002;42(3):195-200. [pmid: 12161043].
69 Hunter M S, Whitehead M I. Psychological experience of the climacteric and postmenopause. Progress in Clinical & Biological Research. 1989;320:211-24. [pmid: 2602440].
70 Avis N E, Kaufert P A, Lock M, et al. The evolution of menopausal symptoms. Baillieres Clin Endocrinol Metab. 1993;7(1):17-32. [pmid: 8435051].
71 Bardel A, Wallander M A, Svardsudd K. Hormone replacement therapy and symptom reporting in menopausal women: a population-based study of 35–65-year-old women in mid-Sweden. Maturitas. 2002;41(1):7-15. [pmid: 11809338].
72 Bell M L. Attitudes toward menopause among Mexican American women. Health Care Women Int. 1995;16(5):425-35. [pmid: 8576014].
73 Feldman B M, Voda A, Gronseth E. The prevalence of hot flash and associated variables among perimenopausal women. Res Nurs Health. 1985;8(3):261-8. [pmid: 3852361].
74 Groeneveld F P, Bareman F P, Barentsen R, et al. The climacteric and well-being. J Psychosom Obstet Gynaecol. 1993;14(2):127-43. [pmid: 8358526].
75 Hagstad A, Janson P O. The epidemiology of climacteric symptoms. Acta Obstet Gynecol Scand Suppl. 1986;134:59-65. [pmid: 3468732].
76 Hammar M, Berg G, Fahraeus L, et al. Climacteric symptoms in an unselected sample of Swedish women. Maturitas. 1984;6(4):345-50. [pmid: 6533438].
77 Hording U, Pedersen K H, Sidenius K, et al. Urinary incontinence in 45-year-old women. An epidemiological survey. Scandinavian Journal of Urology & Nephrology. 1986;20(3):183-6. [pmid: 3787195].
78 Jaszmann L, Van Lith N D, Zaat J C. The age of menopause in the Netherlands. The statistical analysis of a survey. Int J Fertil. 1969;14(2):106-17. [pmid: 5786396].
79 Jansson C, Johansson S, Lindh-Astrand L, et al. The prevalence of symptoms possibly related to the climacteric in pre- and postmenopausal women in Linkoping, Sweden. Maturitas. 2003;45(2):129-35. [pmid: 12787971].
80 Keenan N L, Mark S, Fugh-Berman A, et al. Severity of menopausal symptoms and use of both conventional and complementary/alternative therapies. Menopause. 2003;10(6):507-15. [pmid: 14627858].
81 Li C, Wilawan K, Samsioe G, et al. Health profile of middle-aged women: The Women's Health in the Lund Area (WHILA) study. Human Reproduction. 2002;17(5):1379-85. [pmid: 11980768].
82 McKinlay S M, Jefferys M. The menopausal syndrome. Br J Prev Soc Med. 1974;28(2):108-15. [pmid: 4854952].
83 O'Connor V M, Del Mar C B, Sheehan M, et al. Do psycho-social factors contribute more to symptom reporting by middle-aged women than hormonal status?. Maturitas. 1995;20(23):63-9. [pmid: 7715476].
84 Olofsson A S, Collins A. Psychosocial factors, attitude to menopause and symptoms in Swedish perimenopausal women. Climacteric. 2000;3(1):33-42. [pmid: 11910608].
85 Porter M, Penney G C, Russell D, et al. A population based survey of women's experience of the menopause. Br J Obstet Gynaecol. 1996;103(10):1025-8. [pmid: 8863703].
86 Rekers H, Drogendijk A C, Valkenburg H A, et al. The menopause, urinary incontinence and other symptoms of the genito-urinary tract. Maturitas. 1992;15(2):101-11. [pmid: 1470043].
87 Rybo G, Westerberg H. Symptoms in the postmenopause--a population study. A preliminary report. Acta Obstet Gynecol Scand Suppl. 1971;9(Suppl9):25. [pmid: 5287098].
88 Schwingl P J, Hulka B S, Harlow S D. Risk factors for menopausal hot flashes. Obstet Gynecol. 1994;84(1):29-34. [pmid: 8008318].
89 Slaven L, Lee C. A cross-sectional survey of menopausal status, symptoms and psychological distress in a community sample of Australian women. J Health Psychol. 1998;3(1):117-23.
90 Thompson B, Hart S A, Durno D. Menopausal age and symptomatology in a general practice. J Biosoc Sci. 1973;5(1):71-82. [pmid: 4693879].
91 Young T, Rabago D, Zgierska A, et al. Objective and subjective sleep quality in premenopausal, perimenopausal, and postmenopausal women in the Wisconsin Sleep Cohort Study. Sleep. 2003;26(6):667-72. [pmid: 14572118].
92 Young T, Finn L, Austin D, et al. Menopausal status and sleep-disordered breathing in the Wisconsin Sleep Cohort Study. Am J Respir Crit Care Med. 2003;167(9):1181-5. [pmid: 12615621].
93 Matthews K A, Wing R R, Kuller L H, et al. Influences of natural menopause on psychological characteristics and symptoms of middle-aged healthy women. J Consult Clin Psychol. 1990;58(3):345-51. [pmid: 2365898].
94 Treloar A E. Menstrual cyclicity and the pre-menopause. Maturitas. 1981;3(34):249-64. [pmid: 7334935].
95 Treloar A E. Menarche, menopause, and intervening fecundability. Hum Biol. 1974;46(1):89-107. [pmid: 4426598].
96 McKinlay S M, Bigano N L, McKinlay J B. Smoking and age at menopause. Ann Intern Med. 1985;103:350-6. [pmid: 4026083].
97 Nilsson P, Moller L, Koster A, et al. Social and biological predictors of early menopause: a model for premature aging. J Intern Med. 1997;242(4):299-305. [pmid: 9366808].
98 Cooper G S, Sandler D P, Bohlig M. Active and passive smoking and the occurrence of natural menopause. Epidemiology. 1999;10(6):771-3. [pmid: 10535795].
99 Kato I, Toniolo P, Akhmedkhanov A, et al. Prospective study of factors influencing the onset of natural menopause. J Clin Epidemiol. 1998;51(12):1271-6. [pmid: 10086819].
100 Whelan E A, Sandler D P, McConnaughey D R, et al. Menstrual and reproductive characteristics and age at natural menopause. Am J Epidemiol. 1990;131(4):625-32. [pmid: 2316494].
101 Sherman B, Wallace R, Bean J, et al. Relationship of body weight to menarcheal and menopausal age: implications for breast cancer risk. J Clin Endocrinol Metab. 1981;52(3):488-93. [pmid: 7462400].
102 MacLennan AH, Henry D, Hills S, et al. Oral oestrogen replacement therapy versus placebo for hot flushes, Menstrual Disorders Module of the Cochrane Database of Systematic Reviews. Menstrual Disorders Module of the Cochrane Database Syst Rev 2000.
103 MacLennan A, Lester S, Moore V. Oral estrogen replacement therapy versus placebo for hot flushes: a systematic review. Climacteric. 2001;4(1):58-74. [pmid: 11379379].
104 Nelson H D. Postmenopausal estrogen for treatment of hot flashes: clinical applications. JAMA. 2004;291(13):1621-25. [pmid: 15069050].
105 Speroff L. Efficacy and tolerability of a novel estradiol vaginal ring for relief of menopausal symptoms. Obstet Gynecol. 2003;102:823-34. [pmid: 14551014].
106 Al-Azzawi F, Buckler H M. Comparison of a novel vaginal ring delivering estradiol acetate versus oral estradiol for relief of vasomotor menopausal symptoms. Climacteric. 2003;6(2):118-27. [pmid: 12841882].
107 Ayton R A, Darling G M, Murkies A L, et al. A comparative study of safety and efficacy of continuous low dose oestradiol released from a vaginal ring compared with conjugated equine oestrogen vaginal cream in the treatment of postmenopausal urogenital atrophy. Br J Obstet Gynaecol. 1996;103(4):351-8. [pmid: 8605133].
108 Bachmann G, Notelovitz M, Nachtigall L, et al. A comparative study of a low-dose estradiol vaginal ring and conjugated estrogen cream for postmenopausal urogenital atrophy. Primary Care Update for Ob/Gyns. 1997;4(3):109-15.
109 Rioux J E, Devlin C, Gelfand M M, et al. 17beta-estradiol vaginal tablet versus conjugated equine estrogen vaginal cream to relieve menopausal atrophic vaginitis. Menopause. 2000;7(3):156-61. [pmid: 10810960].
110 Wiklund I, Karlberg J, Mattsson L A. Quality of life of postmenopausal women on a regimen of transdermal estradiol therapy: a double-blind placebo-controlled study. Am J Obstet Gynecol. 1993;168(3 Pt 1):824-30. [pmid: 8456888].
111 von Holst T, Salbach B. Efficacy and tolerability of a new 7-day transdermal estradiol patch versus placebo in hysterectomized women with postmenopausal complaints. Maturitas. 2000;34(2):143-53. [pmid: 10714909].
112 Shulman L P, Yankov V, Uhl K. Safety and efficacy of a continuous once-a-week 17beta-estradiol/levonorgestrel transdermal system and its effects on vasomotor symptoms and endometrial safety in postmenopausal women: the results of two multicenter, double-blind, randomized, controlled trials. Menopause. 2002;9(3):195-207. [pmid: 11973443].
113 Campbell S. Double blind psychometric studies on the effects of natural estrogens on post-menopausal women. In: Campbell S, editor. The Management of the Menopause and Post Menopausal Years. Lancaster: MTP; 1976.
114 Good W R, John V A, Ramirez M, et al. Comparison of Alora estradiol matrix transdermal delivery system with oral conjugated equine estrogen therapy in relieving menopausal symptoms. Climacteric. 1999;2(1):29-36. [pmid: 11915854].
115 Polo-Kantola P, Erkkola R, Helenius H, et al. When does estrogen replacement therapy improve sleep quality?. Am J Obstet Gynecol. 1998;178(5):1002-9. [pmid: 9609575].
116 Hays J, Ockene J, Brunner R, et al. Effects of estrogen plus progestin on health-related quality of life. N Engl J Med. 2003;348(19):1839-54. [pmid: 12642637].
117 Purdie D W, Empson J A C, Crichton C, et al. Hormone replacement therapy, sleep quality and psychological wellbeing. Br J Obstet Gynaecol. 1995;102(9):735-39. [pmid: 7547766].
118 Soares C d N, Almeida O P, Joffe H, et al. Efficacy of estradiol for the treatment of depressive disorders in perimenopausal women: A double-blind, randomized, placebo-controlled trial. Arch Gen Psychiatry. 2001;58(6):529-34. [pmid: 11386980].
119 Strickler R, Stovall D W, Merritt D, et al. Raloxifene and estrogen effects on quality of life in healthy postmenopausal women: a placebo-controlled randomized trial. Obstet Gynaecol. 2000;96(3):359-65.
120 Voss S, Quail D, Dawson A, et al. A randomised, double-blind trial comparing raloxifene HCl and continuous combined hormone replacement therapy in postmenopausal women: effects on compliance and quality of life. BJOG. 2002;109(8):874-85. [pmid: 12197366].
121 Khoo S K, Coglan M, Battistutta D, et al. Hormonal treatment and psychological function during the menopausal transition: an evaluation of the effects of conjugated estrogens/cyclic medroxyprogesterone acetate. Climacteric. 1998;1(1):55-62. [pmid: 11907928].
122 Bech P, Munk-Jensen N, Obel E, et al. Combined versus sequential hormonal replacement therapy: A double-blind, placebo-controlled study on quality of life-related outcome measures. Psychother Psychosom. 1998;67(45):259-65. [pmid: 9693354].
123 Saure A, Planellas J, Poulsen H K, et al. A double-blind, randomized, comparative study evaluating clinical effects of two sequential estradiol-progestogen combinations containing either desogestrel or medroxyprogesterone acetate in climacteric women. Maturitas. 2000;34(2):133-42. [pmid: 10714908].
124 Ditkoff E C, Crary W G, Cristo M, et al. Estrogen improves psychological function in asymptomatic postmenopausal women. Obstet Gynaecol. 1991;78(6):991-5.
125 Furuhjelm M, Karlgren E, Carlstrom K. The effect of estrogen therapy on somatic and psychical symptoms in postmenopausal women. Acta Obstet Gynecol Scand. 1984;63(7):655-61. [pmid: 6440406].
126 Hall G, Pripp U, Schenck-Gustafsson K, et al. Long-term effects of hormone replacement therapy on symptoms of angina pectoris, quality of life and compliance in women with coronary artery disease. Maturitas. 1998;28(3):235-42. [pmid: 9571599].
127 Klaiber E L, Broverman D M, Vogel W, et al. Individual differences in changes in mood and platelet monoamine oxidase (MAO) activity during hormonal replacement therapy in menopausal women. Psychoneuroendocrinology. 1996;21(7):575-92. [pmid: 9044441].
128 Gerdes L C, Sonnendecker E W, Polakow E S. Psychological changes effected by estrogen-progestogen and clonidine treatment in climacteric women. Am J Obstet Gynecol. 1982;142(1):98-104. [pmid: 6275706].
129 Thomson J, Oswald I. Effect of oestrogen on the sleep, mood, and anxiety of menopausal women. BMJ. 1977;2(6098):1317-9. [pmid: 338104].
130 Wheatley D. Hormone replacement therapy in post menopausal depression and the female climacteric. Curr Med Res Opin. 1977;4(SUP 3):37-45.
131 Wilklund I, Karlberg J, Mattsson L A. Quality of life of postmenopausal women on a regimen of transdermal estradiol therapy: a double-blind placebo-controlled study. Am J Obstet Gynecol. 1993;168:824-30. [pmid: 8456888].
132 Karlberg J, Mattsson L A, Wiklund I. A quality of life perspective on who benefits from estradiol replacement therapy. Acta Obstet Gynecol Scand. 1995;74(5):367-72. [pmid: 7778430].
133 Skarsgard C, Berg G E, Ekblad S, et al. Effects of estrogen therapy on well-being in postmenopausal women without vasomotor complaints. Maturitas. 2000;36(2):123-30. [pmid: 11006499].
134 Derman R J, Dawood M Y, Stone S. Quality of life during sequential hormone replacement therapy -- a placebo-controlled study. Int J Fertil Menopausal Stud. 1995;40(2):73-8. [pmid: 7599662].
135 Rebar R W, Trabal J, Mortola J. Low-dose esterified estrogens (0.3 mg/day): long-term and short-term effects on menopausal symptoms and quality of life in postmenopausal women. Climacteric. 2000;3(3):176-82. [pmid: 11910619].
136 Hilditch J R, Lewis J, Ross A H, et al. A comparison of the effects of oral conjugated equine estrogen and transdermal estradiol-17betacombined with an oral progestin on quality of life in postmenopausal women. Maturitas. 1996;24(3):177-84. [pmid: 8844631].
137 Wren B G, Champion S M, Willetts K, et al. Transdermal progesterone and its effect on vasomotor symptoms, blood lipid levels, bone metabolic markers, moods, and quality of life for postmenopausal women. Menopause. 2003;10(1):13-8. [pmid: 12544672].
138 Leonetti H B, Longo S, Anasti J N. Transdermal progesterone cream for vasomotor symptoms and postmenopausal bone loss. Obstet Gynaecol. 1999;94(2):225-8.
139 de Wit H, Schmitt L, Purdy R, et al. Effects of acute progesterone administration in healthy postmenopausal women and normally-cycling women. Psychoneuroendocrinology. 2001;26(7):697-710. [pmid: 11500251].
140 Morrison J C, Martin D C, Blair R A, et al. The use of medroxyprogesterone acetate for relief of climacteric symptoms. Am J Obstet Gynecol. 1980;138(1):99-104. [pmid: 7416212].
141 Schiff I, Tulchinsky D, Cramer D, et al. Oral medroxyprogesterone in the treatment of postmenopausal symptoms. JAMA. 1980;244(13):1443-5. [pmid: 6775094].
142 Lobo R A, Rosen R C, Yang H M, et al. Comparative effects of oral esterified estrogens with and without methyltestosterone on endocrine profiles and dimensions of sexual function in postmenopausal women with hypoactive sexual desire. Fertil Steril. 2003;79(6):1341-52. [pmid: 12798881].
143 Hickok L R, Toomey C, Speroff L. A comparison of esterified estrogens with and without methyltestosterone: effects on endometrial histology and serum lipoproteins in postmenopausal women. Obstet Gynaecol. 1993;82(6):919-24.
144 Shifren J L, Braunstein G D, Simon J A, et al. Transdermal testosterone treatment in women with impaired sexual function after oophorectomy. N Engl J Med. 2000;343(10):682-8. [pmid: 10974131].
145 Dobs A S, Nguyen T, Pace C, et al. Differential effects of oral estrogen versus oral estrogen-androgen replacement therapy on body composition in postmenopausal women. J Clin Endocrinol Metab. 2002;87(4):1509-16. [pmid: 11932273].
146 Barrett-Connor E, Young R, Notelovitz M, et al. A two-year, double-blind comparison of estrogen-androgen and conjugated estrogens in surgically menopausal women. Effects on bone mineral density, symptoms and lipid profiles. J Reprod Med. 1999;44(12):1012-20. [pmid: 10649811].
147 Raisz L G, Wiita B, Artis A, et al. Comparison of the effects of estrogen alone and estrogen plus androgen on biochemical markers of bone formation and resorption in postmenopausal women. J Clin Endocrinol Metab. 1996;81(1):37-43. [pmid: 8550780].
148 Watts N B, Notelovitz M, Timmons M C, et al. Comparison of oral estrogens and estrogens plus androgen on bone mineral density, menopausal symptoms, and lipid-lipoprotein profiles in surgical menopause. Obstet Gynaecol. 1995;85(4):529-37.
149 Simon J, Klaiber E, Wiita B, et al. Differential effects of estrogen-androgen and estrogen-only therapy on vasomotor symptoms, gonadotropin secretion, and endogenous androgen bioavailability in postmenopausal women. Menopause. 1999;6(2):138-46. [pmid: 10374221].
150 Floter A, Nathorst-Boos J, Carlstrom K, et al. Addition of testosterone to estrogen replacement therapy in oophorectomized women: effects on sexuality and well-being. Climacteric. 2002;5(4):357-65. [pmid: 12626215].
151 Penotti M, Sironi L, Cannata L, et al. Effects of androgen supplementation of hormone replacement therapy on the vascular reactivity of cerebral arteries. Fertil Steril. 2001;76(2):235-40. [pmid: 11476766].
152 Braunstein G. Testosterone patches for the treatment of low sexual desire in surgically menopausal women. Menopause. 2003;10:587. Abstract p-70.
153 Davis S, Rees M, Ribot C, et al. Efficacy and safety of testosterone patches for the treatment of low sexual desire in surgically menopausal women.[abstract]. Fertil Steril. 2003;80:S76.
154 Barnhart K T, Freeman E, Grisso J A, et al. The effect of dehydroepiandrosterone supplementation to symptomatic perimenopausal women on serum endocrine profiles, lipid parameters, and health-related quality of life. J Clin Endocrinol Metab. 1999;84(11):3896-902. [pmid: 10566625].
155 Stomati M, Rubino S, Spinetti A, et al. Endocrine, neuroendocrine and behavioral effects of oral dehydroepiandrosterone sulfate supplementation in postmenopausal women. Gynecol Endocrinol. 1999;13(1):15-25. [pmid: 10368794].
156 Lam P M, Cheung G W, Shek D T, et al. A randomized, placebo-controlled, crossover study of tibolone (Livial) on menopause symptoms, psychological well-being, and dyadic relationship of postmenopausal Chinese women and their spouses. Menopause. 2004;11(4):416-22. [pmid: 15243279].
157 Meeuwsen I B, Samson M M, Duursma S A, et al. The influence of tibolone on quality of life in postmenopausal women. Maturitas. 2002;41(1):35-43. [pmid: 11809341].
158 Winkler U H, Altkemper R, Kwee B, et al. Effects of tibolone and continuous combined hormone replacement therapy on parameters in the clotting cascade: a multicenter, double-blind, randomized study. Fertil Steril. 2000;74(1):10-9. [pmid: 10899490].
159 Hammar M, Christau S, Nathorst-Boos J, et al. A double-blind, randomised trial comparing the effects of tibolone and continuous combined hormone replacement therapy in postmenopausal women with menopausal symptoms. Br J Obstet Gynaecol. 1998;105(8):904-11. [pmid: 9746385].
160 Huber J, Palacios S, Berglund L, et al. Effects of tibolone and continuous combined hormone replacement therapy on bleeding rates, quality of life and tolerability in postmenopausal women. BJOG. 2002;109(8):886-93. [pmid: 12197367].
161 Lloyd G, McGing E, Cooper A, et al. A randomised placebo controlled trial of the effects of tibolone on blood pressure and lipids in hypertensive women. J Hum Hypertens. 2000;14(2):99-104. [pmid: 10723115].
162 Ross L A, Alder E M, Cawood E H, et al. Psychological effects of hormone replacement therapy: a comparison of tibolone and a sequential estrogen therapy. J Psychosom Obstet Gynaecol. 1999;20(2):88-96. [pmid: 10422040].
163 Baracat E C, Barbosa I C, Giordano M G, et al. A randomized, open-label study of conjugated equine estrogens plus medroxyprogesterone acetate versus tibolone: effects on symptom control, bleeding pattern, lipid profile and tolerability. Climacteric. 2002;5(1):60-9. [pmid: 11974560].
164 Benedek-Jaszmann L J. Long-term placebo-controlled efficacy and safety study of Org OD 14 in climacteric women. Maturitas. 1987;Suppl(1):25-33. [pmid: 3306289].
165 De Aloysio D, Fabiani A G, Mauloni M, et al. Use of Org OD 14 for the treatment of climacteric complaints. Maturitas. 1987;Suppl(1):49-65. [pmid: 3306291].
166 Egarter C, Huber J, Leikermoser R, et al. Tibolone versus conjugated estrogens and sequential progestogen in the treatment of climacteric complaints. Maturitas. 1996;23(1):55-62. [pmid: 8861087].
167 Hudita D, Posea C, Ceausu I, et al. Efficacy and safety of oral tibolone 1.25 or 2.5 mg/day vs. placebo in postmenopausal women. Eur Rev Med Pharmacol Sci. 2003;7(5):117-25. [pmid: 15214586].
168 Landgren M B, Bennink H J, Helmond F A, et al. Dose-response analysis of effects of tibolone on climacteric symptoms. BJOG. 2002;109(10):1109-14. [pmid: 12387462].
169 Mendoza N, Suarez A M, Alamo F, et al. Lipid effects, effectiveness and acceptability of tibolone versus transdermic 17 beta-estradiol for hormonal replacement therapy in women with surgical menopause. Maturitas. 2000;37(1):37-43. [pmid: 11099872].
170 Mendoza N, Pison J A, Fernandez M, et al. Prospective, randomised study with three HRT regimens in postmenopausal women with an intact uterus. Maturitas. 2002;41(4):289-98. [pmid: 12034516].
171 Nathorst-Boos J, Hammar M. Effect on sexual life--a comparison between tibolone and a continuous estradiol-norethisterone acetate regimen. Maturitas. 1997;26(1):15-20. [pmid: 9032742].
172 Palacios S, Menendez C, Jurado A R, et al. Changes in sex behaviour after menopause: effects of tibolone. Maturitas. 1995;22(2):155-61. [pmid: 8538485].
173 Volpe A, Facchinetti F, Grasso A, et al. Benefits and risks of different hormonal replacement therapies in post-menopausal women. Maturitas. 1986;8(4):327-34. [pmid: 3033444].
174 Wu M H, Pan H A, Wang S T, et al. Quality of life and sexuality changes in postmenopausal women receiving tibolone therapy. Climacteric. 2001;4(4):314-9. [pmid: 11770188].
175 Yang T S, Tsan S H, Chen C R, et al. Evaluation of conjugated estrogen plus medroxyprogesterone acetate versus tibolone in early postmenopausal Chinese women. Chung Hua i Hsueh Tsa Chih - Chin Med J. 1999;62(5):308-15.
176 Dansuk R, Unal O, Turan C. Evaluation of the effect of tibolone and transdermal estradiol on triglyceride level in hypertriglyceridemic and normohypertriglyceridemic postmenopausal women (abstract). Climacteric 2002;5(Supplement 1).
177 Johannes E, Coelingh Bennink H, Engelen S, et al. Tibolone: Dose-Response Analysis of Effects on Climacteric Symptoms. Acta Obstet Gynecol Scand Suppl. 1997;167:13. Abstract FC801.6.
178 Kokcu A, Cetinkaya M B, Yanik F, et al. The effects of tibolone and combined oestrogen plus progesterone therapy on the sexual performance of post-menopausal women. Hum Reprod. 2000;15(A1):188. Abstract P233.
179 Yang T S, Ng H T. Preliminary Report of the Effects of HRT on the Chinese Early Postmenopausal Women: Conjugated Estrogen Plus Medroxyprogesterone Versus Tibolone. Acta Obstet Gynecol Scand Suppl. 1997;167:58. Abstract P86.16.
180 Berning B, van Kuijk C, Bennink H J, et al. Absent correlation between vaginal bleeding and oestradiol levels or endometrial morphology during tibolone use in early postmenopausal women. Maturitas. 2000;35(1):81-8. [pmid: 10802404].
181 Stearns V, Beebe K L, Iyengar M, et al. Paroxetine controlled release in the treatment of menopausal hot flashes: a randomized controlled trial. JAMA. 2003;289(21):2827-34. [pmid: 12783913].
182 Wesel S, Bourguignon R P, Bosuma W B. Veralipride versus conjugated oestrogens: a double-blind study in the management of menopausal hot flushes. Curr Med Res Opin. 1984;8(10):696-700. [pmid: 6327190].
183 Evans M L, Pritts E, Vittinghoff E, et al. Management of postmenopausal hot flashes with Venlafaxine Hydrochloride: A randomized, controlled trial. Obstet Gynaecol. 2005;105(1):161-66.
184 Melis G B, Gambacciani M, Cagnacci A, et al. Effects of the dopamine antagonist veralipride on hot flushes and luteinizing hormone secretion in postmenopausal women. Obstet Gynaecol. 1988;72(5):688-92.
185 Zichella L, Falaschi P, Fioretti P, et al. Effects of different dopamine agonists and antagonists on post-menopausal hot flushes. Maturitas. 1986;8(3):229-37. [pmid: 3784919].
186 David A, Don R, Tajchner G, et al. Veralipride: alternative antidopaminergic treatment for menopausal symptoms. Am J Obstet Gynecol. 1988;158(5):1107-15. [pmid: 2967034].
187 Limouzin-Lamothe M A, Mairon N, Joyce C R, et al. Quality of life after the menopause: influence of hormonal replacement therapy. Am J Obstet Gynecol. 1994;170(2):618-24. [pmid: 7509570].
188 Tarim E, Bagis T, Kilicdag E, et al. Moclobemide in the treatment of hot flashes in postmenopausal women. Adv Ther. 2002;19(6):258-65. [pmid: 12665046].
189 Clayden J R, Bell J W, Pollard P. Menopausal flushing: double-blind trial of a non-hormonal medication. British Medical Journal. 1974;1(905):409-12. [pmid: 4593554].
190 Bolli P, Simpson F O. Clonidine in menopausal flushing: a double-blind trial. New Zealand Medical Journal. 1975;82(548):196-7. [pmid: 1105267].
191 Lindsay R, Hart D M. Failure of response of menopausal vasomotor symptoms to clonidine. Maturitas. 1978;1(1):21-5. [pmid: 386045].
192 Salmi T, Punnonen R. Clonidine in the treatment of menopausal symptoms. Int J Gynaecol Obstet. 1979;16(5):422-6. [pmid: 35414].
193 Edington R F, Chagnon J P, Steinberg W M. Clonidine (Dixarit) for menopausal flushing. CMAJ. 1980;123(1):23-6. [pmid: 6998552].
194 Wren B G, Brown L B. A double-blind trial with clonidine and a placebo to treat hot flushes. Med J Aust. 1986;144(7):369-70. [pmid: 3515137].
195 Nappi C, Petraglia F, de Chiara B M, et al. The effect of various drugs with neuroendocrine activity and transdermal estradiol on plasma gonadotropin concentrations after ovariectomy in reproductive-aged women. Acta Obstet Gynecol Scand. 1991;70(6):435-9. [pmid: 1763606].
196 Sonnendecker E W, Polakow E S. Comparison of oestrogen-progestogen with clonidine in the climacteric syndrome. S Afr Med J. 1980;58(19):753-56. [pmid: 6252641].
197 Nagamani M, Kelver M E, Smith E R. Treatment of menopausal hot flashes with transdermal administration of clonidine. Am J Obstet Gynecol. 1987;156(3):561-5. [pmid: 3826200].
198 Guttuso T Jr, Kurlan R, McDermott M P, et al. Gabapentin's effects on hot flashes in postmenopausal women: a randomized controlled trial. Obstet Gynaecol. 2003;101(2):337-45.
199 Andersen O, Engebretsen T, Solberg V M, et al. alpha-Methyldopa for climacteric hot flushes. A double-blind, randomized, cross-over study. Acta Obstet Gynecol Scand. 1986;65(5):405-9. [pmid: 3535358].
200 Hammond M G, Hatley L, Talbert L M. A double blind study to evaluate the effect of methyldopa on menopausal vasomotor flushes. J Clin Endocrinol Metab. 1984;58(6):1158-60. [pmid: 6725512].
201 Nesheim B I, Saetre T. Reduction of menopausal hot flushes by methyldopa. A double blind crossover trial. Eur J Clin Pharmacol. 1981;20(6):413-6. [pmid: 7026262].
202 Bergmans M G, Merkus J M, Corbey R S, et al. Effect of Bellergal Retard on climacteric complaints: a double-blind, placebo-controlled study. Maturitas. 1987;9(3):227-34. [pmid: 3323851].
203 Albertazzi P, Pansini F, Bonaccorsi G, et al. The effect of dietary soy supplementation on hot flushes. Obstet Gynaecol. 1998;91(1):6-11.
204 Albertazzi P, Pansini F, Bottazzi M, et al. Dietary soy supplementation and phytoestrogen levels. Obstet Gynaecol. 1999;94(2):229-31.
205 Balk J L, Whiteside D A, Naus G, et al. A pilot study of the effects of phytoestrogen supplementation on postmenopausal endometrium. J Soc Gynecol Investig. 2002;9(4):238-42.
206 Burke G L, Legault C, Anthony M, et al. Soy protein and isoflavone effects on vasomotor symptoms in peri- and postmenopausal women: the Soy Estrogen Alternative Study. Menopause. 2003;10(2):147-53. [pmid: 12627040].
207 Han K K, Soares J M Jr, Haidar M A, et al. Benefits of soy isoflavone therapeutic regimen on menopausal symptoms. Obstet Gynaecol. 2002;99(3):389-94.
208 Dalais F S, Rice G E, Wahlqvist M L, et al. Effects of dietary phytoestrogens in postmenopausal women. Climacteric. 1998;1(2):124-9. [pmid: 11907915].
209 Murkies A L, Lombard C, Strauss B J, et al. Dietary flour supplementation decreases post-menopausal hot flushes: effect of soy and wheat. Maturitas. 1995;21(3):189-95. [pmid: 7616867].
210 Penotti M, Fabio E, Modena A B, et al. Effect of soy-derived isoflavones on hot flushes, endometrial thickness, and the pulsatility index of the uterine and cerebral arteries. Fertil Steril. 2003;79(5):1112-7. [pmid: 12738504].
211 St. Germain A, Peterson C T, Robinson J G, et al. Isoflavone-rich or isoflavone-poor soy protein does not reduce menopausal symptoms during 24 weeks of treatment. Menopause. 2001;8(1):17-26. [pmid: 11201510].
212 Knight D C, Howes J B, Eden J A, et al. Effects on menopausal symptoms and acceptability of isoflavone-containing soy powder dietary supplementation. Climacteric. 2001;4(1):13-8. [pmid: 11379373].
213 Washburn S, Burke G L, Morgan T, et al. Effect of soy protein supplementation on serum lipoproteins, blood pressure, and menopausal symptoms in perimenopausal women. Menopause. 1999;6(1):7-13. [pmid: 10100174].
214 Kritz-Silverstein D, Von Muhlen D, Barrett-Connor E, et al. Isoflavones and cognitive function in older women: the SOy and Postmenopausal Health In Aging (SOPHIA) Study. Menopause. 2003;10(3):196-202. [pmid: 12792289].
215 Duffy R, Wiseman H, File S E. Improved cognitive function in postmenopausal women after 12 weeks of consumption of a soya extract containing isoflavones. Pharmacol Biochem Behav. 2003;75(3):721-9. [pmid: 12895690].
216 Faure E D, Chantre P, Mares P. Effects of a standardized soy extract on hot flushes: a multicenter, double-blind, randomized, placebo-controlled study. Menopause. 2002;9(5):329-34. [pmid: 12218721].
217 Scambia G, Mango D, Signorile P G, et al. Clinical effects of a standardized soy extract in postmenopausal women: a pilot study. Menopause. 2000;7(2):105-11. [pmid: 10746892].
218 Upmalis D H, Lobo R, Bradley L, et al. Vasomotor symptom relief by soy isoflavone extract tablets in postmenopausal women: a multicenter, double-blind, randomized, placebo-controlled study. Menopause. 2000;7(4):236-42. [pmid: 10914616].
219 Brzezinski AAHSRRASATVS, et al. Short term effects of phytoestrogen-rich diet on postmenopausal women. Menopause 1997;4(2):89–94.
220 Carranza-Lira S, Barahona O F, Ramos D, et al. Changes in symptoms, lipid and hormone levels after the administration of a cream with phytoestrogens in the Climacteric--preliminary report. Int J Fertil Womens Med. 2001;46(6):296-9. [pmid: 11795688].
221 Crisafulli A, Marini H, Bitto A, et al. Effects of genistein on hot flushes in early postmenopausal women: a randomized, double-blind EPT- and placebo-controlled study. Menopause. 2004;11(4):400-4. [pmid: 15243277].
222 Komesaroff P A, Black C V, Cable V, et al. Effects of wild yam extract on menopausal symptoms, lipids and sex hormones in healthy menopausal women. Climacteric. 2001;4(2):144-50. [pmid: 11428178].
223 Sammartino A, Di Carlo C, Mandato V D, et al. Effects of genistein on the endometrium: ultrasonographic evaluation. Gynecol Endocrinol. 2003;17(1):45-9. [pmid: 12724018].
224 Russo R, Corosu R. The clinical use of a preparation based on phyto-oestrogens in the treatment of menopausal disorders. Acta Biomed Ateneo Parmense. 2003;74(3):137-43. [pmid: 15055018].
225 Lewis J E. The effect of dietary soy and flax on menopause quality of life. Menopause. 2002;9(6):P-37.
226 Hyde LW. Relaxation training and biofeedback conditioning and the relief of menopausal symptoms: Florida Inst of Technology, 1.; 1983.
227 Boblitz N, Freudenstein J. Fixed combined herbal drug for therapy of menopausal complaints - a placebo-controlled randomized trial. Focus on Alternative and Complementary Therapies. 2003;8(4):481-2.
228 Yoles I. Phytoestrogens: A time-tested solution for menopausal symptoms revisited (abstract). Obstet Gynaecol. 2002;99:S58.
229 Rao A, Steels E, Seipel T. The effect of a natural transdermal preparation in the treatment of symptoms associated with menopause. Focus on Alternative and Complementary Therapies. 2003;8(4):531-2.
230 Valente M. Phytoestrogens: a real alternative to HRT in menopause? (abstract). Gynecol Endocrinol. 2000;14(Supplement 2):121.
231 Leonetti H B, Anasti J N. Natural progesterone cream improves the vasomotor symptoms of the menopause. Fertil Steril. 1998;70(3):S284.
232 Hochanadel G. Soy isoflavones (phytoestrogens) in the treatment of the cognitive and somatic symptoms of menopause. Proceedings of the 47th Annual Meeting of the Pacific Coast Reproductive Society, Carlsbad, CA, April 16, 1999. 1999.
233 Unfer V, Casini M L, Costabile L, et al. Endometrial effects of long-term treatment with phytoestrogens: a randomized double-blind, placebo-controlled study. Fertil Steril. 2004;82(1):145-48. [pmid: 15237003].
234 Cohen S M, Rousseau M E, Carey B L. Can acupuncture ease the symptoms of menopause?. Holist Nurs Pract. 2003;17(6):295-9. [pmid: 14650571].
235 Sandberg M, Wijma K, Wyon Y, et al. Effects of electro-acupuncture on psychological distress in postmenopausal women. Complement Ther Med. 2002;10(3):161-9. [pmid: 12568145].
236 Wyon Y, Lindgren R, Lundeberg T, et al. Effects of acupuncture on climacteric vasomotor symptoms, quality of life, and urinary excretion of neuropeptides among postmenopausal women. Menopause. 1995;2(1):3-12.
237 Chen J K. Menopause: Western and Traditional Chinese Medicine Perspectives, Part II. Acupuncture Today. 2002;3(5):22-23.
238 Davis S R, Briganti E M, Chen R Q, et al. The effects of Chinese medicinal herbs on postmenopausal vasomotor symptoms of Australian women. A randomised controlled trial. Med J Aust. 2001;174(2):68-71. [pmid: 11245505].
239 Hartley D E, Heinze L, Elsabagh S, et al. Effects on cognition and mood in postmenopausal women of 1-week treatment with Ginkgo biloba. Pharmacol Biochem Behav. 2003;75(3):711-20. [pmid: 12895689].
240 Hirata J D, Swiersz L M, Zell B, et al. Does dong quai have estrogenic effects in postmenopausal women? A double-blind, placebo-controlled trial. Fertil Steril. 1997;68(6):981-6. [pmid: 9418683].
241 Wiklund I K, Mattsson L A, Lindgren R, et al. Effects of a standardized ginseng extract on quality of life and physiological parameters in symptomatic postmenopausal women: a double-blind, placebo-controlled trial. Swedish Alternative Medicine Group. Int J Clin Pharmacol Res. 1999;19(3):89-99. [pmid: 10761538].
242 Woo J, Lau E, Ho S C, et al. Comparison of Pueraria lobata with hormone replacement therapy in treating the adverse health consequences of menopause. Menopause. 2003;10(4):352-61. [pmid: 12851519].
243 Atkinson C, Warren RM, Sala E, et al. Red-clover-derived isoflavones and mammographic breast density: a double-blind, randomized, placebo-controlled trial [ISRCTN42940165]. Breast Cancer Research 2004;6(3).
244 Baber R J, Templeman C, Morton T, et al. Randomized placebo-controlled trial of an isoflavone supplement and menopausal symptoms in women. Climacteric. 1999;2(2):85-92. [pmid: 11910672].
245 Jeri A R. The use of an isoflavone supplement to relieve hot flashes. Female Patient. 2002;27:35-7.
246 Knight D C, Howes J B, Eden J A. The effect of Promensil, an isoflavone extract, on menopausal symptoms. Climacteric. 1999;2(2):79-84. [pmid: 11910671].
247 Tice J A, Ettinger B, Ensrud K, et al. Phytoestrogen supplements for the treatment of hot flashes: the Isoflavone Clover Extract (ICE) Study: a randomized controlled trial. JAMA. 2003;290(2):207-14. [pmid: 12851275].
248 van de Weijer P H, Barentsen R. Isoflavones from red clover (Promensil) significantly reduce menopausal hot flush symptoms compared with placebo. Maturitas. 2002;42(3):187-93. [pmid: 12161042].
249 Wuttke W, Seidlova-Wuttke D, Gorkow C. The Cimicifuga preparation BNO 1055 vs. conjugated estrogens in a double-blind placebo-controlled study: effects on menopause symptoms and bone markers. Maturitas. 2003;44(Suppl 1):S67-77. [pmid: 12609561].
250 Hudson T S, Standish L, Breed C, et al. Clinical and endocrinological effects of a menopausal botanical formula. Journal of Naturopathic Medicine Issue. 1998;7:73-7.
251 Bellipanni G, Bianchi P, Pierpaoli W, et al. Effects of melatonin in perimenopausal and menopausal women: a randomized and placebo controlled study. Exp Gerontol. 2001;36(2):297-310. [pmid: 11226744].
252 Blatt M H G, Wiesbader H, Kupperman H S. Vitamin E and climacteric syndrome: failure of effective control as measured by menopausal index. Arch Intern Med. 1953;91:792-6.
253 Cagnacci A, Arangino S, Renzi A, et al. Kava-Kava administration reduces anxiety in perimenopausal women. Maturitas. 2003;44(2):103-9. [pmid: 12590005].
254 Chenoy R, Hussain S, Tayob Y, et al. Effect of oral gamolenic acid from evening primrose oil on menopausal flushing. BMJ. 1994;308(6927):501-3. [pmid: 8136666].
255 Makkonen M, Simpanen A L, Saarikoski S, et al. Endocrine and metabolic effects of guar gum in menopausal women. Gynecol Endocrinol. 1993;7(2):135-41. [pmid: 8213228].
256 Bygdeman M, Swahn M L. Replens versus dienoestrol cream in the symptomatic treatment of vaginal atrophy in postmenopausal women. Maturitas. 1996;23(3):259-63. [pmid: 8794418].
257 Nachtigall L E. Comparative study: Replens versus local estrogen in menopausal women. Fertil Steril. 1994;61(1):178-80. [pmid: 8293835].
258 Rachev E, Nalbansky B, Kolarov G, et al. Efficacy and safety of phospholipid liposomes in the treatment of neuropsychological disorders associated with the menopause: a double-blind, randomised, placebo-controlled study. Curr Med Res Opin. 2001;17(2):105-10. [pmid: 11759177].
259 Salmaggi P, Bressa G M, Nicchia G, et al. Double-blind, placebo-controlled study of S-adenosyl-L-methionine in depressed postmenopausal women. Psychother Psychosom. 1993;59(1):34-40. [pmid: 8441793].
260 Cleary C, Fox J P. Menopausal symptoms: an osteopathic investigation. Complement Ther Med. 1994;2(4):181-6.
261 Williamson J, White A, Hart A, et al. Randomised controlled trial of reflexology for menopausal symptoms. BJOG. 2002;109(9):1050-5. [pmid: 12269681].
262 Nassef A, Mostafa M, Khattar N, et al. Role of phytoestrogens in managing menopausal symptoms among Egyptian women (abstract). Climacteric. 2002;5(Supplement 1):105. [pmid: 12051104].
263 Thompson Coon J, Pittler M, Ernst E. The role of red clover (Trifolium pratense) isoflavones in women's reproductive health: a systematic review and meta-analysis of randomized clinical trials. Focus on Alternative and Complementary Therapies. 2003;8(4):544.
264 Wyon Y, Wijma K, Nedstrand E, et al. A comparison of acupuncture and oral estradiol treatment of vasomotor symptoms in postmenopausal women. Climacteric. 2004;7(2):153-64. [pmid: 15497904].
265 Aiello E J, Yasui Y, Tworoger S S, et al. Effect of a yearlong, moderate-intensity exercise intervention on the occurrence and severity of menopause symptoms in postmenopausal women. Menopause. 2004;11(4):382-8. [pmid: 15243275].
266 Lindh-Astrand L, Nedstrand E, Wyon Y, et al. Vasomotor symptoms and quality of life in previously sedentary postmenopausal women randomised to physical activity or estrogen therapy. Maturitas. 2004;48(2):97-105. [pmid: 15172083].
267 Teoman N, Ozcan A, Acar B. The effect of exercise on physical fitness and quality of life in postmenopausal women. Maturitas. 2004;47(1):71-7. [pmid: 14706768].
268 Freedman R R, Woodward S, Brown B, et al. Biochemical and thermoregulatory effects of behavioral treatment for menopausal hot flashes. Menopause. 1995;2(4):211-18.
269 Irvin J H, Domar A D, Clark C, et al. The effects of relaxation response training on menopausal symptoms. J Psychosom Obstet Gynaecol. 1996;17(4):202-7. [pmid: 8997686].
270 Germaine L M, Freedman R R. Behavioral treatment of menopausal hot flashes: evaluation by objective methods. J Consult Clin Psychol. 1984;52(6):1072-9. [pmid: 6394631].
271 Rankin M. Effect of low frequency sound on menopausal symptoms. J Holist Nurs. 1989;7(1):34-41.
272 Hunter M, O'Dea I. An evaluation of a health education intervention for mid-aged women: five year follow-up of effects upon knowledge, impact of menopause and health. Patient Educ Couns. 1999;38(3):249-55. [pmid: 10865690].
273 Manson J, Hsia J, Johnson K, et al. Estrogen plus progestin and the risk of coronary heart disease. N Engl J Med. 2003;349(6):523-34. [pmid: 12904517].
274 Wassertheil-Smoller S, Hendrix S, Limacher M, et al. Effect of estrogen plus progestin on stroke in postmenopausal women: The Women's Health Initiative: A randomized trial. JAMA. 2003;289(20):2673-84. [pmid: 12771114].
275 Barton D L, Loprinzi C L, Quella S K, et al. Prospective evaluation of vitamin E for hot flashes in breast cancer survivors. J Clin Oncol. 1998;16:495-500. [pmid: 9469333].
276 Jacobson J S, Troxel A B, Evans J, et al. Randomized trial of black cohosh for the treatment of hot flashes among women with a history of breast cancer. J Clin Oncol. 2001;19(10):2739-45. [pmid: 11352967].
277 Quella S K, Loprinzi C L, Sloan J A, et al. Long term use of megestrol acetate by cancer survivors for the treatment of breast cancer. Cancer. 2000;82(9):1784-88. [pmid: 9576302].
278 Van Patten C L, Olivotto I A, Chambers G K, et al. Effect of soy phytoestrogens on hot flashes in postmenopausal women with breast cancer: a randomized, controlled clinical trial. J Clin Oncol. 2002;20(6):1449-55. [pmid: 11896091].
279 Nikander E, Kilkkinen A, Metsa-Heikkila M, et al. A randomized placebo-controlled crossover trial with phytoestrogens in treatment of menopause in breast cancer patients. Obstet Gynecol. 2003;101(6):1213-20. [pmid: 12798527].
280 Loprinzi C L, Michalak J C, Quella S K, et al. Megestrol acetate for the prevention of hot flashes. N Engl J Med. 1994;331(6):347-52. [pmid: 8028614].
281 Loprinzi C L, Abu-Ghazaleh S, Sloan J A, et al. Phase III randomized double-blind study to evaluate the efficacy of a polycarbophil-based vaginal moisturizer in women with breast cancer. J Clin Oncol. 1997;15:969-73. [pmid: 9060535].
282 Loprinzi C L, Kugler J W, Sloan J A, et al. Venlafaxine in management of hot flashes in survivors of breast cancer: a randomised controlled trial. Lancet. 2000;356(9247):2059-63. [pmid: 11145492].
283 Loprinzi C L, Sloan J A, Perez E A, et al. Phase III evaluation of fluoxetine for treatment of hot flashes. J Clin Oncol. 2002;20(6):1578-83. [pmid: 11896107].
284 Goldberg R M, Loprinzi C L, O'Fallon J R, et al. Transdermal clonidine for ameliorating tamoxifen-induced hot flashes. J Clin Oncol. 1994;12(1):155-8. [pmid: 8270972].
285 Pandya K J, Raubertas R F, Flynn P J, et al. Oral clonidine in postmenopausal patients with breast cancer experiencing tamoxifen-induced hot flashes: a University of Rochester Cancer Center Community Clinical Oncology Program study. Ann Intern Med. 2000;132(10):788-93. [pmid: 10819701].
286 Hernandez Munoz G, Pluchino S. Cimicifuga racemosa for the treatment of hot flushes in women surviving breast cancer. Maturitas. 2003;44(Suppl 1):S59-65. [pmid: 12609560].
287 Ganz P A, Greendale G A, Petersen L, et al. Managing menopausal symptoms in breast cancer survivors: results of a randomized controlled trial. J Natl Cancer Inst. 2000;92(13):1054-64. [pmid: 10880548].
288 Secreto G, Chiechi L M, Amadori A, et al. Soy isoflavones and melatonin for the relief of climacteric symptoms: a multicenter, double-blind, randomized study. Maturitas. 2004;47(1):11-20. [pmid: 14706761].
289 Carpenter J S, Johnson D, Wagner L, et al. Hot flashes and related outcomes in breast cancer survivors and matched comparison women. Oncol Nurs Forum. 2002;29(3):E16-25. [pmid: 11979290].