# Acknowledgments

This systematic evidence review was developed for the National Institutes of Health State-of-the-Science Conference on Management of Menopause-Related Symptoms. It was supported by the Office of Medical Applications of Research (OMAR) at the National Institutes of Health and the Agency for Healthcare Research and Quality (AHRQ), and the investigators acknowledge the contributions of Carmen Kelly, PharmD, Task Order Officer, AHRQ, Lata Nerurka, PhD, OMAR, and Carol Mangione, MD, MSPH, Chair of the State-of-the-Science Conference Panel. The Women's Health Fellowship at the Portland Veterans Administration Medical Center provided support for Kimberly Vesco, MD. Investigators thank the Technical Expert Panel members providing guidance for the project, expert reviewers commenting on the draft version, Andrew Hamilton, MLS, MS for conducting the literature searches, and Laurie Huffman, MS, and Korene Maceo, BS, for assisting with the project.