# Discussion

Based on review of currently available cohort and cross-sectional population studies, vasomotor symptoms and vaginal dryness are symptoms most consistently associated with the menopausal transition. Sleep disturbance, somatic complaints, urinary complaints, sexual dysfunction, mood, and quality of life are inconsistently associated. No studies provide data on cognition and uterine bleeding problems, onset, duration, and severity of specific symptoms, or conclusive data on the influence of race/ethnicity, age of onset of menopause, BMI, oophorectomy status, presence of depression, or smoking status. The literature is limited by differences in how symptoms are defined and measured, variability of study populations, and incompatibility of data preventing direct comparisons between studies or pooling of results. Future research using standard and validated measures and uniform definitions for a more comprehensive array of symptoms would improve knowledge of these associations.

Trials of therapy are conclusive only for estrogen and its use in treating vasomotor and urogenital symptoms, although other therapies may prove effective if further studied. Undertaking trials to treat symptoms that are not clearly associated with the menopausal transition would not be useful. Trials are limited in many ways including use of highly selected small samples of women; short durations; inadequate reporting of loss to follow up, maintenance of comparable groups, contamination, methods of analysis, and adverse events; use of dissimilar measures and outcomes that are often not standardized or validated; unclear inclusion and exclusion criteria; and industry sponsorship. Future research addressing these deficiencies, as outlined in Key Question 5, would guide patient and clinician decision making when managing menopause related symptoms.

The evidence review is limited in several ways. For Key Questions 1 and 2, literature searches focused on population studies of women undergoing the menopausal transition reporting symptoms, and did not include epidemiologic or biologically-based etiologic studies. In addition, studies that may not have been identified by searches include those in which menopause was not a primary focus of the study, but a predictor variable included in a multivariable model evaluating the outcome or symptom of interest. Studies potentially not identified would be those that identified no association between menopausal stage and the outcome of interest. Studies with a positive association would probably have reported it in the abstract and be identified by the searches. Also, the review was limited to English-language randomized controlled trials of therapies. Exploratory studies of agents may provide contributory data that were not included in this report.