# Results

To address Key Questions 1 and 2, 6,342 abstracts were reviewed to identify relevant studies evaluating menopause related symptoms and their associations with the menopausal transition. The review focused on prospective studies of cohorts of midlife women transitioning through the stages of menopause. Forty-nine studies conducted among 14 cohorts met inclusion criteria. Seven cohorts were based in the U.S. (Massachusetts Women's Health Study, ^20–25^ Seattle Midlife Women's Health Study,^26–28^ Ohio Midlife Women's Study,^29^ National Health Examination Follow-up Study [NHANES],^30^ Study of Women's Health Across the Nation [SWAN],^31–39^ University of Minnesota/Tremin Trust Longitudinal Study [includes a small subset from other countries],^40^ and Pennsylvania Ovarian Aging Study^41,^ ^42^). Seven cohorts were based outside the U.S. (Gothenburg, Sweden,^43–45^ Australian Longitudinal Study on Women's Health,^46,^ ^47^ Medical Research Council [MRC], U.K.,^48–51^ Melbourne Women's Midlife Health Project, Australia, ^52–62^ Manitoba Project on Women and Their Health in the Middle Years, Canada,^63^ Copenhagen, Denmark,^64–66^ and Eindhoven, Netherlands.^67,^ ^68^). Cohorts are described in Table 2, results are listed by symptoms in Table 3, and full details are provided in Appendix 6-1.

Table 2 Descriptions of cohort studies

Cohort | Description | Number of publications included in evidence review
Australian Longitudinal Study on Women's Health | 8,236 Australian women 45 to 50 years old in 1996. | 2^46,^ ^47^
Copenhagen | 630 women 40 years old in 1976 selected from 4 municipalities and served by one hospital in Copenhagen, Denmark. Women using postmenopausal hormone therapy or who underwent premature or surgical menopause were excluded. | 3^64–66^
Eindhoven | 8,503 women recruited based on responses to an osteoporosis screening study in Eindhoven, Netherlands. Women were excluded if non-Dutch White, had hysterectomy with or without oophorectomy, had bilateral oophorectomy, are using postmenopausal hormone therapy, or were noncompliant with one or more items in the questionnaire. | 2^67,^ ^68^
Gothenburg | 1,462 women 38 to 60 years old randomly selected in 1968-69 and followed for over 25 years in Gothenburg, Sweden. Measures were assessed through periodic medical exams and interviews. | 3^43–45^
Manitoba Project on Women and Their Health in the Middle Years | A cross-sectional and longitudinal cohort study that enrolled 2,500 women aged 40–59 years old from the general population of Manitoba, Canada. | 1^63^
Massachusetts Women's Health Study | 2,500 premenopausal women from Massachusetts, U.S. | 6^20–25^
Medical Research Council (MRC) National Survey for Health and Development | 1,572 women identified from a socially stratified sample of all births in March 1943 in Britain. | 4^48–51^
Melbourne Women's Midlife Health Project | Cross-sectional and longitudinal, community-based cohort that enrolled 2,000 women 45 to 55 years old from Melbourne, Australia. Longitudinal follow up of 492 women has been ongoing since 1991. The study assesses women's health during midlife and the menopause including well being, sexuality, symptoms, and bone density and their relationship to a range of variables including hormones, age, stress, lifestyle, and other health experiences. | 11^52–62^
Minnesota/Tremin Trust Longitudinal Research Program on Women's Health | Longitudinal study that initially consisted of 2,350 University of Minnesota women. Between 1961-1963, a second group of 1,600 women was added, and in 1965, a third group of 1,000 native Alaskan women were added. Women in the study range from teens to mid-nineties and represent fifty states and twenty-five foreign countries. | 1^40^
National Health Examination Follow-up Study | Sample of 3,049 U.S. women 40 to 60 years old from the National Health and Nutrition Examination Survey (NHANES). | 1^30^
Ohio Midlife Women's Study | 208 women 40 to 60 years old, recruited with advertisements from a community in Ohio, U.S. Cohort includes 57% Caucasian, 43% African-American women. | 1^29^
Pennsylvania Ovarian Aging Study | Population-based cohort of 436 women from Philadelphia County, Pennsylvania, 35–47 years old at baseline including 50% African American, 50% Caucasian. Ongoing longitudinal study. | 2^41,^ ^42^
Seattle Midlife Women's Health Study | 11,222 women from within Seattle, U.S. census tracts, 35 to 55 years old, including multiple ethnicities and income levels and followed for 3 years. All women had active menstrual periods at baseline and were excluded if pregnant, using postmenopausal hormones, or non-English reading/speaking. | 3^26–28^
Study of Women's Health Across the Nation (SWAN) | U.S., community-based, multisite cross-sectional and longitudinal cohort study that enrolled 16,065 women 40 to 55 years old. Longitudinal follow up of 3,306 women has been ongoing since 1995. The goal of the study is to describe the chronology of the biological and psychosocial characteristics of the menopausal transition and its effects on health and risk factors for age-related chronic diseases. | 8^31,^ ^32–39^

Table 3 Results of cohort studies of menopause related symptoms

| | | | | | | Modifiers
Study, year | Cohort | Population | N | Symptom | Associated with change in menopausal stage? | Direction of change with transition | Age at onset | Body mass index | Race/ethnicity | Smoking | Depression | Surgical menopause | Quality rating
Vasomotor symptoms
Brown, 2002^46^ | Australian Longitudinal Study on Women's Health | Mid-age (45–50 years) cohort selected from 41,500 Australian women with national health insurance. | 8,236 | Hot flashes, night sweats | Yes | Hot flashes: pre-peri, peri-peri and HT groups had significantly higher odds ratio vs. pre-pre. Night sweats: Significantly increased odds ratio for all groups. | NR | Adjusted for but NR | Adjusted for but NR | Adjusted for but NR | Adjusted for but NR | NR | Good
Dennerstein, 2000^53^ | Melbourne Women's Midlife Health Project | Community-based cohort of 492 women (45–55 years) living in Melbourne, Australia. | 172 | Hot flashes, night sweats | Yes | Increased in late peri- and post-menopause. | NE | NR | NE | Yes, for hot flashes | NE | Excluded | Good
Hardy, 2002^51^ | Medical Research Council (MRC) | Socially stratified sample of all births in 1 week in March 1943 in Britain. | 1,572 | Vasomotor symptoms | Yes | Increase | NR | NR | NR | NR | NR | NR | Good
Mitchell, 1996^26^ | Seattle | Pre- and perimenopausal women (35–55 years) identified by census tract in Seattle, including minorities. | 301 | Vasomotor | No | NA | NA | NE | NE | NE | NE | Excluded | Fair
Vaginal dryness
Dennerstein, 2000^53^ | Melbourne Women's Midlife Health Project | Community-based cohort of 492 women (45–55 years) living in Melbourne, Australia. | 172 | Vaginal dryness | Yes | Increased in late peri- and postmenopause. | NE | NR | NE | NR, presumed not significant | NE | Excluded | Good
Sleep disturbance
Brown, 2002^46^ | Australian Longitudinal Study on Women's Health | Mid-age (45–50 years) cohort selected from 41,500 Australian women with national health insurance. | 8,236 | Difficulty sleeping | Yes | Pre-peri, peri-peri, pre/peri-post and HT had significantly higher odds ratios vs. pre-pre; only post-post was not significant. | NR | Adjusted for but NR | Adjusted for but NR | Adjusted for but NR | Adjusted for but NR | NR | Good
Dennerstein, 2000^53^ | Melbourne Women's Midlife Health Project | Community-based cohort of 492 women (45–55 years) living in Melbourne, Australia. | 172 | Trouble sleeping | Yes | Increased gradually across menopausal stages. | NE | NR | NE | NR, presumed not significant | NE | Excluded | Good
Mitchell, 1996^26^ | Seattle | Pre- and perimenopausal women (35–55 years) identified by census tract in Seattle, including minorities. | 301 | Insomnia | No | NA | NA | NE | NE | NE | NE | Excluded | Fair
Mood symptoms
Avis, 1994^20^ | Massachusetts Women's Health Study | Cohort of premenopausal women sampled from Massachusetts, USA (born 1926-36). | 2,565 | Depression | No | Increased odds ratio of depression (2.05; 95% CI 1.04–4.02) for peri-peri group. No other significant odds ratios with change in stage. | NR | NR | NR | NR | Yes | NR | Fair
Busch, 1994^30^ | National Health Examination Follow-up Study | U.S. women 40–60 years in NHANES. | 573 | Depression | No | NA | NR | NR | NR | NR | NR | No | Poor
Dennerstein, 1999^54^ | Melbourne Women's Midlife Health Project | Community-based cohort of 492 women (45–55 years) living in Melbourne, Australia. | 354 | Negative mood | No | NA | NE | NE | NE | No | NE | Excluded | Good
Dennerstein, 2001^55^ | Melbourne Women's Midlife Health Project | Community-based cohort of 492 women (45–55 years) living in Melbourne, Australia. | 267 | Positive mood | No | NA | NE | NS | NE | NS | NE | Excluded | Good
Freeman, 2004^41^ | Pennsylvania Ovarian Aging Study | Cohort of 436 African American and Caucasian women age 35–47 years from Pennsylvania, recruited by random digit dialing. | 332 | Depression | Yes | Increased odds of CES-D scores ≥ 16 in early and late transition. No increased odds of major depressive disorder. | NE | NS | Yes, increased odds of depression in African Americans vs. Caucasians | NR in multivariate model | Yes | NE | Good
Glazer, 2002^29^ | Ohio Midlife Women's Study | Community population based on media recruitment; 40–60 years. | 208 | Anxiety | No | NA | NE | NE | NE | NE | Yes | Yes | Good
Glazer, 2002^29^ | Ohio Midlife Women's Study | Community population based on media recruitment; 40–60 years. | 208 | Depression | No | NA | NE | NE | NE | NE | Yes | Yes | Good
Hallstrom, 1985^44^ | Gothenburg | Systematic sampling of women age 38–60 years using Taxation Office Register; psychiatric sample selected from this group. | 899 | Development of mental disorder | No | NA | NR | NR | NR | NR | NR | Excluded | Poor
Hardy, 2002^51^ | Medical Research Council (MRC) | Socially stratified sample of all births in 1 week in March 1943 in Britain. | 1,572 | Psychological symptoms (anxiety or depression) | No | NA | NR | NR | NR | NR | NR | NR | Good
Kaufert, 1992^63^ | Manitoba | Community population of Manitoba, Canada 45–55 years. | 469 | Depression | No | NA | NE | NE | NE | NE | NE | Increased odds of being depressed | Fair
Maartens, 2002^68^ | Eindhoven | Women born between 1941-1947 living in Eindhoven, The Netherlands, participating in Eindhoven Perimenopausal Osteoporosis Study. | 2,103 | Depression | Yes | Increase from pre-peri and peri-postmenopause. | NE | NE | NE | NE | NE | Excluded | Good
McKinlay, 1989^24^ | Massachusetts Women's Health Study | Cohort of premenopausal women sampled from Massachusetts, USA (born 1926-36). | 2,466 | Depression | No | Increased depression for those within 3 months of hysterectomy. | NR | NR | NR | NR | NR | Yes | Poor
Mishra, 2003^47^ | Australian Longitudinal Study on Women's Health | Mid-age (45–50 years) cohort selected from 41,500 Australian women with national health insurance. | 8,623 | General mental health (SF-36) | No | NA | NR | Adjusted for weight but NR | NR | Adjusted for but NR | NR | Excluded | Good
Mitchell, 1996^26^ | Seattle | Pre- and perimenopausal women (35–55 years) identified by census tract in Seattle, including minorities. | 301 | Dysphoric mood | No | NA | NA | NE | NE | NE | NE | Excluded | Fair
Woods, 1997^28^ | Seattle | Pre- and perimenopausal women (35–55 years) identified by census tract in Seattle, including minorities. | 347 | Depressed mood | No | NA | NE | NE | NE | NE | NE | Excluded | Fair
Somatic complaints
Brown, 2002^46^ | Australian Longitudinal Study on Women's Health | Mid-age (45–50 years) cohort selected from 41,500 Australian women with national health insurance. | 8,236 | Back pain | Yes | Only peri-peri had higher odds ratio than pre-pre, others not significant. | NR | Adjusted for but NR | Adjusted for but NR | Adjusted for but NR | Adjusted for but NR | NR | Good
Brown, 2002^46^ | Australian Longitudinal Study on Women's Health | Mid-age (45–50 years) cohort selected from 41,500 Australian women with national health insurance. | 8,236 | Headache | No | All odds ratios not significant. | NR | Adjusted for but NR | Adjusted for but NR | Adjusted for but NR | Adjusted for but NR | NR | Good
Brown, 2002^46^ | Australian Longitudinal Study on Women's Health | Mid-age (45–50 years) cohort selected from 41,500 Australian women with national health insurance. | 8,236 | Severe tiredness | Yes | Severe tiredness: pre-peri, peri-peri, and HT groups had significantly higher odds ratios vs. pre-pre; others not significant. | NR | Adjusted for but NR | Adjusted for but NR | Adjusted for but NR | Adjusted for but NR | NR | Good
Brown, 2002^46^ | Australian Longitudinal Study on Women's Health | Mid-age (45–50 years) cohort selected from 41,500 Australian women with national health insurance. | 8,236 | Stiff/painful joints | Yes | Pre-peri, peri-peri, HT groups had significantly higher odds ratios vs. pre-pre; others not significant. | NR | Adjusted for but NR | Adjusted for but NR | Adjusted for but NR | Adjusted for but NR | NR | Good
Brown, 2002^46^ | Australian Longitudinal Study on Women's Health | Mid-age (45–50 years) cohort selected from 41,500 Australian women with national health insurance. | 8,236 | Constipation | No | Only HT group had significantly higher odds ratios than pre-pre; others not significant. | NR | Adjusted for but NR | Adjusted for but NR | Adjusted for but NR | Adjusted for but NR | NR | Good
Dennerstein, 2000^53^ | Melbourne Women's Midlife Health Project | Community-based cohort of 492 women (45–55 years) living in Melbourne, Australia. | 172 | Breast soreness | Yes | Decreased in late peri- and post-menopause. | NE | NR | NE | NR | NE | Excluded | Good
Dennerstein, 2000^53^ | Melbourne Women's Midlife Health Project | Community-based cohort of 492 women (45–55 years) living in Melbourne, Australia. | 172 | Somatic symptoms (other than breast soreness) | No | NA | NE | NR | NE | NR | NE | Excluded | Good
Mishra, 2003^47^ | Australian Longitudinal Study on Women's Health | Mid-age (45–50 years) cohort selected from 41,500 Australian women with national health insurance. | 8,623 | Bodily pain (SF-36) | Yes | Only peri-peri and HT groups had significantly worse scores for bodily pain vs. pre-pre. | NR | Adjusted for weight change and weight at baseline, but contribution NR | NR | Adjusted for but NR | NR | Excluded | Good
Mishra, 2003^47^ | Australian Longitudinal Study on Women's Health | Mid-age (45–50 years) cohort selected from 41,500 Australian women with national health insurance. | 8,623 | General health perception (SF-36) | Yes | Only peri-peri and HT groups had significantly worse general health perceptions vs. pre-pre. | NR | Adjusted for weight change and weight at baseline but contribution NR | NR | Adjusted for but NR | NR | Excluded | Good
Mitchell, 1996^26^ | Seattle | Pre- and perimenopausal women (35–55 years) identified by census tract in Seattle, including minorities. | 301 | Neuromuscular | No | NA | NA | NE | NE | NE | NE | Excluded | Fair
Mitchell, 1996^26^ | Seattle | Pre- and perimenopausal women (35–55 years) identified by census tract in Seattle, including minorities. | 301 | Somatic | No | NA | NA | NE | NE | NE | NE | Excluded | Fair
Urinary complaints
Brown, 2002^46^ | Australian Longitudinal Study on Women's Health | Mid-age (45–50 years) cohort selected from 41,500 Australian women with national health insurance. | 8,236 | Leaking urine | Yes | Only per-peri had significantly higher odds ratio than pre-pre; others not significant. | NR | Adjusted for but NR | Adjusted for but NR | Adjusted for but NR | Adjusted for but NR | NR | Good
Dennerstein, 2000^53^ | Melbourne Women's Midlife Health Project | Community-based cohort of 492 women (45–55 years) living in Melbourne, Australia. | 172 | Urinary symptoms | No | NA | NE | NR | NE | NR | NE | Excluded | Good
Sherburn, 2001^56^ | Melbourne Women's Midlife Health Project | Community-based cohort of 492 women (45–55 years) living in Melbourne, Australia. | 373 | Urinary in-continence | No | NA | NE | Yes | NE | Not significant | NE | Yes | Good
Sexual dysfunction
Dennerstein, 2001^57^ | Melbourne Women's Midlife Health Project | Community-based cohort of 492 women (45–55 years) living in Melbourne, Australia. | 283 | Sexual dysfunction | Yes | Increased | NA | NA | NA | NA | NA | Excluded | Fair
Dennerstein, 2002^58^ | Melbourne Women's Midlife Health Project | Community-based cohort of 492 women (45–55 years) living in Melbourne, Australia. | 226 | Sexual dysfunction | Yes | Increased from early to late peri-menopause. | NE | NE | NE | NE | NE | Excluded | Fair
Reduced quality of life
Busch, 1994^30^ | National Health Examination Follow-up Study | U.S. women age 40–60 years in NHANES. | 573 | Quality of life | No | NA | NR | NR | NR | NR | NR | No | Poor
Dennerstein, 1997^52^ | Melbourne Women's Midlife Health Project | Community-based cohort of 492 women (45–55 years) living in Melbourne, Australia. | 438 | Quality of life | Yes | Decreased across menopausal categories | NR | NR | NR | NR | NR | Excluded | Good
Dennerstein, 2002^59^ | Melbourne Women's Midlife Health Project | Community-based cohort of 492 women (45–55 years) living in Melbourne, Australia. | 226 | Well-being | Yes | Increased from early to late peri- and post menopause. | NE | NE | NE | NE | NE | Excluded | Good
Mishra, 2003^47^ | Australian Longitudinal Study on Women's Health | Mid-age (45–50 years) cohort selected from 41,500 Australian women with national health insurance. | 8,623 | Quality of life | Yes, for peri-peri women only | Decreased | NR | Similar body weight between groups | NR | NR | NR | Excluded | Good

Abbreviations

CI=Confidence Interval

CES-D = Center for Epidemiologic Studies Depression Scale

HT=Hormone Replacement Therapy

NA=Not Applicable

NE=Not Examined

NR=Not Reported

Peri=Perimenopausal

Post=Postmenopausal

Pre=Premenopausal

SF-36=Short Form-36 Health Survey

Major limitations of cohort studies include dissimilar methods for evaluating and reporting symptoms and for assessing menopausal change. Some studies based results on cross-sectional data reported at serial time points rather than individual tracking of women over time. Some studies failed to adjust or stratify for potentially important variables such as age, race, BMI, life events, or history of depression when attempting to attribute symptoms to change in menopausal stage. Although most included studies were population-based, in many cases, enrolled women were additionally selected from the initial recruited cohort and may have been less representative of the general population.^44,^ ^52,^ ^53,^ ^55,^ ^57–59^ Also, many studies were based on cohorts recruited from community populations and are more representative of volunteers than entire communities.

A total of 51 cross-sectional studies meeting similar inclusion criteria were obtained to provide additional prevalence data including 29 studies from the 14 study cohorts^21–25,^ ^27,^ ^30,^ ^33–40,^ ^42,^ ^45,^ ^48–50,^ ^56,^ ^60–66,^ ^69^ and 22 studies from other populations.^70–91^ Results of cross-sectional studies are summarized in Table 4.

Table 4 Results of cross-sectional studies of menopause related symptoms

| Main Outcomes
Study, year | Vasomotor | Vaginal dryness | Sleep | Mood | Cognitive | Somatic | Urinary | Uterine bleeding | Sexual dysfunction | Quality of life | Age at onset | Race/ethnicity | BMI | Surgical/natural menopause | Smoking | Depression
Data from study cohorts
Avis, 1997^21^ | X | | | | | | | | | | X
Avis, 2000^22^ | | | | X | | | | | X | X | | | X
Avis, 2001^33^ | X | | | X | | | | | | | | x
Avis, 2003^34^ | | | | | | | | | | X | | X
Bromberger, 2001^35^ | X | | X | X | | | | | | | | X | | | X
Bromberger, 2003^36^ | X | | X | X | | X | | | | | | X
Busch, 1994^30^ | | | | | | | | | | | | | | X
Dennerstein, 1993^60^ | X | | X | X | X | | X
Dennerstein, 1994^61^ | | | | | | | | | X
Gold, 2000^37^ | X | X | X | | X | X | X | | | | | X | X | | X
Gracia, 2004^42^ | | | | | | | | | X | | | X | X
Guthrie, 1996^62^ | X | | | | | | | | | | | | | | X
Hunter, 1989^69^ | X | X | X | X | X | X | | | X
Kaufert, 1992^63^ | | | | X | | | | | | | | | | X
Koch, 1995^40^ | X | X | | | | | | X | X
Koster, 1993^64^ | X | | | X | | X | | | | | | | | X
Koster, 1993^65^ | | | | | | | | | X | | | | | X
Koster, 2002^66^ | X | | | X | | X | | | X | | | | | X
Kravitz, 2003^38^ | | | X | | | | | | | | | X | | X
Kuh, 1997^48^ | X | X | X | X | X | X | X | | X | | | | | X | X | X
Kuh, 1999^49^ | | | | | | | X | | | | | X
Kuh, 2002^50^ | | | | X
McKinlay, 1987^23^ | | | | X
McKinlay, 1989^24^ | | | | X
McKinlay, 1992^25^ | X | | X
Milsom, 1993^45^ | | | | | | | X | | | | | | | X
Mitchell, 2001^27^ | | | | | X
Randolph, 2003^39^ | | | | | | | | | | | | X | X | | X
Sherburn, 2001^56^ | | | | | | | X | | | | | | X | X
Data from other populations
Avis, 1993^70^ | X | | | X | | | | | | | | X | | X
Bardel, 2002^71^ | X | X | | | | X | X
Bell, 1995^72^ | X | X | | X | | X | | | | | | X | | X
Feldman, 1985^73^ | X | | | | | | | | | | | | | X
Groeneveld, 1993^74^ | X | X | | | | | | | | X | | | X | | X
Hagstad, 1986^75^ | X | X | | | | | X
Hammar, 1984^76^ | X | X | | X
Hording, 1986^77^ | | | | | | | X
Jansson, 2003^79^ | X | | X
Jaszmann, 1969^78^ | X | | X | | | X
Keenan, 2003^80^ | X | X | X | X | X | | | X | | | | | | X
Li, 2002^81^ | X | | X | X | X | X
McKinlay, 1974^82^ | X | | X | X | | X
O'Connor, 1995^83^ | X | X | | X | | X | | | X
Olofsson, 2000^84^ | X | X | X | X | X | X | X | | X
Porter, 1996^85^ | X | X | X | X | X | X | X
Reckers, 1992^86^ | | | | | | | X | | X | | | | | X
Rybo, 1971^87^ | X | | X | | X | X | X
Schwingl, 1994^88^ | X | | | | | | | | | | | | X | | X
Slaven, 1998^89^ | X | | | | X | X | | | X | | | | | X
Thompson, 1973^90^ | X | | X | X | | X | | | | | | | | X
Young, 2003^92^ | | | X | | | | | | | | | | X | | X | X

Key

X=statistically significant association between symptom and menopausal stage.

## Key Question 1. Symptoms Associated with Menopause

### What is the evidence that the symptoms more frequently reported by middle-aged women are attributable to ovarian aging and senescence?

#### Vasomotor Symptoms

Four studies from four population-based cohorts evaluated the association between vasomotor symptoms and menopausal stage, including three rated good-quality^46,^ ^51,^ ^53^and one fair.^26^ Women transitioning from premenopause to either perimenopause or postmenopause had increased vasomotor symptoms in the three good-quality studies.^46,^ ^51,^ ^53^

The prevalence of hot flashes was reported in 33 cross-sectional studies.^25,^ ^27,^ ^33,^ ^35–37,^ ^40,^ ^48,^ ^60,^ ^62,^ ^64,^ ^66–67,^ ^69–76,^ ^78–85,^ ^87–90^ Prevalence rates ranged from 14 percent to 51 percent for premenopausal women, were approximately 50 percent for perimenopausal women, and between 30 percent to 80 percent for postmenopausal women, depending on the age and population studied. In one study, approximately 29 percent of women age 60 years reported hot flashes, suggesting only a modest decline in frequency with increasing time from menopause.^66^

#### Vaginal Dryness

Vaginal dryness was associated with menopause, and became more common with the transition from premenopause to postmenopause, in the one good-quality cohort study examining this relationship.^53^ Thirteen cross-sectional studies^37,^ ^40,^ ^48,^ ^69,^ ^71,^ ^72,^ ^74–76,^ ^80,^ ^83–85^ reported prevalence rates ranging from 4 percent to 22 percent for premenopausal women, 7 percent to 39 percent for perimenopausal women, and 17 percent to 30 percent for early postmenopausal women. Two cross-sectional studies showed either no association,^84^ or a weak association,^83^ between vaginal dryness and menopausal stage.

#### Sleep Disturbance

Three cohort studies evaluated the impact of menopausal status on sleep; two were rated good-quality^46,^ ^53^ and one fair.^26^ In the good-quality studies, women had more difficulty sleeping as they progressed through the menopausal stages,^46,^ ^53^ and sleeping difficulty was associated with the presence of hot flashes.^53^ The fair-quality study reported no association.^26^

Eighteen cross-sectional studies evaluated the prevalence of sleep disturbance at different menopausal stages.^25,^ ^35–38,^ ^48,^ ^60,^ ^69,^ ^78–82,^ ^84,^ ^85,^ ^87,^ ^90,^ ^92^ Of these, eight reported prevalence rates ranging from 16 percent to 42 percent for premenopausal women, 39 percent to 47 percent for perimenopausal women, and 35 percent to 60 percent for postmenopausal women (including women with either surgical or natural menopause and hormone therapy users).^37,^ ^60,^ ^78,^ ^80–82,^ ^85,^ ^90^ Some studies,^79,^ ^82,^ ^87^ but not others,^38,^ ^90^ reported an association between hot flashes and sleep disturbance. When hot flashes/night sweats and insomnia were considered together in one study, 27 percent of premenopausal women, 46 percent of perimenopausal women, and 38 percent of postmenopausal women reported disturbances.^25^

Four cross-sectional studies reported increased adjusted odds ratios for difficulty sleeping for menopausal women compared to premenopausal women^37,^ ^48,^ ^69,^ ^92^ In one study, an age-adjusted significant correlation between sleep problems and menopausal status was reported, but increases among perimenopausal and postmenopausal women were small, and social class was a stronger predictor.^69^ A factor analysis of sleep-related problems found sleep was not associated with menopausal status.^84^ In another study, sleep disordered breathing increased across the menopausal stages after multivariate adjustment and stratification by BMI and age.^92^

#### Mood Symptoms

Fourteen studies from 11 cohorts evaluated the impact of menopausal stage on mood.^20,^ ^24,^ ^26,^ ^28–30,^ ^41,^ ^44,^ ^47,^ ^51,^ ^54,^ ^55,^ ^63,^ ^68^ Of these, seven were rated good-quality,^29,^ ^41,^ ^47,^ ^51,^ ^54,^ ^55,^ ^68^ four fair,^20,^ ^26,^ ^28,^ ^63^ and three poor. ^24,^ ^30,^ ^44^ Symptoms included anxiety,^29^ depression,^20,^ ^24,^ ^28–30,^ ^41,^ ^63,^ ^68^ dysphoric or negative mood,^26,^ ^54^ and positive mood.^55^ Development of a mental disorder,^44^ psychological symptom reporting,^51^ and general mental health^47^ were also assessed.

Twelve of the 14 studies, including five good-quality, four fair, and three poor, found no influence of menopausal stage on mood symptoms, development of a mental disorder, or general mental health.^20,^ ^24,^ ^26,^ ^28–30,^ ^44,^ ^47,^ ^51,^ ^54,^ ^55,^ ^63^ Two good-quality studies demonstrated a change in mood symptoms with the menopausal transition.^41,^ ^68^ A well-designed, nested case-control study of age-matched menopausal and premenopausal women from the Pittsburgh cohort found no differences between the groups in depression, anger, anxiety, or stress symptoms.^93^

Twenty-four cross-sectional studies reported relevant data.^22–24,^ ^33,^ ^35,^ ^36,^ ^48,^ ^50,^ ^60,^ ^63,^ ^64,^ ^66,^ ^67,^ ^69,^ ^70,^ ^72,^ ^76,^ ^80–85,^ ^90^ The prevalence of depressed mood ranged from 8 percent to 37 percent for premenopausal women, 11 percent to 46 percent for perimenopausal women, 8 percent to 47 percent for women with natural menopause, and 8 percent to 38 percent for women with surgical menopause.^23,^ ^66,^ ^67,^ ^80,^ ^85^

#### Cognitive Disturbances

No cohort studies longitudinally assessed cognitive symptoms. Eight cross-sectional studies showed no differences in the prevalence rates of memory or concentration problems by menopausal stage.^37,^ ^48,^ ^67,^ ^69,^ ^80,^ ^81,^ ^84,^ ^85^

#### Somatic Complaints

Somatic complaints were evaluated in four studies conducted among three cohorts rated good-quality^46,^ ^47,^ ^53^ or fair-quality.^26^ Perimenopausal women had increased somatic symptoms compared to premenopausal women in one cohort.^46,^ ^47^ Symptoms included back pain, severe tiredness, stiff or painful joints, bodily pain, and worse general health. Other studies reported reduced breast tenderness,^53^ or no association with somatic or neuromuscular symptoms.^26^

Fourteen of 18 cross-sectional studies evaluating changes in somatic symptoms showed no significant increases as women transitioned from premenopause to postmenopause in adjusted analytic models.^36,^ ^37,^ ^48,^ ^64,^ ^66,^ ^67,^ ^69,^ ^71,^ ^72,^ ^81–85,^ ^87^ Three studies showed slight increases in somatic symptoms during perimenopause that decreased during postmenopause,^78,^ ^89^ or remained stable.^67^ Another study showed significantly fewer somatic symptoms for women at menopause compared with those at premenopause.^90^

#### Urinary Complaints

Three good-quality cohort studies evaluated the impact of menopausal stage on urinary symptoms.^46,^ ^53,^ ^56^ In one study, women who were perimenopausal at baseline were more likely to report leakage of urine two years later than women who remained premenopausal.^46^ Two studies from the Melbourne cohort found no association of menopausal status with urinary symptoms.^53,^ ^56^

Fourteen cross-sectional studies^37,^ ^45,^ ^48,^ ^49,^ ^56,^ ^60,^ ^67,^ ^71,^ ^75,^ ^77,^ ^84–87^ provided relevant data. Prevalence rates of urinary incontinence or leakage ranged from 10 percent to 36 percent for premenopausal women, 17 percent to 39 percent for perimenopausal women, 14 percent to 36 percent for women undergoing natural menopause, and 18 percent to 36 percent for women undergoing surgical menopause.^37,^ ^46,^ ^56,^ ^67,^ ^86^

#### Uterine Bleeding Problems

No studies meeting inclusion criteria addressed uterine bleeding problems, most likely because currently accepted definitions of menopause rely historically on changes in uterine bleeding.

#### Sexual Dysfunction

Sexual dysfunction was evaluated in two fair-quality studies from the Melbourne cohort.^57,^ ^58^ Sexual function was variably measured and included decreased responsivity, decreased libido, and/or decreased frequency of sexual activity. In that cohort, women demonstrated decreases in some or all of the sexual parameters as they transitioned from early to late perimenopause or postmenopause.^57,^ ^58^

Thirteen cross-sectional studies, including one from the Melbourne cohort, also evaluated sexual function.^22,^ ^40,^ ^42,^ ^48,^ ^61,^ ^65,^ ^66,^ ^69,^ ^83,^ ^84,^ ^86,^ ^89^ Five studies showed the prevalence of sexual disinterest, dysfunction, or discomfort to increase from premenopause to perimenopause to postmenopause,^48,^ ^61,^ ^67,^ ^69,^ ^86^ and four showed no change.^40,^ ^65,^ ^84,^ ^89^

#### Reduced Quality of Life

Four cohort studies addressed the impact of menopausal stage on quality of life, three rated good-quality^47,^ ^52,^ ^59^ and one poor.^30^ Two studies from the Melbourne cohort had conflicting results.^52,^ ^59^ One study showed declines in well-being across progressive menopausal stages (lowest for the one to two years postmenopause) that improved when women were more than two years postmenopause.^52^ A second study showed increased well-being from early to late perimenopause and postmenopause.^59^ In another good-quality study, women who remained perimenopausal over a two year follow-up period reported significant decreases in quality of life compared to women who remained premenopausal, although significant decreases were not reported by women in other stages.^47^ A poor-quality cohort study found that well-being was not associated with change in menopausal status.^30^

Three cross sectional studies also evaluated quality of life.^22,^ ^34,^ ^74^ Satisfaction with life,^22^ and impaired functioning^34^ did not vary with menopausal stage in multivariate regression modeling of data from the Massachusetts Women's Health Study. In another study, various aspects of general well-being were lower among postmenopausal women compared to premenopausal women.^74^

## Summary

- Vasomotor symptoms: Evidence from population-based cohort and cross-sectional studies supports the association between vasomotor symptoms and menopausal stage. Studies are consistent in reporting increasing prevalence rates of vasomotor symptoms as women transition from premenopause to either perimenopause or postmenopause, affecting 50 percent or more of women. Studies suggest that vasomotor symptoms persist for several years after menopause for some women.
- Vaginal dryness: Vaginal dryness is associated with menopause and prevalence rates increase as women transition through the menopausal stages. Estimates indicate that up to one third of perimenopausal and postmenopausal women experience vaginal dryness.
- Sleep disturbance: Although results of studies are mixed, two good-quality cohort studies indicate that women have more difficulty sleeping as they transition through menopausal stages, and this may be due to vasomotor symptoms. Up to 40 percent to 60 percent of perimenopausal and postmenopausal women experience sleep disturbance, a slight increase from prevalence rates of premenopausal women.
- Mood symptoms: The majority of studies from a large literature report no associations between menopausal stage and mood symptoms, development of a mental disorder, or general mental health. Studies of prevalence rates report wide ranges that are similar across menopausal stages.
- Cognitive disturbances: The few studies evaluating cognitive disturbances in menopause have inadequate measures.
- Somatic complaints: Most studies report no association of somatic symptoms with menopause, although somatic symptoms were increased among perimenopausal women compared with premenopausal women in one cohort and two cross-sectional studies.
- Urinary complaints: Urinary leakage increased among perimenopausal women compared with premenopausal women in one study, and another reported no associations. Studies of prevalence rates report wide ranges that are similar across menopausal stages.
- Uterine bleeding problems: No studies meeting inclusion criteria addressed uterine bleeding problems, most likely because currently accepted definitions of menopause rely historically on changes in uterine bleeding.
- Sexual dysfunction: Women from two study cohorts reported declines in some or all of the measured sexual parameters as they transitioned through menopausal stages. Results of cross-sectional studies are mixed.
- Reduced quality of life: Results of available cohort and cross-sectional studies are conflicting.

## Key Question 2. Factors Influencing Symptoms

### When do the menopausal symptoms appear, how long do they persist and with what frequency and severity, and what is known about the factors that influence them?

Included studies do not characterize the severity and duration of specific symptoms, and frequency is described by prevalence data in Key Question 1.

#### Race and Ethnicity

Two cohort studies^38,^ ^41^ addressed the influence of race and ethnicity on menopausal symptoms, while many adjusted for it in multivariable models. Depression was reported more often among African American women compared to Caucasian women,^41^ and sleep difficulties were reported more often among Caucasian and Hispanic women and less often among African American, Chinese, and Japanese women.^38^

Seven cross-sectional studies conducted in the large SWAN cohort also evaluated symptoms by race or ethnicity.^33–37,^ ^39,^ ^70^ In SWAN, vasomotor symptoms were reported more often among African American women and less often among Hispanic, Chinese, and Japanese women compared with Caucasian women.^33,^ ^37^ Japanese, Chinese, African American, and Hispanic women reported fewer mood symptoms compared to Caucasian women,^33,^ ^35,^ ^36^ although “impaired social function” was reported among Hispanic women in two studies^34,^ ^70^ and among African American women in one study.^34^ Hispanic women also reported more bodily pain than Caucasian women.^34^ A cross-sectional study conducted outside the SWAN cohort found that Mexican American women had similar prevalence rates of vasomotor symptoms and vaginal dryness as Caucasian women.^72^

#### Age at Onset of the Menopause Transition

Long term studies evaluating menstrual cycles over many years among large cohorts of women showed the median onset of menstrual irregularity to begin between the ages of 45 and 47.5 years with a mean duration of the menopausal transition lasting 5 years.^94–96^ Factors associated with earlier menopause include smoking,^97–99^ shorter cycle length during menstruating years,^100^ and shorter stature and leaner body weight.^101^ Factors associated with later age at menopause include higher gravidity or parity^98,^ ^99^ and higher BMI.^99^

A cross-sectional study reported increased rates of hot flashes among women with menopause prior to age 53 after adjustment for other factors.^88^ Another found that earlier age of inception of perimenopause was related to a longer perimenopause stage.^21^

#### Body Mass Index (BMI)

Two good-quality cohort studies evaluated BMI and its effect on symptoms among menopausal or perimenopausal women and found that BMI was a significant predictor of urinary incontinence,^56^ but not positive mood.^55^ A cross-sectional study reported a slight increase in vasomotor symptoms (15 percent) among women with a BMI of 27 or greater, although, vasomotor symptoms were less common at the extremes of BMI.^37^ Lower BMI was independently associated with increased hot flashes in another cross-sectional study.^88^ Three cross-sectional studies^22,^ ^42,^ ^74^ found no significant differences for increased BMI. Other studies evaluating menopausal symptoms adjusted for BMI in multivariate models but did not report the contribution of BMI to symptoms.^46,^ ^47,^ ^53,^ ^92^

#### Surgical Versus Natural Menopause

Two good-quality^29,^ ^56^ and one fair-quality cohort studies^63^ reported data for women with surgical menopause. The Ohio Midlife Women's Study found that hysterectomy was not a predictor of anxiety or depression.^29^ In contrast, a community-based study of women in Manitoba, Canada reported that women with hysterectomies had increased odds of depression.^63^ In the Melbourne Women's Midlife cohort, surgical menopause was not a significant predictor of urinary incontinence.^56^ Other symptoms were not addressed in these studies.

Sixteen cross-sectional studies reported symptoms among women with surgical and natural menopause.^30,^ ^38,^ ^45,^ ^48,^ ^56,^ ^63–66^ ^70,^ ^72,^ ^73,^ ^80,^ ^86,^ ^89,^ ^90^ Four studies showed no significant differences in vasomotor symptoms,^48,^ ^70,^ ^80,^ ^90^ and three studies showed slightly higher rates of vasomotor symptoms among women with surgical menopause (seven percent to eight percent higher).^64,^ ^66,^ ^73^ Vasomotor symptoms were similar among Japanese and Canadian women with surgical and natural menopause in another study.^70^ Three studies evaluated vaginal dryness; two showed similar rates,^48,^ ^72^ and one reported a nine percent higher prevalence among women with surgical compared to natural menopause.^80^ One cross-sectional study found no differences in rates of sexual dysfunction by type of menopause,^48^ and another showed higher rates of urinary incontinence (36 percent vs. 22 percent) among women with surgical menopause.^86^

The prevalence of anxiety and depression was evaluated in four cross-sectional studies,^66,^ ^70,^ ^80,^ ^89^ and two showed higher prevalence rates among women with surgical menopause.^66,^ ^80^ In a cross-sectional study from the Massachusetts Women's Health Study evaluating depression, women who had undergone surgical menopause in the previous three months were twice as likely as the rest of the cohort to have elevated depression scores.^24^

#### Depression

The interaction of baseline depression with menopausal stage and/or transition and the presence or absence of symptoms was not evaluated in any cohort study. A cross-sectional study reported that prior anxiety or depression did not predict menopausal symptoms.^48^ One other cross-sectional study evaluating menopausal symptoms adjusted for depression in a multivariate model but did not report the contribution of depression to symptoms.^92^

#### Smoking

Three good-quality studies from the Melbourne Women's Midlife cohort examined the association of smoking status with mood symptoms and urinary incontinence.^54–56^ In this cohort, current smoking was associated with negative mood,^54^ but not positive mood,^55^ and was not evaluated as an interaction term with menopausal transition or stage. Smoking was not a significant predictor of urinary incontinence.^56^ Two good-quality studies adjusted for smoking in multivariate models, but did not report any data for this variable.^46,^ ^47^

Five cross-sectional studies provide data on smoking and menopausal symptoms.^35,^ ^37,^ ^48,^ ^62,^ ^88^ Two studies showed no association between smoking and menopausal symptoms,^37,^ ^62^ one reported that smoking was associated with psychological distress but did not evaluate smoking as an interaction term,^35^ and another showed that smoking at anytime in the past predicted greater vasomotor symptoms during menopause.^48^ Another study reported no association between hot flashes and smoking, but identified higher rates of vasomotor symptoms among thin smokers than among thin non-smokers.^88^ Other studies evaluating menopausal symptoms adjusted for smoking status in multivariate models but did not report the contribution of smoking status to symptoms^39,^ ^74,^ ^92^

## Summary

- Included studies do not provide adequate details to characterize the onset, severity, and duration of specific symptoms. Frequency is described by prevalence data in Key Question 1.
- Race and ethnicity: The influence of race and ethnicity on menopausal symptoms has not been extensively studied. Prevalence rates of vasomotor and mood symptoms vary among race and ethnic groups in the large SWAN cohort.
- Age at onset of menopausal transition: Available studies are inconclusive.
- Body mass index: Available studies are inconclusive.
- Surgical versus natural menopause: Studies present mixed results regarding the impact of surgical menopause on vasomotor symptoms, vaginal dryness, and mood. Adjustment for confounders is necessary because women undergoing hysterectomy differ from women with natural menopause in ways that may also influence their menopause related symptoms.
- Depression: Only one cross sectional study was included and reported that prior anxiety or depression did not predict menopausal symptoms.
- Smoking: Available studies are inconclusive.

## Key Question 3. Benefits and Adverse Effects of Therapies

### What is the evidence for the benefits and harms of commonly used interventions for relief of menopause-related symptoms?

#### Estrogen

Three recent good-quality systematic reviews and meta-analyses of randomized controlled trials of estrogen, alone (unopposed) or combined with progestin or progesterone (opposed), describe benefits and harms of various forms, doses, and regimens for treating menopausal symptoms. These include a Cochrane review of trials of oral estrogen for hot flashes,^16,^ ^102,^ ^103^ a meta-analysis of trials of oral conjugated equine estrogen (CEE) and oral and transdermal estradiol for hot flashes,^15,^ ^104^ and a review of commonly used types of estrogen for several menopausal symptoms.^15^ Trials were conducted predominantly in the U.S. or western Europe and recruited participants from primary care or gynecology practices. Most trials focused on healthy menopausal women in their early 50s with baseline symptoms that varied by study. All trials were double blind, of 12 weeks duration or more, and rated good or fair quality.

Vasomotor symptoms. The Cochrane meta-analysis indicated a significant reduction in frequency of weekly hot flashes for oral estrogen compared to placebo with a pooled weighted mean difference of -17.9 hot flashes per week (95% confidence interval [CI], -22.9 to -13.0; nine trials), equivalent to a 75.3 percent reduction in frequency (95% CI, 64.3 percent to 82.3 percent).^16^ Severity of symptoms was also significantly reduced compared to placebo (odds ratio [OR] 0.13; 95% CI, 0.07 to 0.23; 13 trials). Differences between types of estrogens were not determined, although trials of estradiol and CEE predominated. The review also found that the reduction in weekly hot flash frequency was similar for opposed and unopposed estrogen regimens compared to placebo (opposed: -19.9 per week; 95% CI, -26.7 to -12.6; three trials; unopposed: -14.7; 95% CI, -20.1 to -8.7; six trials). Symptom severity seemed to be better treated by opposed (OR 0.10; 95% CI, 0.06 to 0.19; 10 trials) than by unopposed estrogen (OR 0.35; 95% CI, 0.22 to 0.56; four trials), although heterogeneity of trials could also explain this difference.

Hot flash frequency, severity, or both improved in nine of 10 trials of oral estradiol and in all 11 trials of transdermal estradiol compared to placebo in a review of these agents.^15^ The pooled weighted mean differences in hot flashes were -16.8 per week (95% CI, -23.4 to -10.2; five trials) for oral estradiol, and -22.4 per week (95% CI, -35.9 to -10.4; six trials) for transdermal estradiol. Results were similar when opposed and unopposed regimens were considered separately.^15^ All eight trials of oral CEE reported statistically significant improvements in hot flash frequency, severity, or both compared with placebo. One trial of CEE that provided data comparable to the estradiol meta-analyses reported a mean reduction of -19.1 hot flashes per week (95 percent CI, -33.0 to -5.1). Four trials comparing estrogen agents head-to-head (CEE compared with oral or transdermal estradiol) indicated improved number and severity of hot flashes for all treatment groups with no significant differences between them (pooled weighted mean difference in hot flashes -0.3; 95 percent CI, -3.4 to 2.7; three trials).

In a review of 32 trials of estrogen for treatment of vasomotor symptoms, all but five were less than one year in duration and only three trials enrolled more than 500 participants, limiting evaluation of adverse effects.^15^ Trials reported multiple specific adverse effects including atypical bleeding and endometrial hypertrophy, nausea and vomiting, breast tenderness, headache, weight change, dizziness, venous thromboembolic events, cardiovascular events, rash and pruritus, cholecystitis, liver effects, and other adverse events. These outcomes were reported unevenly across studies and could not be combined in summary statistics. Trials included in the Cochrane review indicated similar adverse effects with breast tenderness and uterine bleeding most commonly reported.^16^

Urogenital symptoms/sexual dysfunction. In a systematic review of good and fair-quality trials of a variety of estrogen agents, urogenital symptoms improved in eight of nine trials, and sexual function (including pain during intercourse and responses to questionnaires) in eight of 11 trials.^15^ Vaginal forms of estrogen were evaluated in five trials. In a placebo controlled trial, vaginal dryness and pain during intercourse improved with use of the estradiol intravaginal ring compared to placebo.^105^ A trial of the estradiol intravaginal ring and oral estradiol reported improved vaginal dryness, involuntary loss of urine, and pain during intercourse for both groups.^106^ Head-to-head trials comparing the intravaginal estradiol ring with CEE vaginal cream among women with signs and symptoms of urogenital atrophy indicated that the two agents were comparable for relief of vaginal dryness and pain during intercourse, resolution of atrophic signs, improvement in vaginal mucosal maturation indices, and reduction in vaginal pH.^107,^ ^108^ Similar findings were reported in a trial of the estradiol vaginal tablet and CEE cream.^109^

Four placebo controlled trials of transdermal estradiol indicated improvements in some, but not all, urinary and sexual symptoms. Two trials reported improvements in responses to the McCoy Sex Scale Questionnaire compared to placebo,^9,^ ^110^ although, another trial indicated no differences for symptoms of vaginal discomfort, loss of libido, and incontinence.^111^ Another trial of transdermal estradiol indicated improvement in vaginal dryness, but not pain during intercourse, frequent urination, dysuria, stress incontinence, and nocturia, compared to placebo.^112^

A trial of oral CEE reported significantly improved vaginal dryness and urinary frequency, but no significant improvement on six other items related to sexual function on a General Health Questionnaire compared to placebo.^113^ A trial comparing oral CEE and transdermal estradiol indicated that the majority of women reported either no change or improvements in vaginal dryness and itching, pain during intercourse, and urinary pain and burning in all treatment groups with no major differences between groups.^114^ All treatment groups demonstrated improved vaginal cytology, measured by the maturation index, with the biggest improvement in the higher dose estradiol group (0.1 mg/day).

Sleep disturbance. Improved measures of sleep were specifically reported in three trials included in the systematic review.^15^ Transdermal estradiol provided significant improvements in sleep quality, sleep onset, and decreased nocturnal restlessness and awakening compared to placebo.^115^ In a subanalysis of the Women's Health Initiative (WHI) that considered women ages 50 to 54 years old who reported moderate to severe vasomotor symptoms at baseline, there was a positive effect on sleep disturbance with CEE compared to placebo.^116^ In contrast, a trial of CEE in women with hot flashes and nighttime awakening at baseline indicated improvement in menopausal symptoms and measures of psychological well-being, but not in parameters of sleep quality such as total sleep time, sleep onset time, number of awakenings, and REM sleep duration compared to placebo.^117^

Mood symptoms. Thirteen trials of estrogen reporting mood and depression outcomes met eligibility criteria (Table 5, Appendix 6-2), including three trials rated good-quality,^118–120^ four fair,^121–124^ and six poor.^125–130^ Trials compared placebo with CEE,^119,^ ^121,^ ^124,^ ^126,^ ^128^ oral estradiol,^120,^ ^122,^ ^125^ transdermal estradiol,^118,^ ^126^ piperazin oestrone sulphate,^129,^ ^130^ and estropiate.^127^ Head-to-head comparisons included estradiol and estradiol valerate,^123^ CEE and clonidine,^128^ CEE and raloxifene,^119^ and estradiol and raloxifene.^120^

Table 5 Trials of estrogen for depression

| | | | | | Main results
Study, year | N | Mean age (range) | Therapy | Comparison | Duration | Between group differences | Within group differences | Quality
Bech, 1998^122^ | 151 | Not reported | 1. Estradiol 2 mg/day and NETA 1 mg/day | Placebo | 12 months | Improved scores on Beck Depression Inventory (12 & 21 item scales) with both estrogen groups vs. placebo (p<0.05). | Improved depression scores for estrogen groups. | Fair
| | | 2. Estradiol 2 mg/day for 22 days, 1 mg/day for 6 days and NETA 1 mg/day for 10 days of cycle
Ditkoff, 1991^124^ | 36 | 53 (45–60) | 1. CEE 0.625 mg/day days 1 to 25; cyclic | Placebo | 3 months | Not reported | Improved scores on Beck Depression Inventory and income management scale (p<0.05 for both) for both doses of CEE; no changes on other measures; (MMPI-168; Profile of Adaptation to Life, Wechsler Adult Intelligence Scales). | Fair
| | | 2. CEE 1.25 mg/day days 1 to 25; cyclic
Furuhjelm, 1984^125^ | 58 (48 analyzed) | 54 (44–64) | 1. Estradiol 1–2 mg/day, estriol 0.5–2 mg/day, and norethisterone acetate 1 mg/day; cyclic | Placebo | Cross-over; 4 2-month phases | Not reported | Improved measures of mental distress in estrogen groups (p<0.01); only women depressed at baseline had improved depression scores (p<0.001); (Sabbatsberg General Symptom Scale, Distress Self-rating Scale, Sexual Self-rating Scale, Eysenck Personality Inventory). | Poor
| | | 2. Estradiol 2–4 mg/day, estriol 0.5–2 mg/day, and norethisterone acetate 1 mg/day; cyclic
| | | 3. Estradiol 2 mg/day, estriol 1 mg/day
| | | All groups combined in analysis
Gerdes, 1982^128^ | 38 | Not reported | CEE 1.25 mg/day for 21 days and medrogestrone 5 mg/day from day 16 to 21 followed by 7 days of placebo; cyclic | 1. Placebo | 20 weeks | Improved cheerfulness, health, and energy with CEE vs. placebo (p<0.001); improved moodiness, feeling relaxed, feeling understood, and self-confidence with CEE vs. placebo (p<0.01). Improved depression score (p<0.01) (Mini-Biography Questionnaire) and less moodiness in CEE vs. clonidine group (p<0.05); no difference in moodiness with clonidine vs. placebo. | | Poor
| | | | 2. Clonidine 25 mcg twice daily
Hall, 1998^126^ | 60 | 44–75 | 1. CEE 0.625 mg/day and MPA 5 mg/day; cyclic | Placebo | 1 year | Not reported | Improved measures of mood in all groups; improved depressed mood scores in CEE group (p=0.054) but not in estradiol or placebo groups. | Poor
| | | 2. Estradiol 50 mcg patch and MPA 5 mg/day; cyclic
Khoo, 1998^121^ | 105 | 46 (40–52) | CEE 0.625 mg/day and MPA 10 mg/day days 14 to 27; cyclic | Placebo | Cross-over; 6 months each phase | No differences between groups in depressive symptoms during first phase. | | Fair
Klaiber, 1996^127^ | 38 | 53 (45–65) | Estropiate 1.5 mg/day and norethindrone 1 mg/day | Placebo | Cross-over; 56 days each phase | Improved mood symptoms while on estropiate only vs. placebo (anxiety p<0.001, depression and anger p<0.01); no differences while on estropiate and norethindrone. | | Poor
Saure, 2000^123^ | 376 | 49 | Estradiol 1.5 mg/day for 24 days and desogestrel 0.15 mg/day for 12 days each cycle | Estradiol valerate 2 mg/day for 21 days and MPA 10 mg/day for 10 days of cycle | 6 months | No differences in mood disturbances between groups at end of study. | Improved mood disturbances (self report) in both groups. | Fair
Soares, 2001^118^ | 50 | 49 estradiol, 50 placebo; (40–55) | Estradiol 100 mcg/day transdermal | Placebo | 12 weeks | Improved depressive symptoms in depressed women using estradiol vs. placebo (p<0.001); (Montgomery-Asberg Depression Rating Scale.) | Improved depression scores in both groups at end of treatment. | Good
Strickler, 2000^119^ | 373 | 55 (47–60) | CEE 0.625 mg/day | 1. Raloxifene 60 mg/day | 1 year | No differences in depressed mood between groups. Improved anxiety with raloxifene 60 mg/day vs. placebo (p=0.03), and raloxifene 60 mg/day vs. CEE (p=0.003). No differences with raloxifene 150 mg/day. | | Good
| | | | 2. Raloxifene 150 mg/day
| | | | 3. Placebo
Thomson, 1977^129^ | 42 | 49 (45–55) | Piperazin oestrone sulphate 1.5mg twice a day | Placebo | 8 weeks | No difference in depression, anxiety or hot flashes. Improved sleep on estrogen (p<0.05). | Both groups had improvement in depression, anxiety, hot flashes and sleep | Poor
Voss, 2002^120^ | 1008 | 56 | Estradiol 2 mg/day and norethisterone acetate 1 mg/day | 1. Raloxifene 60 mg/day | 6 months | Improved depressed mood with raloxifene vs. estradiol (p=0.004). No differences in anxiety or fears. | | Good
Wheatley, 1977^130^ | 58 | 50 (45–60) | Piperazin oestrone sulphate 1.5 mg twice a day (with amitriptyline) | Placebo (with amitriptyline) | 4 weeks | No difference in depression between groups. | Both groups had improvement in depression. | Poor

Abbreviations

CEE=Conjugated equine estrogens

MMPI=Minnesota Multiphasic Personality Inventory

MPA=Medroxyprogesterone acetate

NETA=Norethindrone acetate

Two of the four good and fair-quality placebo controlled trials reporting between group differences found improved depressive symptoms among women using transdermal estradiol^118^ and oral estradiol with norethindrone acetate.^122^ No differences were found in trials comparing placebo with CEE/medroxyprogesterone acetate (MPA)^121^ or placebo with CEE.^119^ There were no differences in symptoms when comparing estradiol with estradiol valerate^123^ and estradiol with raloxifene.^120^ Another trial indicated improved anxiety with raloxifene vs. CEE, but no differences in depressed mood.^119^

Reduced quality of life. In a systematic review,^15^ four trials of transdermal estradiol,^112,^ ^131–133^ two trials of oral estradiol,^122,^ ^134^ and one trial of esterified estrogens^135^ indicated improved health related quality of life and well-being compared to placebo, as measured by various instruments. In a subanalysis of the WHI that considered women ages 50 to 54 years old who reported moderate to severe vasomotor symptoms at baseline, there was no effect on health-related quality of life measures on the RAND 36-item Health Survey, despite significant improvements in vasomotor symptoms.^116^ A head-to-head comparison of CEE vs. transdermal estradiol utilizing the Menopause Specific Quality of Life Questionnaire indicated improvement in all areas with no significant differences between groups.^136^

#### Progestin/progesterone

A total of 244 abstracts were identified and five randomized controlled trials met inclusion criteria (Table 6),^137–141^ including one rated good-quality,^137^ one fair,^138^ and three poor.^139–141^ Studies included transdermal progesterone,^137,^ ^138^ intramuscular progesterone,^139^ medroxyprogesterone acetate (MPA) tablet,^141^ and MPA injection.^140^

Table 6 Trials of progestins

| | | | | | Main Results
Study, year | N | Mean age (range) | Therapy | Comparison | Duration | Between group differences | Within group differences | Quality
Progesterone
de Wit, 2001^139^ | 10 | 50–72 | Progesterone intramuscular injections 25, 50, or 100 mg weekly | Placebo | 4 weeks | No differences in mood, cognition, or behavior. Higher rating of sluggishness in 100 mg group. | Not reported | Poor
Leonetti, 1998^231^, 1999^138^ | 102 | 52 | Progesterone transdermal cream 20 mg/day | Placebo cream | 12 months in 4 month phases | Improved vasomotor symptoms with progesterone vs. placebo (p<0.001). No differences in depression scores. | Not reported | Fair
Wren, 2003^137^ | 80 | 54 (43–69) | Progesterone transdermal cream 32 mg/day | Placebo cream | 12 weeks | No differences between groups on measures of vasomotor or somatic symptoms, mood, or sexual feelings. | Not reported | Good
Medroxyprogesterone acetate
Morrison, 1980^140^ | 48 | 45 (27–59) | Medroxy-progesterone acetate injection 50 mg, 100 mg, or 150 mg weekly | Placebo injection | 12 weeks | Improved number of hot flashes and subjective symptoms with MPA vs. placebo; higher satisfaction with MPA. | Not reported | Poor
Schiff, 1980^141^ | 27 | 50 (28–67) | Medroxy-progesterone acetate tablet 20 mg/day | Placebo | 12 weeks | Improved hot flashes in MPA vs. placebo (p value not given). | Improved hot flashes in both MPA (74%) and placebo (26%) groups. | Poor

Abbreviations

MPA=Medroxyprogesterone acetate

Two trials of transdermal progesterone report conflicting results. A good-quality trial reported no differences between progesterone (32 mg/day) and placebo groups for vasomotor or somatic symptoms, mood, or sexual feelings as measured on previously validated instruments.^137^ A fair-quality trial of a lower dose (20 mg/day) reported significant reductions in vasomotor symptoms, but not depression scores, with progesterone compared to placebo (83 percent vs. 19 percent; p<0.001).^138^ A poor-quality trial of intramuscular progesterone described small differences between groups, however, the clinical significance of these are unclear.^139^ Two poor-quality trials of MPA did not provide adequate statistical comparisons.^140,^ ^141^

None of the trials reported adverse effects.

#### Androgens

Testosterone. A total of 1,095 abstracts were identified from a search for trials of androgens that included testosterone and dehydroepiandrosterone (DHEA). Of these, 10 trials of testosterone met inclusion criteria including one rated good-quality,^142^ four fair,^144–146,^ ^148^ and five poor^143,^ ^147–149,^ ^151^ (Table 7, Appendix 6-3). Major limitations of studies include few subjects, undefined inclusion and exclusion criteria, use of unclear outcome measures, and using open label rather than double blind methodology. Two additional studies were reported in abstract form and are included only in the evidence table (Appendix 6-3).^152,^ ^153^

Table 7 Trials of Androgens

| | | | | | Main results
Study, year | N | Mean age (range) | Therapy | Comparison | Duration | Between group differences | Within group differences | Quality
Testosterone
Barrett-Connor, 1999^146^ | 311 | 45 (21–65) | 1. Esterified estrogen 0.625 mg/day and MT 1.25 mg/day | 1. CEE 0.625 mg/day | 2 years | Not reported | Improved hot flashes and vaginal dryness in all groups; non-significant trend toward greater improvement in well-being and sexual interest with MT/estrogen; no differences for somatic symptoms (Modified Kupperman Scale). | Fair
| | | 2. Esterified estrogen 1.25 mg/day and MT 2.5 mg/day | 2. CEE 1.25 mg/day
Dobs, 2002^145^ | 40 | 57 (41–76) | Esterified estrogen 1.25 mg/day and MT 2.5 mg/day | Esterified estrogen 1.25 mg/day | 16 weeks | Not reported | Improved symptoms in both groups. Significant improvement with MT/estrogen in hot flashes (Quality of Life Menopause Scale), sexual functioning, and somatic symptoms; no changes in mood and cognition. | Fair
Floter, 2002^150^ | 50 | 54 (45–60) | Estradiol valerate 2 mg/day and testosterone undecanoate 40 mg/day | Estradiol valerate 2 mg/day | 24 weeks cross over | Improved enjoyment of sex, satisfaction with frequency, interest in sex, and total McCoy Sex Scale score with testosterone/estrogen vs. estrogen. No significant different in psychological well-being. | Improved mood (Psychological General Well-Being Index), sexual symptoms (McCoy Sex Scale), and quality of life (Psychological General Well-Being Index) in both groups. | Poor
Hickok, 1993^143^ | 26 | 52 treatment; 50 comparison | Esterified estrogen 0.625 mg/day and MT 1.25 mg/day | Esterified estrogen 0.625 mg/day | 6 months | No differences between groups in hot flash symptom severity, vaginal dryness, sleep problems (4-point menopausal symptom scale). | Improved hot flash symptom severity, vaginal dryness, sleep problems in both groups (4-point menopausal symptom scale). | Poor
Lobo, 2003^142^ | 218 | 53 (40–65) | Esterified estrogen 0.625 mg/day and MT 1.25 mg/day | Esterified estrogen 0.625 mg/day | 4 months | Improved frequency sexual interest/desire, responsiveness and total Sexual Interest Questionnaire score with MT/ estrogen vs. estrogen, p<0.02. | Improved sexual interest/desire, responsiveness, and total Sexual Interest Questionnaire score in both groups, p<0.05. | Good
Penotti, 2001*,^151^ | 40 | 57 treatment; 55 comparison | Estradiol 50 mcg/day transdermal and MPA 10 mg/day for 12 days/month and testosterone undecanoate 40 mg/day | Estradiol 50 mcg/day transdermal and MPA 10 mg/day for 12 days/month | 8 months | No differences between groups in sexual symptoms (Visual Analogue Scores). | Improved sexual desire and satisfaction on Visual Analogue Scale in both groups. | Poor
Raisz, 1996*,^147^ | 18 | 60 treatment; 66 comparison | Esterified estrogen 1.25 mg/day and MT 2.5 mg/day | CEE 1.25 mg/day | 9 weeks | Not reported | Improved psychosomatic and psychological symptoms in MT/estrogen group. Improved hot flashes, vaginal dryness, and somatic symptoms in both groups. (Modified Kupperman with 0–3 scale) | Poor
Shifren, 2000^144^ | 75 | 47 (31–56) | 1. Testosterone 150 mcg/day transdermal and CEE | CEE at various doses (0.625, 0.9, 1.25, 1.8, or 2.5 mg/day) | 36 weeks cross over | Improved composite score (p=0.04), depressed mood (p=0.03), and positive well-being (p=0.04) (Psychological General Well-Being Index), and improved sexual symptoms (Brief Index of Sexual Function for Women) with testosterone 300 mcg/day vs. placebo (p=0.03) | Not reported | Fair
| | | 2. Testosterone 300 mcg/day transdermal and CEE
Simon, 1999^149^ | 93 | 54 | 1. Esterified estrogen 0.625 mg/day and MT 1.25 mg/day | 1. Esterified estrogen 0.625 mg/day | 3 months | Not reported | Improved somatic symptoms, vaginal dryness, and hot flashes in all nonplacebo groups; no effect on sleep or mood (Kupperman Index). No treatment effect for psychosomatic or psychological scores. | Poor
| | | 2. Esterified estrogen 1.25 mg/day and MT 2.5 mg/day | 2. Esterified estrogen 1.25 mg/day
| | | | 3. Placebo
Watts, 1995^148^ | 66 | 21–60 | Esterified estrogen 1.25 mg/d + MT 2.5 mg/day | Esterified estrogen 1.25 mg/day | 2 years | No differences between groups for hot flashes, vaginal dryness, or sleep (modified Kupperman Index with 0–7 scale). | Improved hot flashes, vaginal dryness and sleep in both groups (modified Kupperman Index with 0–7 scale). | Fair
Dehydroepiandrosterone (DHEA)
Barnhart, 1999^154^ | 60 | 48 (45–55) | DHEA 50 mg/day | Placebo | 3 months | No differences between groups in hot flashes, vaginal dryness, sleep, mood, cognition, somatic symptoms, urinary symptoms, sexual symptoms, and quality of life | Improved total symptoms and health-related quality of life in both groups. | Fair
Stomati, 1999^155^ | 22 | 50–55 | 1. DHEAS 50 mg/day | Estradiol 50 mg/day transdermal | 3 months | Not reported | Similar improved Kupperman Index score with all groups (p<0.01). | Poor
| | | 2. DHEAS 50 mg/day and estradiol 50 mg/day transdermal

Abbreviations

CEE=Conjugated equine estrogen

MT=Methyltestosterone

MPA=Medroxyprogesterone acetate

* Open label trial

Trials used methyltestosterone,^142,^ ^143,^ ^145–149^ testosterone undecanoate,^150,^ ^151^ and transdermal testosterone.^144^ All trials combined testosterone with estrogen and compared it head-to-head with estrogen, and two studies compared it with placebo.^144,^ ^149^ Outcomes included sexual dysfunction,^142,^ ^144–146,^ ^150,^ ^151^ hot flashes,^143–149^ mood,^144,^ ^145,^ ^147,^ ^149,^ ^150^ sleep disturbances,^143,^ ^145,^ ^147–149^ vaginal dryness,^143,^ ^146–149^ and quality of life.^144,^ ^145,^ ^150^

Only one good-quality and two fair-quality trials reported statistical comparisons between testosterone/estrogen and estrogen or placebo groups.^142,^ ^143,^ ^144^ One trial indicated no differences between testosterone/estrogen and estrogen alone for hot flash severity, vaginal dryness, or sleep problems.^143^ Sexual interest and responsiveness were improved with testosterone/estrogen compared to estrogen alone based on scores on the Sexual Interest Questionnaire in another trial.^142^ Sexual symptoms were also improved in a trial comparing testosterone/estrogen with placebo.^144^

Adverse effects were reported in all 10 trials. Acne^142,^ ^143,^ ^146,^ ^148^ and hirsutism^146,^ ^148^ occurred significantly more often among women using methyltestosterone/estrogen than with estrogen alone. Adverse effects were not always separated by treatment group, making it difficult to determine which drug was responsible for the reported effect.^144,^ ^149–151^

Dehydroepiandrosterone (DHEA). One fair-quality^154^ and one poor-quality^155^ randomized controlled trial met inclusion criteria (Table 7, Appendix 6-4). Studies were small, lacked clear exclusion criteria,^155^ and had high losses to follow up.^154^

Trials used dehydroepiandrosterone (DHEA)^154^ and dehydroepiandrosterone sulfate (DHEAS)^155^ alone^154,^ ^155^ or combined with transdermal estradiol.^155^ No significant differences between DHEA and placebo were determined on any measures of symptoms including hot flashes, vaginal dryness, insomnia, depression, urinary difficulties, libido, concentration, dizziness, forgetfulness, irritability, aches, anxiety, headaches, and fatigue in the one trial reporting between group differences.^154^

Adverse effects were reported for DHEA only and included paresthesia of an upper extremity.^154^

#### Tibolone

A total of 162 abstracts were reviewed and 20 randomized controlled trials met inclusion criteria (Table 8, Appendix 6-5) including three rated good-quality,^156–158^ four fair,^159–162^ and 13 poor.^163–175^ Four additional studies were reported in abstract form and are included only in the evidence table (Appendix 6-5).^176–179^

Table 8 Trials of tibolone

| | | | | | Main results
Study, year | N | Mean age (range) | Therapy | Comparison | Duration | Between group differences | Within group differences | Quality
Baracat, 2002*,^163^ | 85 | 51 treatment; 53 comparison (45–65) | Tibolone 2.5 mg/day | CEE 0.625 mg/day and MPA 5 mg/day | 12 months | No differences between groups in intensity and mean number hot flashes, sleep, mood, cognition, somatic complaints, and sexual symptoms. | Improved intensity and mean number hot flashes, sleep, mood, cognition, somatic complaints, and sexual symptoms in both groups. | Poor
Benedek-Jaszmann, 1987^164^ | 60 | 44–61 | Tibolone 2.5 mg/day | Placebo | 12 months | Improved hot flashes, irritability, and psychic instability with tibolone vs. placebo. No consistent differences between groups in depression, sleep, somatic complaints. | Not reported | Poor
De Aloysio, 1987*,^165^ | 168 | Not reported | Tibolone 2.5 mg/day | 1. Placebo injection | 4 months | Improved hot flashes with tibolone vs. placebo; no differences between groups for sleep and somatic symptoms. | “Spontaneous symptomatic improvement” of climacteric symptoms in all three groups (no p-value given). | Poor
| | | | 2. No treatment
Egarter, 1996*,^166^ | 129 | 54 | Tibolone 2.5 mg/day | CEE 0.625 mg/day and medrogestone 10 mg/day for 12 days/month | 6 months | No differences between groups in hot flashes, vaginal dryness, sleep, mood, somatic complaints, and sexual symptoms. | Improved hot flashes, vaginal dryness, sleep, mood, somatic complaints, and sexual symptoms in both groups (Kupperman Index). | Poor
Hammar, 1998^159^ | 437 | 55 | Tibolone 2.5 mg/day | Estradiol 2 mg/day and NETA 1 mg/day | 48 weeks | Improved hot flushes with estrogen/NETA vs. tibolone (p<0.001); no differences between groups in sweating episodes or vaginal dryness; tibolone group had less vaginal bleeding. | Improved hot flushes, sweating episodes, and vaginal dryness in both groups (5 point symptoms scale). | Fair
Huber, 2002^160^ | 501 | 55 | Tibolone 2.5 mg/day | CEE 0.625 mg/day and MPA 5 mg/day | 1 year | No difference between groups in total Greene Climacteric Score, or vaginal or urinary symptoms; vasomotor subscore slightly more improved with CEE/MPA vs. tibolone. Reduced vaginal bleeding and improved sexual interest, drive, and/or performance in tibolone group. | Improved total Greene Climacteric Score in both groups. Improvement in vaginal and urinary symptoms in both groups. | Fair
Hudita, 2003^167^ | 162 | 56 (40–65) | 1. Tibolone 1.25 mg/day | Placebo | 24 weeks | Improved hot flashes, vaginal dryness, and sexual symptoms with both doses of tibolone vs. placebo; greater improvement in hot flashes and vaginal dryness with 2.5 mg vs. 1.25 mg doses (Modified McCoy Sex Scale, menopausal symptoms scale). Increased bleeding with both doses of tibolone. | Improved hot flash and vaginal dryness in both tibolone groups, not in placebo. | Poor
| | | 2. Tibolone 2.5 mg/day
Lam, 2004^156^ | 100 | 50 | Tibolone 2.5 mg/day | Placebo | 6 months in each arm | Improved somatic complaints in tibolone group. No difference in total Greene Climacteric Score or any other subscales. | Improved vasomotor, urogenital, and sexual subscores in both groups; improved mood and somatic complaints in tibolone group; (Greene Climacteric Scale, General Health Questionnaire, Dyadic Adjustment Scale). No change in psychological well-being in either group. | Good
Landgren, 2002^168^ | 775 | 52 (40–60) | 1. Tibolone 0.625 mg/day | Placebo | 12 weeks | Improved frequency of hot flashes and sweating at 1.25 mg, 2.5 mg, and 5.0 mg doses of tibolone vs. placebo (Collins and Landgren Rating Scale). Dose related vaginal bleeding. | Not reported | Poor
| | | 2. Tibolone 1.25 mg/day
| | | 3. Tibolone 2.5 mg/day
| | | 4. Tibolone 5 mg/day
Lloyd, 2000^161^ | 29 | 61 | Tibolone 2.5 mg/day | Placebo | 6 months | No differences between groups in quality of life (General Health Questionnaire). | Not reported | Fair
Meeuwsen, 2002^157^ | 85 | 54 | Tibolone 2.5 mg/day | Placebo | 1 year | Improved hot flashes and sleep with tibolone vs. placebo (p<0.05); no differences between groups for mood, energy, pain, social isolation, urinary symptoms, or quality of life (Nottingham Health Profile). Increased vaginal bleeding with tibolone. | Not reported | Good
Mendoza, 2000*,^169^ | 76 | <50 | Tibolone 2.5 mg/day | Estradiol 50 mcg/day transdermal | 1 year | No differences between groups in hot flashes, mood, and sexual symptoms (Kupperman Index). | Improved hot flashes, mood, and sexual symptoms in both groups (no p-values given for within group comparisons). | Poor
Mendoza, 2002*,^170^ | 165 | 50 | Tibolone 2.5 mg/day | 1. Estradiol 50 mcg/day transdermal and progesterone 200 mg twice weekly | 1 year | No differences between groups for hot flashes, sleep, mood, cognition, somatic symptoms, and sexual symptoms. | Improved hot flashes in both groups (Modified Kupperman Index). | Poor
| | | | 2. Estradiol 50 mcg/day transdermal for 14 days, then Estradiol 50 mcg/day transdermal and NETA 0.25 mg/day for 14 days
Nathorst-Böös, 1997^171^ | 437 | >53 | Tibolone 2.5 mg/day | Estradiol 2 mg/day and NETA 1 mg/day | 48 weeks | Improved sexual frequency, satisfaction, and enjoyment with tibolone vs. estradiol/NETA (p<0.05); (McCoy Sex Scale; Swedish version). | Improved sexual frequency, pain, and vaginal dryness in both groups. Improvement in other sexual symptoms in tibolone. | Poor
Palacios, 1995*,^172^ | 28 | 50–60 | Tibolone 2.5 mg/day | Calcium 500 mg/day | 12 months | Improved sexual symptom score with tibolone vs. placebo (p<0.05) (10 item questionnaire scored on a 7 point scale). | Improved sexual symptom score in tibolone group. | Poor
Ross, 1999^162^ | 36 | 52 (45–65) | Tibolone 2.5 mg/day | CEE 0.625 mg/day and norgestrol 150 mg/day for 12 days of cycle | 3 months | No differences between groups for hot flashes, mood, cognition, somatic symptoms, uterine bleeding, and sexual symptoms (Women's Health Questionnaire, Irritability, Depression, and Anxiety, Greene Climacteric Scale). | Not reported | Fair
Volpe, 1986^173^ | 113 | Not reported | Tibolone 2.5 mg/day | 1. Placebo | 6 months | Not reported. | Improved hot flashes in all treatment groups (4 point scale). | Poor
| | | | 2. CE 0.625 mg/day for 21 days/mo and NETA 5 mg/day for 10 days/mo
| | | | 2. CE 0.625 mg/day for 21days/mo and CPA 12.5 mg/day for 10 days/mo
| | | | 3. Estradiol valerate 2 mg/day for 21 days/mo and NETA 5 mg/day for 10 days/mo
| | | | 4. Estradiol valerate 2 mg/day for 21 days/mo and CPA 12.5 mg/day for 10 days/mo
| | | | 5. Estriol 2–4 mg/day
Winkler, 2000^158^ | 60 | 54 (45–70) | Tibolone 2.5 mg/day | 1. Estradiol 2 mg/day and Estriol 1 mg/day and NETA 1 mg/day | 24 weeks | No differences between groups in hot flashes and vaginal dryness (Karolinska Scale). | Improved hot flashes and vaginal dryness in all treatment groups. (Karolinska Scale) | Good
Wu, 2001*,^174^ | 48 | 51 (38–56) | Tibolone 2.5 mg/day | CEE 0.625 mg/day and MPA 5 mg/day | 3 months | Improved sexuality with tibolone. No differences between groups in hot flashes, mood, and somatic complaints. | Climacteric symptoms, quality of life, and sexuality improved in (McCoy Sex Scale, Greene Climacteric Scale) both groups. | Poor
Yang, 1999*,^175^ | 40 | 51 | Tibolone 2.5 mg/day | CEE 0.625 and MPA 5 mg/day 12 days/month | 6 months | No differences between groups in hot flashes, mood, cognition, somatic complaints, and sexual symptoms. | Improved hot flashes, mood, cognition, somatic complaints, and sexual symptoms in both groups (Greene Climacteric Scale). | Poor

Abbreviations

CE=Conjugated estrogen

CEE =Conjugated equine estrogen

CPA=Cyproterone acetate

MPA=Medroxyprogesterone acetate

NETA=Norethidrone acetate

* Not a double-blind study (single blind or open).

Trials compared tibolone with estrogen alone,^169^ estrogen combined with progestin or progesterone,^158–160,^ ^162,^ ^163,^ ^166,^ ^170,^ ^171,^ ^173–175^or placebo.^156,^ ^157,^ ^161,^ ^164,^ ^165,^ ^167,^ ^168,^ ^172^ Outcomes included hot flashes, sexual dysfunction, mood, uterine bleeding, somatic complaints, vaginal dryness, sleep disturbance, cognitive effects, urinary complaints, and quality of life.

Three good or fair-quality trials reported between group differences for tibolone and placebo.^156,^ ^157,^ ^161^ Results indicated improved hot flashes,^157^ sleep,^157^ and somatic complaints^156^ with tibolone, but no differences between groups in Greene Climacteric Score,^156^ quality of life,^157,^ ^161^ or mood, energy, pain, social isolation, or urinary symptoms.^157^

Four good or fair-quality trials reported between group differences for tibolone and estrogen alone or estrogen combined with progestin or progesterone.^158–160^ ^162^ Two trials indicated improved hot flashes with estrogen compared to tibolone.^159,^ ^160^ Sexual interest, drive, and/or performance were improved with tibolone compared to CEE/MPA in another trial.^160^ No differences between groups were determined for several other menopause related symptoms.^158–160,^ ^162^

Uterine bleeding was increased with tibolone in four trials,^157,^ ^167,^ ^168,^ ^180^ decreased in two,^159,^ ^167^ and was not significantly changed in four others.^158,^ ^162,^ ^163,^ ^174^ Uterine bleeding was dose related in two studies.^168,^ ^180^ Adverse effects that occurred significantly more often among women using tibolone than placebo were reported in 16 of 20 trials and included body pain,^156,^ ^160,^ ^163,^ ^164,^ ^166,^ ^170,^ ^174,^ ^175^ weight gain,^156,^ ^158,^ ^160,^ ^164,^ ^166,^ ^169,^ ^175^ and headache.^156,^ ^160,^ ^163,^ ^166,^ ^167,^ ^170^ Four studies did not report adverse effects.^162,^ ^171–173^

#### Antidepressant drugs

A total of 184 abstracts were reviewed and eight randomized controlled trials met inclusion criteria including one trial rated good-quality,^181^ three fair,^182,^ ^183,^ ^188^ and four poor^184–187^ (Table 9, Appendix 6-6). Trials used paroxetine,^181^ venlafaxine,^183^ moclobemide,^188^ and veralipride.^182,^ ^184–187^ Most studies were limited by small sample sizes, short durations of follow-up, lack of follow-up data, inadequate descriptions of inclusion criteria, and, in one trial, lack of blinding.^187^

Table 9 Trials of antidepressant drugs

| | | | | | Main results
Study, year | N | Mean age (range) | Therapy | Comparison | Duration | Between group differences | Within group differences | Quality
David, 1988^186^ | 50 | 32–81 | Veralipride 100 mg/day | Placebo | Four 20 day courses | Not reported | Improved hot flash frequency and severity with veralipride (p=0.01). | Poor
Evans 2005^183^ | 80 | 51 | Venlafaxine XR, 37.5mg/day for 1 week, then 75mg/day | Placebo | 12 weeks | No difference in hot flash frequency or severity as measured by daily diaries. Greater reduction in “self-perceived hot flash score” in venlafaxine group. (p<0.001; single item on interference of hot flash with daily living). Greater improvement in mood and vitality in venlafaxine group (p=0.005; SF-36 scales). | Both groups noted to have improved hot flash severity scores. (No p-value reported.) | Fair
Limouzine-Lamothe, 1994*,^187^ | 499 | Not reported | Veralipride 100 mg/day first 20 days of each month | Estraderm TTS 50 transdermal and chlormandinon first 12 days of each month | 6 months | Improved numbers of hot flashes in estrogen vs. veralipride group (41% vs. 81%; p<0.001). Improved measures of quality of life, sleep, sexual function, depression, anxiety, general psychological well being, somatic complaints, cognitive difficulties, social life, family life, professional life, and vitality with estrogen vs. veralipride (Women's Health Questionnaire, Psychological General Well-Being Index, Sleep Problems Questionnaire, Sexual Behavior Questionnaire, symptom scale). | Not reported | Poor
Melis, 1988^184^ | 40 | 48–56 | Veralipride 100 mg/day | Placebo | 30 days | Improved hot flash composite score with veralipride vs. placebo (66% vs. 26%; p<0.5); more women noted improvement with veralipride vs. placebo (85% vs. 50%; p<0.05). | Both groups showed improvement in hot flash composite score (placebo p<0.05; veralipride p<0.01). | Poor
Stearns, 2003^181^ | 165 | >35 | Paroxetine 12.5 mg/day or 25 mg/day | Placebo | 6 weeks | Improved mean hot flash frequency with paroxetine 25 mg and 12.5 mg vs. placebo (3.2 and 3.3 vs. 1.8; p=0.01); improved composite score with paroxetine vs. placebo (65% and 62% vs. 38%; p=0.03) (daily hot flash composite score, Greene Climacteric Scale 21). No differences in sleep, depression, anxiety, sexual interest, or disability (Visual Analogue Scale, Beck Anxiety Inventory II, Sheehan Disability Scale, Clinical Global Impression). | Not reported | Good
Tarim, 2002^188^ | 30 | 51 (35–55) | Moclobemide 150 mg/day or 300 mg/day | Placebo | 5 weeks | Not reported | All groups had decreased hot flash composite scores (67% moclobemide 150 mg/day, 35% moclobemide 300 mg/day, 24% placebo). | Fair
Wesel, 1984^182^ | 43 | 40–60 | Veralipride 100 mg/day | CEE 1.25 mg/day | 20 days | No differences between groups in hot flash frequency or composite score. | Improved hot flash frequency and composite score in both groups. | Fair
Zichella, 1986^185^ | 75 | 45–55 | Veralipride 100 mg/day | Placebo | 20 days | Improved hot flash composite score with veralipride vs. placebo (-2.3 vs. -0.6; p<0.5). | Improved hot flash composite score with veralipride (p<0.001) and placebo (p<0.05) | Poor

Abbreviations

CEE=Conjugated equine estrogen

* Non blinded trial

Selective serotonin reuptake inhibitors (SSRIs). A good-quality trial of paroxetine reported statistically significant reductions in mean hot flash frequency and hot flash composite score at two doses compared with placebo.^181^ No differences were detected in sleep, depression, anxiety, sexual interest, disability, or side effects.^181^ A fair-quality trial of venlafaxine reported improvement on a single item measuring how significantly hot flashes interfered with daily activities compared to placebo, but no differences in hot flash frequency or severity as measured on daily diaries.^183^ The venlafaxine group also had improved mood and vitality compared with placebo.^183^ Other trials of SSRIs enrolled women with breast cancer and are described below.

Moclobemide. A fair-quality trial evaluating two doses of moclobemide showed reduced hot flash composite scores with moclobemide at both doses, although comparisons with placebo were not reported.^188^ This trial was further limited by including only 30 participants and lasting only five weeks.

Veralipride. Veralipride, an antidopaminergic drug, was evaluated in five trials; one rated fair-quality^182^ and four poor-quality.^184–187^ Two poor-quality trials comparing veralipride to placebo reported reduced rates of hot flashes with veralipride.^184,^ ^185^ Of the two studies comparing veralipride to estrogen, a poor-quality trial found that veralipride had less benefit,^187^ and a fair-quality trial found it to be equivalent.^182^

In four of the five studies, the side effects of mastodynia and/or galactorrhea occurred more frequently in the veralipride group.

#### Other Drugs

A total of 51 abstracts were identified and 15 randomized controlled trials met inclusion criteria (Appendix 6-7). Trials used clonidine,^128,^ ^189–197^ gabapentin,^198^ methyldopa,^199–201^ and Bellergal Retard.^202^ Major limitations of trials include few subjects, lack of clear inclusion and exclusion criteria, high attrition or loss to follow up, no washout period in crossover trials, lack of data for pre-crossover comparisons, and short treatment duration.

Clonidine. Clonidine was compared to placebo in eight trials,^189–195,^ ^197^ and compared to other active drugs in trials with lisuride, sodium valproate, transdermal estradiol,^195^ and CEE and medrogestone^128,^ ^196^ (Table 10). Two trials were rated fair-quality,^189,^ ^192^ and eight were poor.^128,^ ^190,^ ^191,^ ^193–197^ Outcomes included hot flashes, insomnia, and mood symptoms.

Table 10 Trials of Clonidine

| | | | | | Main results
Study, year | N | Mean age (range) | Therapy | Comparison | Duration | Between group differences | Within group differences | Quality
Bolli, 1975^190^† | 20 | 51 | 1. Clonidine tablet 0.0375 mg twice daily | Placebo crossover | 2 weeks each phase | No differences between groups in mean number of hot flashes or subjective measures of severity and duration. Results same for both doses. | Reduction in number of hot flashes was significant in both the 0.075 mg twice daily (p<0.02) and the placebo (p<0.05) groups. | Poor
| | | 2. Clonidine tablet 0.075 mg twice daily
Clayden, 1974^189^ | 100 | 50 (41–62) | Clonidine tablet 0.025 mg twice daily; increased if needed to maximum 0.075 mg twice daily | Placebo crossover | 4 weeks each phase | Prior to crossover: no differences between groups in mean change in number of hot flashes. After crossover: improved subjective scores of hot flash severity (p=0.05) and duration (p=0.01) for clonidine first only. | Greater reduction in hot flashes while on clonidine first (p<0.05) or second (p<0.001). Improved subjective scores of hot flash severity (p=0.05) and duration (p=0.01) with clonidine first. | Fair
Edington, 1980^193^† | 93 | 47 (27–71) | Clonidine tablet 0.05 mg twice daily | Placebo crossover | 4 weeks each phase | Improved mean number of flushing episodes (averaged over all 4 trials) with clonidine vs. placebo (p<0.05). | | Poor
Gerdes, 1982^128^ (Same as Sonnendecker 1980) | 38 | Not reported | Clonidine tablet 0.050 mg twice daily for 28 days + placebo tablets for CEE and medrogestone | CEE 1.25 mg daily for 21 days + medrogestone 5 mg daily from day 16 to 21 + placebo for clonidine | 20 weeks | Improved depression score (Mini-Biography Questionnaire, p<0.01) and moodiness (p<0.05) with CEE vs. clonidine; no difference in moodiness with clonidine vs. placebo. | Improved scores for depression and anxiety (p<0.05) in the estrogen group only. | Fair-Poor
Lindsay, 1978^191^ | 100 | 46 (35–60) | Clonidine tablet 0.050 mg twice daily; increased if needed to maximum of 0.05 mg three times daily | Placebo crossover | 6 weeks each phase | No differences between groups in hot flashes (Blatt Menopausal Index, flushing attacks scale) or psychological symptoms (Kellner and Sheffield Scale). | | Poor
Nagamani, 1987^197^ | 30 | 41 (25–58) | Clonidine transdermal 0.1 mg/day, patch changed weekly | Placebo | 8 weeks | No differences between groups in mean reduction in hot flashes (diary) at weeks 4 and 8.* More women in the clonidine group reported improvement on subjective measures of frequency (p<0.04), severity (p<0.04), and duration (p<0.03). | Significant decrease in mean number of hot flashes for both clonidine (p=0.002) and placebo (p=0.04) at week 8. | Fair-Poor
Nappi, 1991^195^ | 35 | 44 (30–50) | Clonidine tablet 0.075 mg twice daily | 1. Sodium valproate tablet 200 mg twice daily | 4 weeks | Improved hot flash frequency and intensity in the estradiol, clonidine, and lisuride vs. placebo groups (p<0.01). | | Poor
| | | | 2. Lisuride tablet 0.2 mg twice daily
| | | | 3. Transdermal 17B estradiol 0.050 mg daily
| | | | 4. Placebo
Salmi, 1979^192^ | 40 | 51 (41–57) | Clonidine tablet 0.025 mg twice daily; increased if needed to maximum 0.075 mg twice daily | Placebo crossover | 6 weeks each phase | No differences between groups in frequency of hot flushes, insomnia, depression or anxiety. | | Fair-Poor
Sonnendecker, 1980^196^ | 38 | Not reported | Clonidine tablet 0.050 mg twice daily for 28 days + placebo tablets for CEE and medrogestone | CEE 1.25 mg daily for 21 days + medrogestone 5 mg daily from day 16 to 21 + placebo for clonidine | 20 weeks | No differences between groups in reduction of number of hot flashes. | Number of daily hot flashes decreased significantly in the CEE group (p<0.05) but not in the clonidine group. | Fair-Poor
Wren, 1986^194^† | 19 | 51 (46–56) | Clonidine tablet 0.05 mg twice daily | Placebo crossover | 4 weeks | No differences between groups in mean number of hot flashes. | No change in tiredness, insomnia, anxiety, panic and irritability with clonidine. | Fair-Poor

Abbreviations

CEE=Conjugated equine estrogen

* Calculated p-value; not reported in study

† Pre-crossover data not reported

Of the trials for which pre-crossover statistics were provided or could be calculated, there were no statistically significant differences between clonidine and placebo in the improvement of hot flash symptoms.^189,^ ^191,^ ^192^ In the non-crossover placebo controlled trials, one trial reported that clonidine was more effective than placebo in reducing hot flash frequency and intensity,^195^ and the other found no differences between groups in number of hot flashes, although women on clonidine were significantly more likely to report a decrease in subjective frequency, severity, and duration of hot flashes.^197^ Of the 3 remaining crossover studies reporting only summary statistics,^190,^ ^193,^ ^194^ one trial demonstrated that clonidine was more effective than placebo in reducing the number of hot flashes and improving subjective hot flash measures.^193^ Two head-to-head trials found that estrogen, not clonidine, effectively decreased the number of hot flashes and improved measures of depression and anxiety.^128,^ ^196^ Two trials found no differences between clonidine and placebo in measures of psychological symptoms,^191,^ ^192^ and one found no difference in frequency of insomnia.^192^

Adverse effects were reported in six of 10 trials; dry mouth occurred more frequently in women taking clonidine than placebo,^189,^ ^191,^ ^193^ and blood pressure was not affected by clonidine.^189,^ ^190,^ ^192–194,^ ^197^

Methyldopa. Three crossover trials, two rated fair-quality^200,^ ^201^ and one poor,^199^ compared methyldopa with placebo (Table 11). All trials provided pre-crossover statistics regarding improvement in hot flash frequency and none found significant differences between groups. A fair-quality study reporting post-crossover data separately found that methyldopa was more effective than placebo in reducing the number of hot flashes and improving Visual Analog Scores after crossover.^201^

Table 11 Trials of methyldopa, Bellergal, and gabapentin

| | | | | | Main results
Study, year | N | Mean age (range) | Therapy | Comparison | Duration | Between group differences | Within group differences | Quality
Andersen, 1986^199^ | 40 | 51 (46–60) | Methyldopa 375 mg nightly; increased by 1 tablet every 2 weeks as needed to maximum dose of 1,125 mg nightly | Placebo crossover | Up to 8 weeks each phase | No differences between groups in median number of hot flashes; women on methyldopa felt less troubled by hot flashes (Visual Analogue Scale) vs. placebo (p<0.05). | Number of hot flashes improved for both placebo (12/19) and methyldopa (14/17). | Poor
Bergmans, 1987^202^ | 71 | Not reported | Bellergal Retard 1 tablet twice daily (0.6 mg ergotamine, 40 mg phenobarbital, 0.2 mg levorotatory alkaloids) | Placebo | 8 weeks | No differences between groups at week 8 in mean number and severity of hot flashes, sweating, or any other symptom. | For both groups significant improvement was noted in hot flashes, sweating, insomnia, hyperirritability, and nervousness (p<0.05). Headache, paresthesia and dizziness improved on Bellergal and loss of libido improved on placebo (p<0.05). | Poor
Guttuso, 2003^198^ | 59 | 53 | Gabapentin 300 mg three times daily | Placebo | 12 weeks | Improved hot flash frequency at weeks 4 (p=0.03) and 12 (p=0.02), composite score at weeks 4 (p=0.01) and 12 (p=0.01), and sleep (Pittsburgh Sleep Quality Index) at week 4 (p=0.01) for gabapentin vs. placebo group. No differences between groups in Profile of Mood States score, quality of life (Short Form-36 Health Survey), or Patient Global Impression of Change Scale. | | Good
Hammond, 1984^200^ | 10 | 46 (36–54) | Methyldopa 250 mg twice daily; increased after one week to 3 times daily | Placebo crossover | 4 weeks each phase | No difference between placebo and methyldopa in mean decrease in number of hot flashes prior to crossover. | Improved hot flashes with methyldopa and placebo in the first phase but only for methyldopa (p<0.02) during the second phase. | Fair
Nesheim, 1981^201^ | 40 | Not reported | Methyldopa 250 mg twice daily; increased if needed to maximum of 500 mg twice daily | Placebo crossover | 30 days each phase | Improved hot flash frequency in methyldopa vs. placebo group in the second phase (p=0.01) but not the first (p=0.06); improved Visual Analogue Score in methyldopa vs. placebo group (p=0.002). | Significant reduction in hot flashes with methyldopa (p<0.05). | Fair

All trials noted substantially more adverse effects with methyldopa than placebo. Fatigue or drowsiness, dizziness, and dry mouth occurred more often among women using methyldopa than placebo. One patient on methyldopa developed a lupus-like rash.^200^ No significant changes in blood pressure were noted,^199,^ ^201^ however, one study reported orthostatic hypotension in one patient.^200^

Gabapentin. In a good-quality study comparing gabapentin to placebo, hot flash frequency and a composite menopause symptom score were significantly improved with gabapentin (Table 11).^198^ No significant differences in mood, quality of life, Patient Global Impression of Change scores, and sleep quality were detected.^198^

Gabapentin use reduced levels of albumin, total protein, total bilirubin, blood urea nitrogen, and platelets compared to placebo. Somnolence, dizziness, rash, and peripheral edema were reported for gabapentin but not placebo. Fifty percent of the gabapentin group and 28 percent of the placebo group reported at least one adverse event.

Bellergal. One poor-quality trial compared Bellergal Retard, a combination of 0.6 mg ergotamine, 40 mg phenobarbital, and 0.2 mg levorotatory alkaloids, with placebo (Table 11).^20^ There were no statistically significant differences between Bellergal and placebo in measures of vasomotor symptoms, insomnia, nervousness, hyperirritability, headache, paresthesia, loss of libido, and dizziness.

Adverse effects were similar between groups and included dry mouth, dizziness, and sleepiness.

#### Phytoestrogens

A total of 195 abstracts were identified and 21 randomized controlled trials met inclusion criteria (Table 12, Appendix 6-8). Trials used dietary soy isoflavones,^203–213^ soy isoflavone extracts,^214–218^ other forms of phytoestrogens,^219–223^ and phytoestrogens combined with other agents.^224^ Eight additional studies were reported in abstract form and are included only in the evidence table (Appendix 6-8).^225–232^

Table 12 Trials of phytoestrogens and isoflavones

| | | | | | Main results
Study, year | N | Mean age (range) | Therapy | Comparison | Duration | Between group differences | Within group differences | Quality
Soy isoflavones—dietary
Albertazzi, 1998^203^, 1999^204^ | 104 | 53 (48–61) | Soy powder 60 grams (76 mg isoflavones) | 60 grams casein powder | 12 weeks | Improved hot flash frequency with soy vs. casein at 12 weeks (p<0.01); no differences between groups on Kupperman Index. | Improved hot flash frequency in both groups (44% reduction with soy, 31% with placebo); no changes in Kupperman Index. | Fair
Balk, 2002^205^ | 27 | 57 soy; 58 placebo | Soy and corn flour cereal (100 mg/day isoflavones) | Wheat cereal (Grapenuts) | 6 months | No differences between groups in hot flushes, night sweats, palpitations, headache, depression, vaginal dryness, or decreased libido over 6 months (Menopause Symptoms Questionnaire); soy group had greater insomnia than placebo (p=0.017). | Improved hot flashes, night sweats, and vaginal dryness with placebo (p<0.05). | Poor
Burke, 2003^206^ | 241 | 51 (45–55) | 1. Soy drink with 42 mg/day isoflavones | Soy drink with isoflavones removed | 24 months | No differences between groups in frequency and severity of hot flashes and night sweats (self-reported symptom diary). | Improved hot flash frequency and severity in all groups (p<0.0001). | Fair
| | | 2. Soy drink with 58 mg/day isoflavones
Dalais, 1998^208^ | 52 | 54 soy; 55 linseed; 54 wheat; (45–65) | 1. Soy diet (high in isoflavones) | Wheat diet (low in isoflavones) cross over | 12 weeks each phase | Not reported | Improved rate of hot flushes (diary) with linseed diet (41% decrease) or wheat diet (51% decrease), but not soy. | Poor
| | | 2. Linseed diet (high in isoflavones)
Han, 2002^207^ | 82 | 48 isoflavone; 49 placebo; (45–55) | Soy isoflavone (50 mg soy protein and 33 mg isoflavones) | Placebo | 5 months | Not reported | Improved hot flashes, insomnia, mood, and Kupperman Index scores in soy group. | Fair
Knight, 2001^212^ | 24 | 52 soy; 54 placebo; (40–65) | Soy isoflavone powder beverage 60 g/day (134.4 mg/day isoflavones) | Casein powder | 12 weeks | No differences between groups in flushing frequency or Greene Menopause Symptom Scores. | Improved flushing frequency in both groups. | Fair
Murkies, 1995^209^ | 58 | 54 soy; 56 wheat | Soy flour 45 grams/day | Wheat flour 45 grams/day | 14 weeks | No differences between groups for hot flashes and general symptom scores. | Improved hot flashes and general symptom scores in both groups at 12 weeks (p<0.05). | Fair
Penotti, 2003^210^ | 62 | 53 (45–60) | Soy tablet (36 mg/day isoflavone and 48 mg/day soy saponine) | Placebo | 6 months | No difference between groups in hot flashes (hot flush daily dairy) | 40% reduction in hot flashes overall in both groups. | Fair
St. Germain, 2001^211^ | 69 | 42–62 | 1. Soy protein (80 mg/day isoflavone) | Placebo (whey protein) | 24 weeks | No differences between groups in hot flush frequency or severity, mood, vaginal dryness, urinary or sexual symptoms (Menopausal Index). | Improved hot flashes in all groups (p=0.03). | Fair
| | | 2. Soy protein (4.4 mg/day isoflavone)
Washburn, 1999^213^ | 51 | 51 (45–55) | 1. Soy protein 20 grams (34 mg/day phytoestrogen) | Placebo | 6 weeks | Improved severity of hot flashes (diary) with soy vs. placebo (p<0.001); hypoestrogenic symptom score was improved with soy vs. placebo (p<0.05); no differences in number of hot flushes, night sweats, sleep disturbance, or general health score. | | Poor
| | | 2. Soy protein 20 grams (34 mg/day phytoestrogens) in 2 doses
Soy isoflavones—extract
Duffy, 2003^215^ | 36 | 59 soy; 57 placebo; (50–65) | Soy isoflavone supplement (60 mg/day) | Placebo | 12 weeks | No differences between groups on the Greene Climacteric Score or mood. Improved memory with soy vs. placebo (delayed recall of pictures, p<0.03; immediate story recall, p<0.06; reversal of the simple discrimination rule, p=0.05;improved time to learn complex tasks, p<0.05). | No changes in menopausal symptoms. | Fair
Faure, 2002^216^ | 75 | 53 soy; 54 placebo | Soy isoflavone extract (70 mg genistin/daidzin/ day) | Placebo | 16 weeks | Improved hot flush frequency (diary) with soy vs. placebo (p=0.01);no effect on other symptoms (not described). | Improved hot flushes in soy (61% reduction) and placebo groups (21% reduction). | Fair
Kritz-Silverstein, 2003^214^ | 56 | 61 (55–74) | Soy extracted supplement (isoflavone 100 mg/day) | Placebo | 6 months | Improved cognitive test (category fluency) for soy vs. placebo (p=0.05); no differences between groups for 2 tests of verbal memory and Trails B test. | Improved cognitive tests for both groups. | Fair
Scambia, 2000^217^ | 39 | 54 soy; 53 placebo; (29–63) | Soy extract (400 mg/day with 50 mg/day isoflavone) followed by CEE 0.625 mg/day for 4 weeks | Placebo followed by CEE 0.625 mg/day for 4 weeks | 12 weeks | Improved mean number of hot flushes/week (score card) and Greene Climacteric Scale score with soy vs. placebo at 6 weeks (p<0.01). | Improved hot flushes with CEE in both groups. | Poor
Upmalis, 2000 ^218^ | 177 | 55 soy; 54 placebo | Soy isoflavone extract tablet 50 mg/day | Placebo | 12 weeks | Improved average hot flush severity (diary) with soy vs. placebo (p=0.01); no difference in frequency of night sweats. | Improved hot flushes and night sweats in both groups. | Fair
Phytoestrogens
Brzezinski, 1997^219^ | 145 | 54 phyto-estrogen; 51 placebo; (43–65) | Phytoestrogen rich diet (tofu, soy drink, miso, flax seed, approx 182 mg daidzein, 255 mg genistein, 4 mg lignans) | Regular Israeli diet | 12 weeks | Improved hot flush severity (p=0.004) and vaginal dryness severity (p=0.005) with phytoestrogen vs. control; no difference in Menopause Symptom Questionnaire score. | Both groups improved on the Menopause Symptom Questionnaire score. | Poor
Carranza-Lira, 2001^220^ | 30 | 52 phyto-estrogen, 51 placebo | Phytoestrogen cream (4 mg/day) | Placebo (identical cold cream) | 1 month | No differences in Kupperman Index score between groups. | Improved Kupperman Index score in both groups (p<0.001). | Poor
Crisafulli, 2004^221^ | 90 | 52 genistein; 52 estrogen proges-terone treatment; 51 placebo; (47–57) | Genistein (54 mg/day) | 1. Placebo | 1 year | Genistein group, hot flush score decreased by 22% vs. placebo at 3 months (p<0.01), 29% at 6 months (p<0.001), and 24% at 12 months (p<0.01). Estrogen group, hot flush score decreased by 53% vs. placebo at 3 months (p<0.001) and maintained at 6 and 12 months. Improvement with estrogen greater than genistein at all measurements (p<0.05). | | Fair
| | | | 2. Estradiol (1 mg/day) combined with noresthisterone
Komesaroff, 2001^222^ | 50 | 54 (45–60) | Wild yam cream preparation (Biogest, one teaspoonful twice daily to arms, legs or abdomen) | Placebo cross over | 3 months | No differences between groups (diary) including flushing frequency, severity, mood, breast tenderness, libido, and energy level. | Improved flushing, symptom score, and energy in both groups; improved mood with yam cream. | Poor
Sammartino, 2003*,^223^ | 70 | 51 | Genistein 36 mg/day | Placebo | 12 months | Improved Kupperman Index score with genistein vs. placebo (p<0.05). | Improved Kupperman Index score with genistein (p<0.05). | Fair
Combinations
Russo, 2003^224^ | 50 | 53 (48–54) | Soy based isoflavones (80 mg/day) with C. racemosa (black cohosh) (30 mg/day) | Placebo | 3 months | Improved hot flush symptoms (questionnaire) in treatment vs. placebo group (p<0.05). | | Poor

Abbreviations

CEE=Conjugated equine estrogen

* Not double blinded (open).

Soy isoflavones—dietary. Dietary forms of soy isoflavones were compared to placebo in 10 trials (Table 12) that included soy powder,^203,^ ^204,^ ^211,^ ^213^ cereal,^205^ drink,^206,^ ^212^ diet,^208,^ ^211^ flour,^209^ and tablets.^207,^ ^210^ Of these, seven were rated fair-quality,^203,^ ^204,^ ^206,^ ^207,^ ^209–212^ and three poor.^205,^ ^208,^ ^213^ Outcomes included hot flashes, sleep, mood or depression, vaginal dryness, sexual symptoms, scores on symptoms scales, and single trials reporting palpitations, headaches, and general health.

Of the eight trials providing between group comparisons, one fair-quality and one poor-quality trial reported improved hot flashes with soy compared to placebo^203,^ ^204,^ ^213^ and six reported no differences.^205,^ ^206,^ ^209–212^ A fair-quality trial of soy powder reported improved hot flash frequency with soy compared to placebo (44 percent vs. 31 percent, p<0.01), but no differences between groups on the Kupperman Index.^203,^ ^204^ A poor-quality trial of soy protein tablets indicated improved severity of hot flashes and improved hypoestrogenic symptoms score with soy, but no differences in number of hot flushes, night sweats, sleep disturbance, or general health score.^213^ In most trials, hot flashes improved in both soy and placebo groups,^203,^ ^204,^ ^206,^ ^209–212^ although in two trials rated poor-quality, the placebo group reported improved symptoms while the soy group did not.^205,^ ^208^

Soy isoflavones—extract. Soy isoflavone extracts were compared to placebo in five trials (Table 12), including four rated fair-quality,^214–216,^ ^218^ and one poor.^217^ Outcomes included hot flashes, cognitive tests, scores on the Greene Climacteric Index, and mood.

Of the three trials providing between group comparisons and hot flash outcomes, all reported improved hot flash frequency^216,^ ^217^ or severity^218^ with soy compared to placebo, and one trial reported no differences in frequency of night sweats.^218^ The Greene Climacteric Scale score was improved with soy compared to placebo in one trial,^217^ but not the other.^215^ Performance on cognitive tests, including tests of memory, improved with soy compared to placebo in the two trials evaluating this outcome.^214,^ ^215^ Mood was not improved with soy in one trial.^215^

A trial reporting adverse effects of isoflavones indicated an increased rate of endometrial hyperplasia after five years of using 150 mg/day of isoflavone soy supplement.^233^

Other phytoestrogens. Phytoestrogens were compared to placebo in five trials (Table 12), including two rated fair-quality^221,^ ^223^ and three poor.^219,^ ^220,^ ^222^ Trials included diet,^219^ topical cream,^220,^ ^222^ and genistein tablets.^221,^ ^223^ One trial included a comparison group using estradiol and noresthisterone.^221^ Outcomes included hot flashes in all trials, vaginal dryness, scores on menopausal symptom scales, mood, sexual symptoms, and energy level.

Three of five trials providing between group comparisons and hot flash outcomes reported improved hot flash severity^219^ or score^221,^ ^223^ with phytoestrogen compared to placebo. Two trials reported no differences compared to placebo in frequency and severity of hot flashes^222^ or Kupperman Index score,^223^ and another indicated that the hot flash score was better with estradiol and noresthisterone than genistein.^221^ Vaginal dryness was improved with phytoestrogen diet in one trial,^219^ but there were no significant differences in overall symptom scores.^219^ A trial of wild yam cream found no differences in mood, libido, or energy level.^222^

Combinations. A poor-quality trial of soy based isoflavones combined with C. racemosa (black cohosh) reported improved hot flush symptoms with treatment compared to placebo, as reported on a questionnaire.^224^

#### Complementary and Alternative Medicine

A total of 1,237 abstracts were identified and 28 randomized controlled trials met inclusion criteria (Table 13, Appendix 6-8). Trials used acupuncture,^234–236^ Chinese herbs,^237–242^ red clover,^243–248^ black cohosh,^249^ combinations,^250^ other supplements,^251–259^ manual therapies,^260^ and energy therapies.^261^ Four trials were reported in abstract form and are included only in the evidence table (Appendix 6-8).^227,^ ^231,^ ^262,^ ^263^

Table 13 Trials of complementary and alternative therapies

| | | | | | Main results
Study, year | N | Mean age (range) | Therapy | Comparison | Duration | Between group differences | Within group differences | Quality
Acupuncture
Cohen, 2003^234^ | 18 | 47 (43–53) | 6 acupuncture treatments specific to menopausal symptoms | 6 general tonic acupuncture treatments (shen mein) | 9 weeks | Not reported | Improved mean monthly hot flush severity (diary) at 2, 3, and 4 months in treatment; month 4 in control. Improved sleep disturbance in both groups. Improved mood change in treatment, not control. | Poor
Sandberg, 2002^235^ | 30 | 54 (48–60) | 14 electro-acupuncture treatments specific to menopausal symptoms | Superficial needle insertion (sham) | 12 weeks | Treatment group mood (MOOD Scale) improved vs. control at 8 (p=0.05) and 12 weeks (p=0.01). No differences in climacteric or well-being between groups. | Improved mood (MOOD Scale) in treatment group; climacteric symptoms (Visual Analog Scale) and well-being (SCL-50) improved in both groups. | Poor
Wyon, 1995^236^ | 24 | 54 (47–62) | 10 electro-acupuncture (2 Hz) treatments specific to menopausal symptoms over 8 weeks | Superficial needle insertion (sham) | 8 weeks | No differences between groups on any measure. | Number of flushes/day (logbook) decreased in both groups; climacteric symptoms (Visual Analogue Scale) decreased in treatment group, not control; Kupperman Index improved for both groups; no change in well-being for either group. | Poor
Wyon, 2004^264^ | 45 | 51–55 (43–59) | 14 electro-acupuncture treatments specific to menopausal symptoms | Superficial needle insertion (sham) vs. conjugated estrogen 0.625 mg/day | 12 weeks | For flushes, more pronounced effect in estrogen group vs. electro-acupuncture (p<0.001). | All three groups had significant improvement in Kupperman Index, Visual Analogue Scale and self-reported daily symptom diary. | Fair
Chinese herbs
Chen, 2002^235^ | 62 | 50–52 (45–65) | Chinese herbs (JWSYS=a collection of thirteen herbs) | CEE 0.625 mg/day and MPA 2.5 mg/day | 16 weeks | No differences between groups in total symptom score, anxiety, depression, somatic symptoms, and vasomotor symptoms (Greene Climacteric Score). Improved sexual symptoms with CEE/MPA vs. JWSYS (p<0.05). | Improved psychological and somatic measures in both groups (Greene Climacteric Score). | Poor
Davis, 2001^238^ | 78 | 54–56 (45–70) | Chinese medicinal 12 herb formula | Placebo | 12 weeks | No differences between groups in vasomotor symptoms (daily diary) or Menopause Specific Quality of Life Questionnaire scores. Those having previously not used natural therapies for menopausal symptoms showed improved physical, vasomotor, and sexual domains compared to placebo (p<0.05). | Improved vasomotor symptoms (daily diary) and Menopause Specific Quality of Life Questionnaire scores in both groups. | Poor
Hartley, 2003^239^ | 34 | 58–59 (53–65) | Ginseng; ginkgo tablet 120 mg/day containing 25% ginkgo flavonoids and 6% terpenoids | Placebo | 1 week | No difference between groups on menopausal symptoms, mood, or sleepiness (Greene Climacteric Scale). No difference on 7 of 8 memory tests. Improved non-verbal memory and sustained attention in treatment group. | Improved symptoms (Greene Climacteric Scale) in both groups (p<0.001). | Poor
Hirata, 1997^240^ | 71 | 52 (44–69) | 4.5 grams/day of dong quai from root material | Placebo | 24 weeks | No differences in symptoms between groups (Kupperman Index). | Improved symptoms (Kupperman Index) in both groups (p<0.0001). | Fair
Wiklund, 1999^241^ | 384 | 53–54 (45–65) | Standardized ginseng extract (Ginsana, containing 100 mg of the standardized ginseng extract G115; 2 capsules/day) | Placebo | 16 weeks | Improved depression, well-being, and health scores with ginseng vs. placebo (p<0.05) (Psychological General Well Being index). No differences between groups on Women's Health Questionnaire, Visual Analog Scale, or hot flushes. | Improved vasomotor symptoms and sleep in both groups. | Fair
Woo, 2003^242^ | 136 | 56–57 (50–65) | Pueraria lobata (PL) (a traditional Chinese herbal remedy) and isoflavone 100 mg/day | 1. Placebo | 3 months | No differences between groups in menopausal symptoms or well being measures. No differences in word finding or rate of learning. | No differences of well being. | Fair
| | | | 2. CEE 0.625 mg/day and MPA 5 mg/day during second 14 days of the month | | CEE or PL vs. placebo: Cognitive tests and digital symbol improvement for both treatments (p<0.05).
| | | | | | PL vs. placebo: Flexible thinking improved for PL group (p<0.05).
| | | | | | CEE vs. placebo: Motor skills worsened in the CEE group.
Red clover
Atkinson, 2004^243^ | 205 | 55 (49–65) | Red clover isoflavone tablet (Promensil) 40 mg/day | Placebo | 12 months | No differences between groups in number of hot flushes or menopausal symptoms score (diary). | Improved number of hot flashes and symptoms score in both groups. | Fair
Baber, 1999^244^ | 51 | 45–65 | Red clover isoflavone tablet (Promensil) 40 mg/day | Placebo | 7 months cross-over | No differences in symptoms between groups (Greene Climacteric Score, hot flush frequency). | Improved symptoms in both groups (Greene Climacteric Score, hot flush frequency). | Fair
Jeri, 2002^245^ | 30 | 51–52 | Red clover isoflavone tablet (Promensil) 40 mg/day | Placebo | 16 weeks | Not reported | Improved frequency and severity of hot flushes in treatment group (p<0.001). | Fair
Knight, 1999^246^ | 37 | 54.5 (40–65) | 1. Red clover isoflavone tablet (Promensil) 40 mg/day | Placebo | 12 weeks | No differences between groups in flushing frequency or Greene Climacteric Scale. | Flushing frequency decreased in all groups. | Poor
| | | 2. Red clover isoflavone tablet (Promensil) 160 mg/day
Tice, 2003^247^ | 252 | 52 (45–60) | 1. Red clover isoflavone tablet (Promensil) 82 mg isoflavones/day | Placebo | 12 weeks | No differences between groups in Greene Climacteric Scale or number of hot flushes (p<0.001). Reduction in hot flashes was faster for Promensil compared to placebo (p=.03). | Improved Greene Climacteric Scale and number of hot flushes in all groups. | Good
| | | 2. Red clover isoflavone tablet (Rimostil) 57 mg isoflavones/day
van de Weijer, 2002^248^ | 30 | 53–54 (49–65) | Red clover isoflavone tablet (Promensil) 80 mg/day | Placebo | 12 weeks | Improved hot flushes with isoflavone vs. placebo (p=0.0154); no difference in Greene Climacteric Scale score. | Improved hot flushes in isoflavone group; no change in Greene Climacteric Scale score. | Fair
Black cohosh
Wuttke, 2003^249^ | 62 | 40–60 | C. racemosa preparation (CR BNO 1055;Klimadynon/Menofem) 40 mg herbal drug/day | 1. Placebo | 12 weeks | Improved hot flushes (menopause rating scale) with estrogen vs. placebo (p=0.046). | Improved symptoms for all groups (menopausal rating scale). | Fair
| | | | 2. Conjugated estrogen 0.6 mg/day
Combinations
Hudson, 1998^250^ | 13 | Not reported | Botanical formula 500 mg 2 capsules three times per day (combined dry herb including burdock root [2 parts], licorice root [2 parts], motherwort [1 part], Dong Quai root [2 parts] and Mexican wild yam root [1 part]) | Placebo | 3 months | No differences between groups in number and severity of hot flashes (diary). | Improved number and severity of hot flashes for both groups (diary). | Poor
Other supplements
Bellipanni, 2001^251^ | 79 | 42–62 | Melatonin 3 mg/day | Placebo | 6 months | Improved mood and morning depression (questionnaire) in melatonin vs. placebo group (p<0.05);no differences between groups for other symptoms. | | Poor
Blatt, 1953^252^ | 748 | Not reported | 1. Vitamin E 50–100 mg 3 times daily | Placebo | 3 years | Not reported | Improved hot flash symptoms with CEE and ethinyl estradiol (67% of women), phenobarbital (24%), Vitamin E (13%), and placebo (16%). | Poor
| | | 2. Ethinyl estradiol 0.05 mg/day
| | | 3. CEE 1.25 mg/day
| | | 4. Phenobarbital 15 mg 3 times daily
Bygdeman, 1996*,^256^ | 39 | 58 (43–76) | Vaginal moisturizer (Replens) 3 times per week | Dienoestrol vaginal cream 0.5 mg/day for 2 weeks, then 3 times per week | 3 months | Improved vaginal dryness index with dienoestrol vs. moisturizer (p=0.0001). | Improved vaginal dryness index in both groups. | Poor
Cagnacci, 2003^253^ | 80 | 50–52 (47–53) | 1. Kava kava 100 mg/day + calcium 1g/day | Calcium 1g/day | 3 months | Improved anxiety with treatment vs. placebo; no differences between groups in Greene Climacteric Score or depression score. | Improved Greene Climacteric Score, anxiety, and depression score in both treatment groups. | Fair
| | | 2. Kava kava 200 mg/day + calcium 1g/day
Chenoy, 1994^254^ | 56 | 54 (45–67) | Evening primrose oil (gamolenic acid) 2,000 mg/day with natural vitamin E 10 mg/day | Placebo | 6 months | Improved maximum number of daytime hot flushes (diary) with placebo vs. treatment (p<0.05). | | Poor
Makkonen, 1993^255^ | 30 | 52–54 (44–60) | Guar gum 5 grams three times daily | Placebo | 6 months | No differences between groups in Kupperman Index scores. | Improved Kupperman Index scores in both groups (p<0.001). | Poor
Nachtigall, 1994*,^257^ | 30 | Not reported | Vaginal moisturizer (Replens) 3 times/week | CEE vaginal cream 2 grams/day | 12 weeks | Not reported | Improved vaginal elasticity, pH, fluid volume, and moisture in both groups. | Poor
Rachev, 2001^258^ | 64 | 50–52 (41–59) | Phospholipid liposomes (Liposom Forte) 28 mg/2ml intramuscular injection every other day | Placebo injection every other day | 60 days | Improved climacteric index (p=0.0013) and anxiety (Hamilton Anxiety Scale) (p<0.001) with treatment vs. placebo. | Improved climacteric index and anxiety for both groups (p<0.001 for both). | Fair
Salmaggi, 1993^259^ | 80 | 51 (45–59) | S-adenosyl-L-methionine (SAMe) 1600 mg/day | Placebo | 30 days | Improved depression in treatment vs. placebo group (Hamilton Depression Rating Scale; Rome Depression Inventory; Clinical Global Impression Improvement Scale; Psychoasthenia Scale of the MMPI). | | Poor
Manual therapies
Cleary, 1994^260^ | 30 | 50–60 | Low force osteopathic manipulation of pelvis, spine, and cranium | Sham low force touch in similar areas | 10 weeks treatment | Improved hot flushes and night sweats (questionnaire), urinary frequency, depression, and insomnia in treatment vs. control group. | | Fair
Energy therapies
Williamson, 2002^261^ | 80 | 50.8 (45–60) | Reflexology with 9 sessions over 19 weeks | Standard foot massage | 9 sessions of treatment over 19 weeks | No differences between groups in severity of hot flushes and night sweats (Women's Health Questionnaire, Visual Analogue Scale, and a self-completed measure of quality of life). | | Poor

Abbreviations

MPA=Medroxyprogesterone acetate

CEE=Conjugated equine estrogen

MMPI = Minnesota Multiphasic Personality Inventory

* Not double blind study (open).

Acupuncture. Four small trials compared a series of acupuncture treatments specific to menopausal symptoms with alternate nonspecific acupuncture procedures (Table 13).^234–236,^ ^264^ Of these, one trial was rated fair-quality^264^ and three poor.^234–236^ The fair-quality trial found no differences between groups in any measures,^236^ while a poor-quality study reported improved mood in the treatment group, but no differences in menopausal symptoms or well-being.^235^ A poor-quality trial compared acupuncture treatment specific to menopausal symptoms to both nonspecific acupuncture and estrogen and found a more pronounced improvement in hot flashes with estrogen than acupuncture.^264^

Chinese herbs. Three fair-quality trials^240–242^ and three poor-quality trials^237–239^ of Chinese herbs met criteria for this review. Five trials compared herbs against placebo^238–242^ and two against CEE/MPA^237,^ ^242^ (Table 13). Treatments included specific formulations of herbs,^237,^ ^238^ ginseng,^239,^ ^241^ dong quai,^240^ and an herbal remedy (pueraria lobata) combined with isoflavone.^242^ Outcomes included hot flashes and other vasomotor symptoms, mood and depression, well-being and quality of life, memory, somatic symptoms, sexual symptoms, and general health. Studies were small, had short durations, and included highly selected populations.

A fair-quality trial comparing ginseng with placebo reported significant improvements for depression, well-being, and health scores on the Psychological General Well Being Index, but no differences in hot flashes or scores on other instruments.^241^ Results of two other fair-quality placebo controlled trials indicated no differences between groups for menopausal symptoms,^240,^ ^242^ well-being,^240,^ ^242^ or rate of learning.^242^

Red clover. Red clover isoflavone tablets (Promensil and Rimostil) were compared against placebo in six trials (Table 13) including one rated good-quality,^247^ four fair,^243–245,^ ^248^ and one poor.^246^ Outcomes included hot flashes and other vasomotor symptoms including measures from the Greene Climacteric Scale. One of five trials reporting between group comparisons indicated improved hot flashes with treatment compared to placebo,^248^ and no trials reported differences in scores on the Greene Climacteric Scale or symptom diary.^243,^ ^244,^ ^246–248^

A good-quality meta-analysis of 25 trials of phytoestrogens for treatment of menopausal symptoms included an analysis of red clover using five of the six studies in this review.^244–248^ Results of the meta-analysis indicated no significant differences in hot flash frequency between treatment and placebo groups (weighted mean difference -0.60; 95 percent CI, -1.71 to 0.51).^18^

Black cohosh. One fair-quality trial compared C. racemosa preparation (black cohosh) with estrogen and placebo (Table 13).^249^ Between group comparisons indicated improved hot flushes with estrogen vs. placebo only.

Combinations. A small poor-quality trial of a botanical formula (burdock root, licorice root, motherwort, dong quai, and wild yam) compared with placebo indicated no differences between groups in the number and severity of hot flashes (Table 13).^250^ Results indicated a significant decrease in the total number of other types of symptoms after three months of therapy for the botanical formula group compared to placebo (p<0.03).^250^

Other supplements. Nine trials evaluated effects of other forms of supplements including melatonin,^251^ vitamin E,^252^ kavakava,^253^ evening primrose oil with vitamin E,^254^ guar gum,^255^ vaginal moisturizer,^256,^ ^257^ phospohlipid liposome injections,^258^ and S-adenosyl-L-methionine^259^ (Table 13). Of these, two trials were rated fair-quality^253,^ ^258^ and seven poor.^251,^ ^252,^ ^254–257,^ ^259^ Outcomes included hot flashes, mood or depression, vaginal dryness, and scores on symptom scales.

Between group differences for placebo controlled trials indicated improved symptoms with treatment compared to placebo for mood or depression (melatonin, S-adenosyl-L-methionine),^251,^ ^259^ anxiety (kavakava, phospholipids liposomes),^253,^ ^258^ and scores on symptom scales (phospholipid liposomes).^258^ No differences between groups were found for hot flashes (guar gum),^255^ mood or depression (kavakava),^253^ and scores on symptom scales (kavakava).^253^ In a poor-quality trial of evening primrose oil, hot flashes were significantly improved with placebo compared to treatment.^254^ A poor-quality trial comparing vaginal moisturizer against dienoestrol vaginal cream reported improved vaginal dryness with dienoestrol.^256^

Manual therapies. A fair-quality trial of low force osteopathic manipulation of the pelvis, spine, and cranium was compared against sham low force touch in similar areas (Table 13).^260^ After 10 weeks of therapy, results indicated improved hot flashes and nights sweats, urinary frequency, depression, and insomnia with treatment compared with placebo.^260^

Energy therapies. A poor-quality trial of women undergoing nine sessions of reflexology provided over 19 weeks resulted in no differences in severity of hot flashes and night sweats or measures of health and well-being compared to women receiving standard foot massages (Table 13).^261^

#### Behavioral Interventions

A total of 436 abstracts were identified and eight randomized controlled trials met inclusion criteria (Table 14, Appendix 6-8). Trials consisted of exercise,^265–267^ relaxation, ^268–270^ low frequency sound wave audiotape,^271^ and education interventions.^272^ Of these, three trials were rated fair-quality,^265,^ ^267,^ ^272^ and five poor.^266,^ ^268–271^ One additional trial was reported in abstract form and is included only in the evidence table (Appendix 6-8).^226^

Table 14 Trials of behavioral interventions

| | | | | | Main results
Study, year | N | Mean age (range) | Therapy | Comparison | Duration | Between group differences | Within group differences | Quality
Aiello, 2004^265^ | 173 | 61 | Aerobic exercise 225 minutes/week | Stretching 45 minutes/week | 12 months | No differences between groups in hot flash frequency, sleep, depressive mood, or cognitive function. A subset of women with recent menopause showed improved memory in aerobic vs. stretching group. | Not reported | Fair
Freedman, 1995^268^ | 24 | 53 | Paced respiration training in 8 1-hour biweekly treatment sessions | Alpha-EEG biofeedback in 8 1-hour biweekly treatment sessions | 4 weeks | Not reported | Decreased hot flash frequency for the pacedrespiration group (p<0.001) but not for the alpha wave feedback group. | Poor
Germaine, 1984^270^ | 14 | 50 (44–61) | Progressive muscle relaxation in 6 1-hour weekly trainings | Alpha-EEG biofeedback in 6 1-hour weekly trainings | 6 months | Improved time for onset of hot flush (p<0.01) (physiological laboratory testing) in progressive muscle relaxation vs. biofeedback group. | Reduced hot flash frequency in relaxation group at 6 month follow-up (p<0.01). | Poor
Hunter, 1999^272^ | 86 | Over 50 | Health/ menopause and stress relief education | Usual care | 5 year follow-up | Control group more likely to contribute aches and pains to menopause than intervention group (p<0.01). No differences between groups on mood, health, vaginal dryness or sexual relationships. Knowledge of menopause increased in the intervention group. | Improved maintenance of knowledge, less concern with menopause, more exercise, and less estrogen use in intervention group. More women in the control group lost interest in sex. | Fair
Irvin, 1996^269^ | 45 | 49–53 (44–66) | Relaxation (diaphragmatic breathing 20 minutes/day) and charting hot flashes | 1. Reading and charting hot flashes | 10 weeks | Not reported | Significant improvement in hot flash intensity, tension/anxiety, and depression for the relaxation group (p<0.05). Reduction in trait anxiety and confusion in reading group (p<0.05). No differences in hot flash frequency in any groups. No changes in control group. | Poor
| | | | 2. Charting hot flashes only
Lindh-Astrand, 2004^266^ | 30 | 51–54 (48–63) | Exercise 3 sessions/ week | 1. Estradiol 2 mg/day for 12 weeks minimum | 38 weeks | Not reported | Improved hot flushes, Kupperman Index, symptom list, Visual Analogue Score, and Mood Scale with estrogen; improved Kupperman Index, symptom list, and Visual Analogue Score with exercise. | Poor
| | | | 2. Wait listed controls
Rankin, 1989^271^ | 40 | 49 (40–58) | Low frequency sound wave audiotape; 20 minutes 3 times/week for 2 weeks | Usual care | 2 weeks | No differences between groups in menopausal, somatic, and psychological symptoms. | Improved frequency of menopausal (Neugarten-Kraines Menopausal Index Scale), somatic, and psychological symptoms with sound waves in menopausal group. | Poor
Teoman, 2004^267^ | 81 | 51 (45–65) | Aerobic exercise 3 times/week | Usual care (taking hormone therapy) | 6 weeks | Improved quality of life measures (Nottingham Health Profile) in exercise vs. control group. | Exercise group showed changes in quality of life; no changes for control group. | Fair

Exercise. Two fair-quality studies evaluated the effects of aerobic exercise using comparison groups that underwent stretching activities^265^ or received usual care^267^ (Table 14). Outcomes included hot flashes and other vasomotor symptoms, mood and depression, cognitive function, sleep, well-being, and quality of life. Results of one trial indicated no differences in outcomes in the exercise group compared to the stretching group.^265^ A subset of women categorized as recently entering menopause showed improved memory in the aerobic vs. stretching group. ^265^ In a trial of exercise compared to usual care, exercisers showed significantly improved quality of life on the Nottingham Health Profile.^267^

Other Interventions. A fair-quality trial compared health education with usual care and found no differences between groups for measures of mood, health, vaginal dryness, or sexual relationships.^272^ Knowledge of menopause increased in the intervention group, while the control group was more likely to attribute symptoms to menopause.^272^ Other trials rated poor-quality due to limitations in methods and/or small numbers of subjects evaluated biofeedback, relaxation, paced respiration, and use of audiotapes (Table 14).

## Summary

Results of trials of therapies providing between group comparisons are summarized in Table 15. Although benefits and adverse effects of therapies were equally important in this review, most trials did not report adverse effects or reported them incompletely. Studies of estrogen provided the most information. It is unclear how applicable the adverse effects reported from other larger estrogen trials, such as the Women's Health Initiative (WHI), are for younger, symptomatic women taking estrogen for brief periods.^104^ For women in the WHI who reported having menopausal symptoms, strokes and coronary heat disease events were not significantly elevated.^273,^ ^274^ Other important adverse outcomes, such as breast cancer, thrombosis, and gall bladder disease, have not been reported by age and symptom status in this trial.

Table 15 Summary of benefits of therapies

| Total number of trials | | | | | Number of trials reporting benefit/total number of trials
| | | Quality rating | | | Hot flashes | | | Other symptoms
Therapy | Included in report | Reported comparisons | Good | Fair | Poor | Improved vs. placebo | Improved or same vs. other therapy | Other therapy | Improved vs. placebo | Improved or same vs. other therapy | Other therapy
Estrogen
Vasomotor symptoms*
Estradiol (oral) | 10 | 10 | 10 | | | 9/10
Estradiol (transdermal) | 11 | 11 | 11 | | | 11/11
Conjugated equine estrogen | 8 | 8 | 8 | | | 8/8
Urogenital symptoms* | 9 | 9 | 9 | | | | | | 3/4 | 5/5 | E
Sexual function* | 11 | 11 | 11 | | | | | | 3/6 | 5/5 | E
Sleep* | 3 | 3 | 3 | | | | | | 2/3
Mood and depression | 13 | 10 | 3 | 3 | 4 | | | | 4/8 | 1/3 | R, C
Quality of life* | 9 | 9 | 9 | | | | | | 7/8 | 1/1 | E
Progestin
Progesterone | 3 | 3 | 1 | 1 | 1 | 1/2 | | | 0/3
Medroxyprogesterone acetate | 2 | 2 | | | 2 | 2/2 | | | 1/2
Androgen
Testosterone with estrogen | 10 | 6 | 1 | 4 | 1 | | 2/2 | E | 1/1 | 5/5 | E +/- P
Dehydroepiandrosterone | 2 | 1 | | 1 | | 0/1 | | | 0/1
Tibolone | 20 | 19 | 3 | 4 | 12 | 5/5 | 8/10 | E +/- P | 6/7 | 11/11 | E +/- P
Antidepressants
Paroxetine | 1 | 1 | 1 | | | 1/1 | | | 0/1
Moclobemide | 1 | 0
Venlafaxine | 1 | 1 | | 1 | | 0/1 | | | 1/1
Veralipride | 5 | 4 | | 1 | 3 | 2/2 | 1/2 | E +/- P | 1/2 | 0/1 | E +/- P
Other Drugs
Clonidine | 10 | 10 | | 1 | 9 | 3/8 | 1/2 | E + P | | 0/1 | E + P
Methyldopa | 3 | 3 | | 2 | 1 | 1/3
Gabapentin | 1 | 1 | 1 | | | 1/1 | | | 0/1
Bellergal | 1 | 1 | | | 1 | 0/1 | | | 1/1
Phytoestrogens
Soy isoflavones—dietary | 10 | 8 | | 6 | 2 | 2/8 | | | 1/5
Soy isoflavones—extracts | 5 | 5 | | 4 | 1 | 3/3 | | | 2/2
Phytoestrogen | 5 | 5 | | 2 | 3 | 4/5 | 0/1 | E + P | 1/2
Combinations | 1 | 1 | | | 1 | 1/1
Complementary and Alternative Medicine
Acupuncture | 4 | 3 | | 1 | 2 | 0/3 | 0/1 | E | 1/3
Chinese herbs | 6 | 6 | | 3 | 3 | 0/5 | 2/2 | E + P | 3/4 | 2/2 | E + P
Red clover | 6 | 5 | 1 | 3 | 1 | 1/5 | | | 0/5
Black cohosh | 1 | 1 | | 1 | | 0/1 | 0/1 | E
Combinations | 1 | 1 | | | 1 | 0/1 | | | 1/1
Other supplements | 9 | 7 | | 2 | 5 | 2/4 | | | 3/3 | 0/1 | E
Manual therapies | 1 | 1 | | 1 | | 1/1 | | | 1/1
Energy therapies | 1 | 1 | | | 1 | 0/1 | | | 0/1
Behavioral Interventions | 8 | 5 | | 3 | 2 | 0/5 | 1/3 | | 1/4

Abbreviations

E=Estrogen

P=Progestin

R=Raloxifene

C=Clonidine

* Trials from published systematic reviews^15,^ ^17^

Main findings from trials of therapies include:

- Estrogen, in either opposed or unopposed regimens, is the most consistently effective therapy for vasomotor symptoms, and demonstrates benefit in most trials evaluating urogenital symptoms. Some, but not all, trials evaluating sleep, mood and depression, sexual function, and quality of life outcomes also report benefit with estrogen compared to placebo.
- Breast tenderness and uterine bleeding are the most commonly reported adverse outcomes in estrogen trials; others include nausea and vomiting, headache, weight change, dizziness, venous thromboembolic events, cardiovascular events, rash and pruritus, cholecystitis, and liver effects.
- Trials of progestin indicate mixed results for treatment of vasomotor symptoms.
- Few trials of testosterone are available; one trial indicated no differences between testosterone/estrogen and estrogen alone for hot flash severity, vaginal dryness, or sleep problems. Sexual symptoms were improved with testosterone/estrogen compared to estrogen alone or placebo in two other trials.
- For women using testosterone combined with estrogen, acne and hirsutism occur significantly more often than for women using estrogen alone.
- Based on only a few fair or good-quality trials, tibolone demonstrated benefit for vasomotor symptoms, sleep, and somatic complaints compared to placebo, and was similar to estrogen for some, but not all, symptoms.
- Uterine bleeding, body pain, weight gain, and headache were more common in tibolone vs. placebo groups.
- Several agents demonstrate benefits in managing vasomotor symptoms in some, but not all trials, or in only a few available trials, including paroxetine, veralipride, gabapentin, soy isoflavones, and other phytoestrogens.
- Trials of soy isoflavones and other complementary and alternative medicine therapies report benefits in improving nonvasomotor symptoms, although results vary widely, methods are lacking, and studies are typically small and not generalizable.
- Placebo effects in trials are large reflecting underlying fluctuations of symptoms.

## Key Question 4. Therapies for Women with Specific Characteristics

### What are the important considerations in managing menopause-related symptoms in women with clinical characteristics or circumstances that may complicate decision-making?

#### Bilateral Oophorectomy

A large number of studies reported data on women with bilateral oophorectomies, but did not stratify results by this characteristic.^142,^ ^144–148,^ ^150,^ ^163,^ ^165,^ ^169,^ ^173,^ ^181,^ ^188,^ ^192,^ ^193,^ ^195,^ ^197,^ ^217,^ ^242,^ ^256^ Trials of estrogen that exclusively enrolled women with oophorectomies to take unopposed estrogen reported similar improvements in vasomotor symptoms as trials of women without oophorectomies taking opposed estrogen.^16^

#### Premature Ovarian Failure

Only one trial of soy isoflavones considered premature ovarian failure, but results were not reported specifically for women with this condition.^217^

#### Breast Cancer

A total of 200 abstracts were identified and 15 randomized controlled trials met inclusion criteria (Table 16, Appendix 6-9).^275–289^ Of these, 3 trials were rated good-quality,^278,^ ^280,^ ^285^ 10 fair,^275–277,^ ^279,^ ^281–284,^ ^287,^ ^288^ and 2 poor.^286,^ ^289^ Major limitations of trials include small size, lack of sufficient detail regarding recruitment and randomization, non blinding, and lack of intention-to-treat analyses. Two studies recruited women who either had a history of breast cancer or a perceived increased risk of breast cancer,^282,^ ^283^ and all other trials included women who had prior diagnoses of breast cancer but no residual disease and who were no longer receiving chemotherapy or radiation. Most studies included women taking tamoxifen, although tamoxifen-users represented varying proportions of the study populations (31 percent to 100 percent). Results for tamoxifen-users were presented separately in only one trial,^276^ and in three trials, all women were taking tamoxifen.^284–286^ Study designs did not allow ascertainment of whether treatments were addressing a side effect of tamoxifen therapy^284–286^ or vasomotor symptoms that occur naturally in women with a history of breast cancer. All studies recruited women from breast cancer clinics.

Table 16 Trials in women with breast cancer

| | | | | | Main results
Study, year | N | Population | Therapy | Comparison | Duration | Between group differences | Within group differences | Quality
Barton, 1998^275^ | 125 | 18 and older with previous breast cancer; 54% taking tamoxifen | Vitamin E succinate 800 IU daily | Placebo crossover | 4 weeks each phase | Prior to cross-over and in summary: No differences between groups in hot flash frequency or severity (diary questionnaire). | Improvements within groups were not significant. | Fair
Carpenter, 2002^289^ | 15 | 18 and older with previous breast cancer | 6 magnetic devices attached to participants' skin over acupuncture/acupressure sites used to balance energy and treat hot flashes | Placebo crossover; placebo was identical but blinding not effective because of magnet properties | 72 hours + 2 days follow-up each phase | Summary statistics: Improved hot flash frequency with placebo (10.5 to 6.6) vs. magnet (9.6 to 8.3) (p=0.02); improved “bothersome” hot flashes with placebo (4.4 to 3.2) vs. magnets (4.2 to 4.1) (p=0.02). No differences between groups for hot flash severity, interference scale, or overall quality of life. | | Poor
Ganz, 2000^287^ | 76 | Mean age 54.5; all have breast cancer; 56% taking tamoxifen | Counseling by nurse practitioner, tailored therapy, and support. Therapy includes any of the following: hot flashes—bellergal, clonidine patch, megestrol; behavioral symptoms—slow abdominal breathing; vaginal dryness—moisturizer or lubricant; urinary symptoms—Kegel's, Replens, phenylpropanolamine; psychosocial—referral for counseling or group support. | Usual care | 4 months | Improved adjusted mean change in menopause symptoms (p=0.0004) and adjusted mean change in sexual functioning with intervention vs. usual care (p=0.04); no differences between groups for vitality score. | | Fair
Goldberg, 1994^284^ | 116 | 54 (30–76); all have breast cancer and taking tamoxifen | Clonidine transdermal 0.1 mg/day | Placebo cross over | 4 weeks each phase | Prior to cross-over: Improved median hot flash frequency (p<0.04), severity (p<0.03), and score (p<0.04) for clonidine vs. placebo. Summary statistics: No difference between clonidine and placebo for hot flash frequency, severity or score. Patients preferred clonidine vs. placebo (p=0.02). | | Fair
Hernandez Munoz, 2003^286^ | 136 | >35 years; all have estrogen receptor positive breast cancer and taking tamoxifen | Black cohosh 20 mg one tablet twice daily | Usual care | 60 day | Improved hot flashes with treatment (47% free of hot flashes) vs. usual care (0% free of hot flashes) (p<0.01). | | Poor
Jacobson, 2001^276^ | 85 | 18 and older; all have breast cancer; 69% taking tamoxifen | Black cohosh 1 tablet twice daily | Placebo | 60 days | Improved sweating in black cohosh vs. placebo group (p=0.04). No differences between groups in mean number of hot flashes, hot flash severity, sleep, irritability, nervousness, depression, headaches, and palpitations. | Improved sleep, irritability, nervousness, depression, headaches, palpitations, excessive sweating in both groups; global rating of well being did not change in either group. | Fair
Loprinzi, 1994^280^ | 97 | Women with history of breast cancer; | Megestrol acetate 20 mg twice daily. | Placebo cross-over | 4 weeks each phase | Prior to cross-over: Improved hot flash frequency (26% of baseline for megestrol vs. 73% of baseline for placebo, p<0.001). Improved median hot flash score (17% of baseline for megestrol vs. 73% of baseline for placebo, p<0.001). Reduction of 50% in hot flash frequency: 71% of megestrol group vs. 24% of placebo group, p<0.001. From baseline hot flash frequency of 6.1 hot flashes/day (range 0.9–21.4). | | Good
Loprinzi, 1997^281^ | 52 | Women ≥ 18 with history of breast cancer and persistent vaginal dryness and/or itching for > 2 months | Polycarbophil-based vaginal moisturizer | Placebo (water-soluble lubricating) | 4 weeks each phase | Not reported | Vaginal dryness scores improved in both groups (decreased by 64% in Replens group and 62% in placebo group after 4 wks, p=0.3). | Fair
| | | | | | | Dyspareunia scores decreased in both groups after 4 wks: 60% in Replens group and 41% in placebo group, p=0.05.
Loprinzi, 2000^282^ | 229 | Women >18 with have breast cancer or perceived high risk; 69% taking tamoxifen | Venlafaxine 37.5 mg/day, 75 mg/day, 150 mg/day | Placebo | 4 weeks each phase | Prior to cross-over: Improved hot flash frequency and score with all doses of venlafaxine vs. placebo (p<0.001); improved quality of life with venlafaxine vs. placebo (p=0.02). No differences between groups in depression score or libido. | | Fair
Loprinzi, 2002^283^ | 87 | 18 and older; have breast cancer or perceived high risk; 54% taking tamoxifen | Fluoxetine 20 mg/day | Placebo crossover | 4 weeks each phase | Prior to cross-over: Fewer reports of trouble sleeping sleep with fluoxetine vs. placebo (p=0.03). No significant decrease in hot flash frequency (p=0.54) or score (p=0.35). | | Fair
| | | | | | Summary statistics: Improved hot flash frequency (p=0.01), hot flash score (p=0.02) with combined data at end of both cross over periods; No overall differences between groups for sleep, quality of life, depression, or libido.
Nikander, 2003^279^ | 62 | Mean age 54 (35–69); all have breast cancer; 5% had used tamoxifen>5 months prior | Phytoestrogen tablet 114 mg; 3 twice daily | Placebo crossover | 3 months each phase | Prior to cross-over: No differences between groups in Kupperman Index, or hot flashes. | Improved Kupperman Index in both groups; improved hot flash intensity with placebo; no effect on anxiety, working ability, or self confidence in either group. | Fair
Pandya, 2000^285^ | 198 | Mean age 53–55 (35–77); all have breast cancer and taking tamoxifen | Clonidine 0.1 mg/day | Placebo | 8 weeks treatment + 4 weeks follow-up | Improved mean hot flash frequency, hot flash score, and duration with clonidine vs. placebo. Improved quality of life score with clonidine vs. placebo. No differences between groups in hot flash severity. Increased difficulty sleeping with clonidine vs. placebo. | | Good
Quella, 2000^277^ | 182 | women >18; previous breast cancer; 78% on tamoxifen | Soy isoflavone 600 mg tablet one three times daily (each contains 50 mg of soy isoflavones: 40–45% genistein, 40–45% diadzein, and 10–20% glycitein) | Placebo crossover | 4 weeks each phase | Summary statistics: No differences in hot flash score or frequency between groups. For outcome of reduction by half in hot flash frequency, 36% for placebo vs. 24% for soy (p=0.01). | | Fair
Secreto, 2004^288^ | 262 | ≥35; women with breast cancer included (<25%); none on tamoxifen | 1. Isoflavones 40 mg midday, and isoflavones 40 mg with melatonin 3 mg evening | Placebo midday and evening | 3 months | No differences between groups in the total score or sub scores of Greene Climacteric Scale. | Improved Greene Climacteric Scale scores in all groups: 38% placebo; 26% melatonin alone; 38% isoflavone alone; 39% isoflavones and melatonin. | Fair
| | | 2. Isoflavones 40 mg midday and evening
| | | 3. Placebo midday, and melatonin 3 mg evening
Van Patten, 2002^278^ | 157 | Mean age 55–56; all have breast cancer; 31% taking tamoxifen | Soy beverage totaling 90 mg/day isoflavones | Placebo | 12 weeks | No differences between groups in frequency and intensity of hot flashes. | Improved hot flash frequency and intensity in both groups. | Good

Trials used conventional and complementary/alternative medical treatments including venlafaxine,^282^ fluoxetine,^283^ clonidine,^284,^ ^285^ megestrol acetate,^280^ various preparations of soy/isoflavone products,^277–279,^ ^288^ black cohosh,^276,^ ^286^ magnets,^289^ vitamin E,^275^ and a polycarbonphil-based vaginal moisturizer.^281^ All compared treatments with placebo or usual care. Outcomes included hot flashes, sleep disturbances, mood, somatic complaints, sexual dysfunction, vaginal dryness, quality of life, and overall menopausal symptoms. No trials evaluated cognitive symptoms, urinary symptoms, or uterine bleeding.

Clonidine, venlafaxine, and megestrol acetate were associated with significantly improved measures of hot flashes.^280,^ ^282,^ ^284,^ ^285^ A good-quality trial of oral clonidine indicated a 38 percent decrease in hot flashes for clonidine (8 to 5 hot flashes/day) vs. 24 percent for placebo (7.4 to 5.7 hot flashes/day).^285^ In a fair-quality trial of transdermal clonidine, hot flashes decreased 44 percent with clonidine (6.1 to 3.4 hot flashes/day) compared to 27 percent for placebo (7 to 5.1 hot flashes/day).^284^ Megestrol acetate reduced hot flashes by 74 percent compared to 27 percent for placebo in a good-quality trial.^280^ A fair-quality trial of venlafaxine reported a mean decrease in hot flashes of 30 percent to 58 percent for varying doses of venlafaxine vs. 19 percent for placebo.^282^ Vitamin E, black cohosh, isoflavones, magnets, and fluoxetine alone did not reduce hot flashes.

Results for other outcomes were mixed. Sleep was improved in a fair-quality trial evaluating fluoxetine,^283^ but not in a fair-quality trial using black cohosh.^276^ None of the four fair-quality trials assessing mood (fluoxetine, venlafaxine, phytoestrogen and black cohosh) found them to be effective.^276,^ ^279,^ ^282,^ ^283^ Of the trials evaluating somatic complaints (headaches, palpitations, excessive sweating, nausea, fatigue), the only benefit reported was from a single fair-quality trial using black cohosh showing improvement of excessive sweating.^276^ Behavioral counseling with tailored therapies was effective at improving sexual functioning in one trial,^287^ but a fair-quality trial of venlafaxine found no difference in libido.^282^ The one trial evaluating polycarbophil-based vaginal preparation found it no more effective than placebo in reducing vaginal dryness, but effective at improving dyspareunia scores.^281^ Of the four trials evaluating quality of life, clonidine improved measures,^285^while fluoxetine, magnets, and behavioral counseling did not.^282,^ ^287,^ ^289^ Three trials assessed overall menopausal symptoms, of which only behavioral counseling was effective.^287^

Adverse effects were reported in 12 of 15 trials.^275–285,^ ^289^ Gastrointestinal adverse effects occurred more often among women using phytoestrogen products,^278,^ ^279^ particularly a soy beverage preparation.^278^ Two other trials reported no gastrointestinal adverse effects with soy preparations,^277,^ ^288^ although one trial excluded all women with intolerance to soy prior to randomization. ^288^ Fluoxetine was associated with worse appetite, nausea, constipation and dry mouth than placebo.^283^ The clonidine patch was associated with dry mouth, constipation, itchiness under the patch, and drowsiness.^284^ Clonidine tablets were associated with a trend toward more difficulty sleeping than placebo.^285^ Participants in the trial of magnets had difficulty with itching, redness, and perspiration at the site where magnets were affixed.^289^ Polycarbophil-based vaginal preparation was associated with an undesirable “wetness sensation.”^281^

#### Concurrent Use of Selective Estrogen Receptor Modulators (SERMs) and Other Agents

Patients using tamoxifen were enrolled in most of the trials of therapies in women with breast cancer.^275–279,^ ^282–287^ One fair-quality study of black cohosh reported hot flash symptoms separately for tamoxifen users vs. non-users, but found no significant differences between groups.^276^ Other studies of treatment of menopausal symptoms did not describe how concurrent use of SERMs affects therapy.

#### Lifestyle and Behavioral Factors

Few trials considered lifestyle and behavioral factors such as smoking, alcohol use, diet, or others,^161,^ ^162,^ ^169,^ ^170^ and no trials reported results according to these factors.

#### Recent Discontinuation of Menopausal Hormone Therapy

Most trials required discontinuation of hormone therapy prior to enrollment, however, no results were specifically reported for women with recent discontinuation.

#### Very Low or Very High Body Mass Index (BMI)

Some trials specified a range of acceptable BMIs in their eligibility criteria thereby disallowing enrollment of women with very high or low BMI. No studies reported results according to BMI.

## Summary

- Evidence is not available to determine if the effectiveness of therapy or adverse effects differ for women with bilateral oophorectomy, premature ovarian failure, concurrent use of SERMs or other potentially interacting agents, lifestyle and behavioral factors, recent discontinuation of menopausal hormone therapy, or very low or very high BMI.
- For women with breast cancer, results of 15 randomized controlled trials indicate that clonidine, venlafaxine, and megestrol acetate are associated with significantly improved measures of hot flashes, and vitamin E, black cohosh, isoflavones, magnets, and fluoxetine are not. Result for nonvasomotor outcomes are mixed.

## Key Question 5. Future Research on Therapies

### What are the future research directions for treatment of menopause-related symptoms and conditions?

Although many trials of several types of interventions have been published, results are consistent and conclusive only for estrogen agents for the treatment of vasomotor and urogenital symptoms. Despite this evidence, many questions remain about the benefits and adverse effects of estrogen for treating menopause related symptoms long-term. For nonestrogen therapies, larger, more rigorous, and more comprehensive trials are needed in order to determine benefits and adverse effects. Funding for nonindustry sponsored trials would enable trials of non drug therapies, including head-to-head trials comparing several types of drug and non drug interventions. Future research should include:

- Determination of optimally effective doses, combination regimens, durations of use, and timing of therapy.
- Evaluation of approaches to identify optimal candidates for specific therapies (e.g., identification of thrombophilias).
- Head-to-head and placebo comparisons of estrogen alone and combined with other types of therapies including non drug interventions.
- Trials demonstrating how to discontinue estrogen when symptoms subside, including the effectiveness of tapering doses and/or replacing with other therapies including non drug interventions.
- Better reporting of adverse effects in trials and use of standardized categories of adverse effects so data can be combined across trials.
- Improved analysis of results including analysis by hysterectomy and oophorectomy status, stage of menopause, age, concurrent conditions and medications, and other factors.
- More comprehensive trials to determine the role of regular exercise, sleep management, optimal nutrition, healthy relationships, social support, and relaxation; effects of mind-body techniques such as biofeedback and breathing; effects of a whole system approach with Chinese medicine.
- Additional, well-designed and controlled trials of phytoestrogens, botanicals, and bio-identical hormones, especially estriol, estradiol, and progesterone. Further study of antidepressants for vasomotor symptoms would be justified based on evidence of currently available trials.
- Enrollment of women with specific characteristics who have not previously been evaluated such as nonwhite women, women with premature ovarian failure, those using SERMs and other agents influencing symptoms concurrently, women with very high or low BMI, and those with lifestyle and behavioral factors influencing symptoms. Trials should report data specific to these groups in order to interpret their influence on therapy.
- Use of standard definitions, measures, and outcomes so results can be compared across trials.