# Methods

## Analytic Framework and Key Questions

The Key Questions for this evidence review were determined by the Planning Committee for the National Institutes of Health State-of-the-Science Conference on Management of Menopause-Related Symptoms. Key Questions examine a chain of evidence about symptoms commonly associated with menopause, factors that may influence the frequency, severity, or persistence of these symptoms, the effectiveness, benefits, and adverse effects of interventions for managing menopausal symptoms, and how the effects of interventions may differ for women with specific characteristics. The analytic framework (Figure 2) outlines the organization of key questions by identifying the target population, treatment interventions, health outcomes, and their relationships.

Figure 2. Analytic framework

## Technical Expert Panel (TEP) and Expert Reviewers

A Technical Expert Panel (Appendix 1) was assembled to provide input from experts and clinicians in the field to ensure that the scope of the project addressed important clinical questions and issues. The panel included obstetrician/gynecologists, internists, naturopathic physicians, behavioral experts, and researchers. The panel was convened for periodic conference calls during the course of the project. Expert reviewers, including several panel members, provided comments on the draft evidence report (Appendix 2).

## Literature Search and Strategy

Relevant studies were identified from multiple searches of MEDLINE, PsycINFO, DARE, the Cochrane database of systematic reviews and controlled trials, MANTIS, and AMED (1953 to November 2004) (Appendix 3). Additional articles were obtained from recent systematic reviews, reference lists, reviews, editorials, websites, and by consulting experts. Retrieved abstracts were entered into an electronic database (EndNote®).

## Inclusion and Exclusion Criteria

### Key Questions 1 and 2

Full text cohort studies with data on women experiencing menopause and at least one of the symptoms listed in Key Question 1 were initially reviewed and subsequently included if the study enrolled 100 or more subjects, subjects represented the target population, and data on symptoms associated with menopause were provided. Exclusions included studies of women not undergoing the menopausal transition and experiencing menopause related symptoms, studies of aging and its effects, and biologically based studies that did not report epidemiological data relating to symptoms (e.g., studies of hormone levels) (Appendix 4). Non-English language papers and studies of animals or cadavers were also excluded. Cross-sectional studies meeting similar inclusion/exclusion criteria were examined for contributory data and included if they reported relevant data about symptoms by menopausal stage, such as prevalence rates.

### Key Questions 3 and 4

Full text randomized controlled trials and meta-analyses of randomized controlled trials providing data on treatment of menopausal symptoms, using one or more of the interventions listed in Key Question 3, were included. Trials enrolling women with breast cancer were considered separately from those enrolling women without breast cancer. Exclusions included studies of women not undergoing menopause and experiencing menopause related symptoms during the course of the study, studies of animals, and non-English language papers (Appendix 4). For this report, abstracts of unpublished trials are included in evidence tables, but not in summary tables and text.

## Data Extraction and Synthesis

All eligible studies were reviewed and a “best evidence” approach was applied, in which studies with the highest quality and most rigorous design are emphasized.^13^ Data were extracted from each study, entered directly into evidence tables, and summarized descriptively. Benefits and adverse effects of therapies were considered equally important and both types of outcomes were abstracted. Trials of alternative and complementary therapies were grouped according to the National Center for Complementary and Alternative Medicine categories^14^ most closely related to included topics. For this report, acupuncture and Chinese herbal treatments were categorized in the alternative healthcare systems category, and lifestyle modifications, such as exercise, counseling and education, were placed within the mind-body category. Additional categories include biologically based therapies (e.g., red clover), manual medicine (e.g., osteopathic manipulations), and energy therapies (e.g., reflexology).

Results of recently published meta-analyses on estrogens^15–17^ and isoflavones^18^ are included in this report. No new meta-analyses were conducted because of heterogeneity of trials of other therapies.

Two reviewers independently rated the quality of randomized controlled trials and cohort studies using criteria specific to different study designs developed by the U.S. Preventive Services Task Force (Figure 3).^19^ Similar criteria for cross-sectional studies are not available. The overall rating is a combination of internal and external validity scores. When reviewers disagreed, a final rating was reached through consensus. Studies reporting several different outcomes may have different quality ratings for each outcome depending on how well it measured the symptom and how completely it controlled for key confounders in multi-variable models.

Figure 3. Quality rating criteria

## Size of Literature

A total of 10,059 unique citations were reviewed, including 6,342 about symptoms and factors influencing them (Key Questions 1 and 2); 4,078 about interventions (Key Question 3); and 806 about specific characteristics that may influence the effects of interventions (Key Question 4) (Appendix 5).