# Introduction

## Purpose

This systematic evidence review focuses on five Key Questions relating to symptoms of menopause and their management, as specified by the Planning Committee for the National Institutes of Health State-of-the-Science Conference on Management of Menopause-Related Symptoms:

1. What is the evidence that the symptoms more frequently reported by middle-aged women are attributable to ovarian aging and senescence? These include vasomotor symptoms, vaginal dryness, sleep disturbance, mood symptoms, cognitive disturbances, somatic complaints, urinary complaints, uterine bleeding problems, sexual dysfunction, and reduced quality of life.
2. When do the menopausal symptoms appear, how long do they persist and with what frequency and severity, and what is known about the factors that influence them? Factors include race and ethnicity, age at onset of the menopause transition, body mass index (BMI), surgical versus natural menopause, depression, and smoking.
3. What is the evidence for the benefits and harms of commonly used interventions for relief of menopause-related symptoms? Interventions include estrogens, progestins, androgens, tibolone, antidepressants, other drugs, phytoestrogens, complementary and alternative medicine, and behavioral interventions.
4. What are the important considerations in managing menopause-related symptoms in women with clinical characteristics or circumstances that may complicate decision-making? These include bilateral oophorectomy, premature ovarian failure, breast cancer, concurrent use of selective estrogen receptor modulators (SERMs) and other interacting therapeutic agents, lifestyle and behavioral factors, recent discontinuation of menopausal hormone therapy, and very low or very high BMI.
5. What are the future research directions for treatment of menopause-related symptoms and conditions?

The target population includes adult women in the U.S. undergoing menopause. The evidence review emphasizes the patient's perspective in assessment of symptoms, the choice of interventions, outcome measures, and potential adverse effects, and focuses on those that are applicable to clinical practice. It also considers the generalizability of efficacy studies performed in controlled settings. Although the evidence review attempts to assess research findings from the perspectives of clinicians and patients, it is not intended to propose practice recommendations.

## Menopausal Transition

Menopause is defined as the permanent cessation of menses resulting from reduced ovarian hormone secretion that occurs naturally or is induced by surgery, chemotherapy, or radiation. Natural menopause is recognized after 12 months of amenorrhea that is not associated with a pathologic cause. The average age of menopause in the U.S. is 51 years, and can vary normally between 40 and 58 years.^1^ The menopausal transition can span over several years, and often begins with variations in menstrual cycle length in response to rising levels of follicle stimulating hormone (FSH). The mean age of onset of the menopausal transition is 47.5 years and commonly lasts approximately 4 to 5 years.^1^

Stages and nomenclature of the menopausal transition were defined by experts in 2001 at the Stages of Reproductive Aging Workshop (STRAW), sponsored by the American Society for Reproductive Medicine, the National Institute on Aging, the National Institute of Child Health and Human Development, and the North American Menopause Society.^2^ The group recognized seven stages of the reproductive aging continuum, and acknowledged that most women do not progress precisely through each stage (Figure 1). These stages are also described by the following terms:

Figure 1. Normal reproductive aging in women

- Premenopause: the time up to the beginning of the perimenopause, but is also used to define the time up to the last menstrual period.
- Perimenopause: the time around menopause during which menstrual cycle and endocrine changes are occurring but 12 months of amenorrhea has not yet occurred.
- Postmenopause: begins at the time of the last menstrual period, although not recognized until after 12 months of amenorrhea.

## Menopausal Symptoms

A hot flash or flush refers to the spontaneous sensation of warmth, often associated with perspiration, resulting from a vasomotor response to declining estrogen levels. Although the term “flash” indicates a prodromal phase and “flush” the vasomotor dilation phase, they are combined in this report because they are reported inconsistently in studies. Nightsweats are hot flashes or flushes occurring at night, often while sleeping. Other symptoms, such as vaginal dryness, sleep disturbance, mood symptoms, cognitive disturbances, somatic complaints, urinary complaints, uterine bleeding problems, sexual dysfunction, and reduced quality of life are also attributed to the menopausal transition.

## Measures of Menopausal Symptoms

Although many measures have been developed to assess menopausal symptoms, few demonstrate standardization, validity, or reliability. Some measures are based on self-reports of the presence, severity, and frequency of individual symptoms, such as hot flashes. Others utilize cumulative or global scores based on lists or scales of symptoms attributed to menopause, such as mood, cognition, quality of life, sexual function, and somatic symptoms. Many studies base their measures on study-specific checklists, questionnaires, or scales. Ninety-two measures of menopausal symptoms were reported by studies included in this evidence review (Table 1). The most common measures are described below.

Table 1 Measures of menopause related symptoms

Measure
Vasomotor symptoms/Global menopausal symptoms
Blatt Menopausal Index^191,^ ^211,^ ^252^
Climacteric Index^258^
Clinical Global Impression Improvement Scale (CGI-I)^181,^ ^227,^ ^259^
Daily Symptom Rating Calendar (DSR)^154^
General Health Questionnaire (GHQ)^156,^ ^161^
Greene Climacteric Scale (GCS)^137,^ ^156,^ ^160,^ ^162,^ ^174,^ ^175,^ ^179,^ ^181,^ ^212,^ ^217,^ ^237,^ ^238,^ ^244,^ ^246,^ ^253,^ ^288^
Hopkins Symptom Checklist^130^
Hot Flash Related Daily Interference Scale (HFRDIS)^289^
Kupperman Index^146,^ ^148,^ ^155,^ ^203,^ ^204,^ ^220,^ ^227,^ ^236,^ ^264^
Measure Yourself Medical Outcome Profile (MYMOP)^261,^ ^263^
Menopausal Rating Scale^249^
Menopausal Symptom Index^276^
Menopausal Symptom Scale^263,^ ^287^
Menopausal Symptoms Questionnaire (MSQ)^205,^ ^219^
Menopause Representation Questionnaire (MRQ)^272^
Neugarten-Kraines Menopausal Index Scale^271^
Nottingham Health Profile (NHP)^126,^ ^157,^ ^267^
Patient Global Impression of Change Scale^198^
Short Form-36 Health Survey (SF36)^183,^ ^198,^ ^242,^ ^287^
Symptom Check List-90 (SCL-90)^235,^ ^266^
Visual Analogue Scales (VAS)^129,^ ^151,^ ^181,^ ^199,^ ^201,^ ^235,^ ^243,^ ^261,^ ^264,^ ^266,^ ^276,^ ^279^
Women's Health Questionnaire (WHQ)^119,^ ^120,^ ^162,^ ^187,^ ^241,^ ^261,^ ^272^
Sleep disturbances
Epworth Sleepiness Scale^215,^ ^238^
Pittsburgh Sleep Quality Index^198^
Sleep Dysfunction Test^236^
Sleep Problems Questionnaire^187^
Stanford Sleepiness Scale^215,^ ^238^
Mood symptoms
Beck Anxiety Inventory II (BAI-II)^181^
Beck Depression Inventory (BDI)^124,^ ^214,^ ^282,^ ^283^
Center of Epidemiological Studies Depression Scale (CES-D)^154^
Eysenck Personality Inventory^125^
Hamilton Anxiety Scale (HAMA)^129,^ ^258^
Hamilton Depression Rating Scale (HAM-D)^129,^ ^130,^ ^154,^ ^259^
Hospital Anxiety and Depression Scale^215,^ ^238,^ ^263^
Irritability, Depression, and Anxiety (IDA)^162^
Leckie-Withers Test of Liability to Depressive Illness^128^
Minnesota Multiphasic Personality Inventory (MMPI)^124,^ ^259^
Personal Distress Scale (PDS)^153^
Profile of Mood Scale^154^
Profile of Mood States^198^
Psychological General Well-Being Index (PGWBI)^144,^ ^150,^ ^153,^ ^160,^ ^187,^ ^241,^ ^236^
Rome Depression Inventory (RDI)^259^
Sabbatsberg Distress Self-Rating Scale (SDS)^125^
Self-Evaluations Depression Scale^253^
South African Personality Questionnaire^128^
Spielberger State-trait Anxiety Inventory^253,^ ^269^
Zung Self-Rating Depression Scale Questionnaire^138^
Cognitive disturbances
Auditory Serial Addition Test^215^
Boston Naming Test^242^
Buschke Immediate Recall and Delayed Recall Tests^154^
Digit Symbol Substitution Test^154^
Hong Kong List-Learning Test^242^
Logical Memory and Recall^214^
Mini-Biography Questionnaire^128^
Mini-Mental State Examination (MMSE)^214,^ ^242^
National Adult Reading Test-Revised^238^
Neuropsychological Test Battery^214^
Symbol Copying Test^154^
Trail Making Test^242^
Wechsler Adult Intelligence Scales of Digit Span and Digit Symbol^124^
Weschler Memory Scale^215,^ ^238^
Work Ability Index^279^
Sexual dysfunction
Bem Sex Role Inventory^128^
Brief Index of Sexual Function for Women (BISF-W)^142,^ ^144,^ ^145^
Local Urogenital Complaints Rating Scale (LUCRS)^160^
McCoy Sex Scale^150,^ ^167,^ ^171,^ ^174^
Profile of Female Sexual Function (PFSF)^152,^ ^153^
Sabbatsberg Revised Sexual Rating Scale (SRS)^145^
Sabbatsberg Sexual Self-Rating Scale (SSS)^125^
Sexual Activity Log (SAL)^152,^ ^153^
Sexual Behavior Questionnaire^187^
Sexual Interest Questionnaire (SIQ)^142,^ ^145^
Sexual Summary Scale^287^
Quality of life
Cancer Quality of Life Score (European Organization for Research and Treatment)^263^
Menopause Specific Quality of Life Questionnaire (MENQOL)^137,^ ^225,^ ^229,^ ^238^
Quality of Life Menopause Scale (QUALMS)^145^
Quality of Life, Enjoyment and Satisfaction Questionnaire (Q-LES-Q)^160^
SmithKline Beecham Quality of Life Self Report Questionnaire^154^
Uniscale QOL instrument^282,^ ^283^
Other
Collins and Landgren Rating Scale^168^
Dyadic Adjustment Scale (DAS)^156^
Finger Tapping Test^242^
Food Frequency Questionnaire^242^
Halstead-Reitan^214^
Heat Stress Test (HST)^270^
Karolinska Scale^158^
Kellner and Sheffield Rating Scale^191^
Profile of Adaptation to Life^124^
Sheehan Disability Scale^181^
Uken Motherliness Test^128^
Vaginal Dryness Index^256^
Vaginal Health Index^257^

The Kupperman Index, or Kupperman Blatt Index, assesses overall menopause symptoms, and is frequently used to determine severity of hot flashes. The Kupperman Index grades the self-reported severity of 11 symptoms (hot flashes, paresthesias, insomnia, nervousness, melancholia, vertigo, weakness, arthralgia or myalgia, headache, palpitations, and formication) on a scale from 0 to 3. Item scores are weighted to create a composite score. This measure has been validated and is responsive to change, however, it lacks statistical justification for weights.^3^ The Greene Climacteric Scale assesses the severity of 21 self-reported symptoms on a 4-point scale.^4^ Psychological, somatic, and vasomotor symptoms are assessed, along with one question on sexual dysfunction. The Women's Health Questionnaire was developed for use primarily as a quality of life instrument, although it is also used to measure overall symptoms. It includes 36 items with 4-point self-report response categories. It has demonstrated reliability, has undergone psychometric evaluation, and allows for cross-cultural comparisons.^3^

The Beck Depression Inventory and Hamilton Depression Rating Scale are widely-used and validated measures of depression that are highly correlated.^5,^ ^6^ The Hamilton Depression Rating Scale is the usual standard against which other depression rating scales are validated. The Psychological General Well-Being Index is less commonly used, and has demonstrated validity in assessing general psychological well-being.^7^

The Brief Index of Sexual Functioning for Women is a 22-item validated self-report instrument measuring current levels of female sexual functioning and satisfaction, assessing both quantitative and qualitative aspects.^8^ The McCoy Sex Scale assesses sexual experience and responsiveness in the 30 days prior to testing utilizing 14 items on a 7-point scale.^9^

The Menopause Specific Quality of Life Questionnaire is a validated instrument that assesses physical, vasomotor, psychosexual, and sexual domains of life quality using a 7-point scale. A difference in one point on a domain score represents a 15 percent change.^10^ The Nottingham Health Profile includes 38 yes/no questions in six subsections (physical mobility, pain, sleep, energy, social isolation, and emotional reactions).^11^ The Short-Form 36 Health Survey measures eight health concepts and has been extensively tested and validated.^12^