# Appendix F. Evidence Tables

Evidence table 6-1. Key Question 1 and 2 cohort studies

Study/Year | Umbrella | N | Study Design | Type Control Group | Length of Follow-Up | Recruitment (Data source) | Population/ Setting | Race/ Ethnicity | Age (range) | Inclusion/Exclusion Criteria | Ascertainment of Symptoms | Response Rate | Withdrawals | Measures Used | Menopausal status | Hysterectomy or BSO (#/n) | Premature Ovarian Failure (#/n) | Breast Cancer (#/n) | Use of SERMS (#/n) | Behavior or Lifestyle Factors (#/n) | Recent discontinuation of HRT (#/n) | High or Low BMI (#/n) | Hot Flashes | Vaginal Dryness | Sleep | Mood | Cognitive | Somatic | Urinary | Uterine Bleeding | Sexual Dysfunction | Quality of Life | Other Outcomes | Predictors studied (significant/not significant) | Statistical Models | Significant predictors in multivariate (adjusted models) | RR or OR | Comments
Avis, 1994 | Massachusett's Women's Health Study | 2565 | Cohort | Internal | 5 years | Random sample of 8,050 women ages 45–55 in Massachusetts, from which 2,565 were identified as having menstruated in the past 3 months, having a uterus and ≥ one ovary | Population based recruitment of premenopausal women | _ | _ | _ | _ | _ | _ | CES-D for depression | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | Used CES-D score of <16 vs. ≥16 as dichotomous outcome variable. Logistic regression model adjusted for HRT, menopausal symptoms at T2, T1-T2 menopausal transition and T1 CES-D score. | _ | _ | Depression at baseline was most predictive of subsequent depression (OR 9.12, p<0.0001). A menopausal symptoms variable was also significant contributor (OR=3.55, <0.0001). The menopausal transition was significant as a single variable but the individual variables were not. (OR 0.59 to 1.28, all CI crossing 1).
| | | | | | | | | | | | | | Seven measures of health care utilization | | | | | | | | | | | | | | | | | | | | | | | | Comparing the prevalence of depression among groups, the peak prevalence of depression for those not depressed at baseline, was for those who were peri-peri. For those who were depressed at baseline, the peak prevalence of depression occurred in the pre/peri-post group (see figure in paper, no numbers given in text).
| | | | | | | | | | | | | | Self-assessed health, physical symptoms, restricted activity and chronic conditions.
| | | | | | | | | | | | | | Surgical menopause included either hysterectomy or BSO.
Avis, 1997 | Massachusett's Women's Health Study | 454 (131 for some analyses) | Cross-sectional analyses from cohort | Internal | 4.5 years | Sample was part of larger cohort of 8,050 women randomly selected; 2,565 were pre- or early menopausal | Community-based, Massachusetts | NR | 45–55 in 1982 (baseline) | For this analysis, women who were premenopausal at baseline and naturally post-menopausal at the last study f/u (4 yrs later, 6th clinic visit). | Telephone and mailed questionnaires | 94–95% retention over 6 contacts for cohort of 2,565 pre- and early menopausal women | | hot flashes and night sweats (frequency and bothersomeness) consult with MD regarding menopause | All women in this analysis progressed from pre to post menopausal (natural) over the course of the f/u period | Excluded | Excluded | NR | NR | Current smoking at baseline 41% | Excluded | NR | 23% were [underlined: not] bothered by HF/NS at any of the six interviews. | | | | | | | | | | | Smoking (;<0.05), physical symptoms (p<0.01), psychological symptoms (p<0.001), having had a surgery for a benign breast cyst, greaster alcohol consumption and agreeing with the statement “many women think they are no longer “real” women after the menopause” were related to FH/NS bothersomeness. | Stepwise logistic regression. | "Smoking (;<0.05), physical symptoms (p<0.01), psychological symptoms (p<0.001), having had a surgery for a benign breast cyst, greaster alcohol consumption and agreeing with the statement “many women think they are no longer “real” women after the menopause” were related to FH/NS bothersomeness. | OR for HF/NS frequency from stepwise logistic regression:
| | | | | | | | | | | | | | | | | | | | | | | HF and NS bothersomeness were highly correlated. | | | | | | | | | | | | | Primary variables predicting frequncy of HF/NS reporting were premenopausal symptoms and attitudes toward menopause. | smoking 1.44 (CI 1.02, 2.05)
| | | | | | | | | | | | | | | | | | | | | | | Length of perimenopause was not correlated with number or bothersomeness of symptoms. | | | | | | | | | | | | | Age at inception of peri-menopause was associated with length of perimenopause (r=-0.16, p=0.0005). | tubal ligation 0.47 (CI 0.29, 0.78)
| | | | | | | | | | | | | | | | | | | | | | | Women with more negative attitude toward menopause report HF/NS more frequently. | | | | | | | | | | | | | | any college 0.59 (0.42, 0.84)
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | physical symptoms 1.47 (1.18, 1.83)
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | psychological symptoms 2.14 (1.38, 3.35)
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | length of perimenopause 1.24 (1.07, 1.44).
Avis, 2000 | Massachusett's Women's Health Study | 2000 | Cross-sectional analyses from cohort | Intenral | 5 years (1986-91) | Random pop-based sample of 8,050 women in Mass. 2,569 women ages 45–55 selected for f/u. Of these 427 (78.6% of 543) were eligible for this study. 200 included in this analysis. | Community-based, Massachusetts | NR | 51–61, mean age 54 | Inclusion criteria: | Questionnaires | RR 77% from initial recruitement. | | Sexual activity questionnaire adapted for Amssachusetts male Agin Study | | Exlcuded | Excluded | Excluded if within 5 years | NR | Current smoking 22% | Excuded (n=51) | BMI range 17–49, mean±SE=27.9±5.5 | | | | Overall: 12.6% had CES-D score ≥16. | | | | | Fewer perimenopausal women reported never having difficulty reaching orgasm (NS). | Satisfaction with life did not vary by menopausal status. | | The following variables were unrelated to any aspect of sexual functioning: employment status, vasomotor symptoms, parter stress, alcohol , exercise and BMI | Multiple regression | Sexual Function:
| | | | | | | | | | 1. Intact uterus and 1 ovary | | | | Satisfaction with current sexual relationship | | | | | | | | | | | | 39.8% had psychological symptoms | | | | | Level of sexual desire was lower among post-menopausal women compared with premenopausal women (p<0.05). | | | | | Recent vaginal dryness was related to pain during or after intercourse (OR 3.86) and difficulty reaching orgasm (OR 2.51).
| | | | | | | | | | 2. No HRT in past 2 yrs | | | | Frequency of sexual intercourse | | | | | | | | | | | | | | | | | Frequency of sexual intercourse and pain during intercourse did not vary by menopausal status. | | | | | Menoapausal status was not related to either pain during intercourse or difficulty reaching orgasm.
| | | | | | | | | | 3. Current sexual partner | | | | Sexual desire | | | | | | | | | | | | | | | | | | | | | | Age was negatively related to difficulty reaching orgasm.
| | | | | | | | | | 4. Living within 1 hr of Boston | | | | Belief that interest in sex declines with age
| | | | | | | | | | 5. <12 months consecutive ammenorrhea | | | | Level of arousal
| | | | | | | | | | 6. No major cancer in last 5 years. | | | | Difficulty reaching organsm
| | | | | | | | | | | | | | Pelvic area pain
Avis, 2001 | SWAN | 14,906 | Cross-sectional | _ | _ | _ | _ | _ | 47.1 (40–55) | Exclusion: | _ | 87.70% | _ | _ | Surgical 20.8% | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | Factor 1 - psychosomatic symptoms | Age, education, self-assessed health, economic strain, geographic site | Multiple linear regression model for Factors 1 and multiple logistic regression for Factor 2. | [underlined: Factor 1: Psychosomatic symptoms] | | Psychosomatic symptom reporting differs by both race/ethnicity and by menopausal status. All other racial/ethnic groups report significantly fewer symptoms than Caucasian women. Peri-menopausal women, HRT users and women with surgical menopause report more symptoms than premenopausal women.
| | | | | | | | | | 450 missing race/ethnicity data | | | | | Postmenopausal 14.6% | | | | | | | | | | | | | | | | | | Factor 2 - vasomotor symptoms | interaction terms for race/ethnicity and menopausal status | | Significant predictors (p<0.0001) | | Vasomotor symptom reporting also varies by race/ethnicity and menopausal status. Effects are greater when looking 2 symptoms vs. none. AA were more likely and Hispanic, Japanese, Chinese were less likely than Caucasian women to report vasomotor symptoms. All menopausal groups reported significantly more symptoms than premenopausal women.
| | | | | | | | | | 341 uncertain menopausal status | | | | | Perimenopausal 27.2% | | | | | | | | | | | | | | | | | | Symptoms had to load ≥ 0.40 on a factor for all ethnic groups. | | | Age | 1.22–1.29; 1.38–2.58; 1.15–1.30
| | | | | | | | | | 55 pregnant or breastfeeding | | | | | Premenopausal 29.7% | | | | | | | | | | | | | | | | | | | | | Education (reference postgraduate degree) - high school degree/equivalent | 1.41; 1.59; 0.60; 0.65; 1.69–1.96
| | | | | | | | | | 313 incomplete data on symptoms or covariates | | | | | Hormone user 7.7% | | | | | | | | | | | | | | | | | | | | | Self-assessed health (reference excellent) - very good, good, fair/poor | 1.05; 1.53–1.79; 1.69–3.72; 1.18–1.55
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Difficult to pay for basics (reference not at all hard) - somewhat hard or very hard | 1.28–1.82; 0.25–0.77; 3.35–3.81; 0.74–0.75
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Racial/ethnic group (reference Caucasian) - AA, H, Chinese, Japanese, Hispanic
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Menopausal status (reference premenopausal) - peri and surgical menopause, HRT users
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Geographic site (reference Detroit) - Boston, Newark
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | [underlined: Factor 2: Vasomotor symptoms (1 vs. 0)]
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Education (ref postgraduate degree) - college graduate or less education
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Self-assessed health (ref excellent) - very good, good, fair/poor
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Difficult to pay for basics (ref not at all hard) - somewhat hard or very hard
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Racial ethnic group (ref Caucasian) -
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | AA: Chicago; AA: Detroit; Chinese; Japanese
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Menopausal status (ref premenopausal) - peri, post, surgical, and HRT users
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | [underlined: Factor 2: Vasomotor symptoms (2 vs. 0)]
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Age; Education (ref postgraduate degree) - college graduate or less education;
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Self-assessed health (ref excellent) - very good, good, fair/poor; Difficult to pay for basics (ref not at all hard) - somewhat hard or very hard;
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Racial ethnic group (ref Caucasian)
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | AA (all sites); Chinese, Japanese, Hispanic
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Menopausal status (ref premenopausal) - peri, post, surgical, and HRT users
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Geographic site (ref Detroit) - Pittsburgh, L.A.
Avis, 2003 | SWAN | 3,193 | Cross-sectional | _ | _ | _ | _ | AA 28.15% | 46.2 (42–52) | Data on menopausal status and SF-36 outcomes missing for 109 of 3302 | _ | 96.70% | _ | 5 subscales of SF-36 as measures of health related quality of life (HRQL): bodily pain, role limitations due to physical health, role limitations due to emotional problems, social functioning and vitality menopausal status, sociodemographic and lifestyle variables, health variables psychosocial variables including the Center for Epidemiological Studies (CES-D) scale, Perceived Stress Scale, Medical Outcomes Study Social Support Survey | Premenopause 53.82 % | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | SES, sociodemographic, health, lifestyle and social circumstance variables | Adjusted models for impaired function (women at or below the 25th percentile) on the SF-36 scales | In unadjusted models, early perimenopause and ethnic group were significantly associated with Impaired Function. | _ | “Symptoms are important mediators between physiological conditions and HRQL.”
| | | | | | | | Chinese 7.68% | | | | | | | Early perimenopause 46.18% | | | | | | | | | | | | | | | | | | | | | In models adjusted for health conditions, impaired function did not differ by menopausal status.
| | | | | | | | H 8.44% | | | | | | | Late perimenopause 0% | | | | | | | | | | | | | | | | | | | | | In adjusted models, Hispanic women were more likely than whites to report bodily pain and impaired social functioning. Blacks were more likely than Whites to report impaired social functioning.
| | | | | | | | J 8.63% | | | | | | | Post-menopause 0%
| | | | | | | | W 47.1%
Bromberger, 2001 | SWAN | 10,374 | Cross-sectional | N/A | N/A | _ | _ | AA 25.8% | 40–55 | 5213 of 16065 were excluded for 1) exogenous hormone use preceding 3 months, 2) pregnancy, 3) hysterectomy, 4) no menses past 12 months due to pregnancy, breast-feeding, severe weight loss, or illness | _ | 64.57% | _ | 12-item questionnaire of physical and psychological symptoms | Premenopause 43.2 % | Ineligible | NR | NR | NR | Smoking: | _ | _ | Yes 32.5% | NR | Difficulty sleeping: | Psychological distress: | NR | NR | NR | NR | NR | NR | The following variable were significantly associated with psychological distress (p<0.001): | Significant: | Multivariate association of psychological distress with menopausal status | Early perimenopause as compared to premenopause was associated with increased odds of psychological distress (OR 1.2). | _ | Early perimenopause and vasomotor symptoms were associated with increased odds of psychological distress. Late perimenopause and post-menopause were not associated with increased odds of psychological distress.
| | | | | | | | Chinese 5 | mean 45.9 with distress | | | | | Psychological distress = presence of all 3 symptoms feeling tense or nervous, feeling blue or depressed, feeling irritable or grouchy (categorical - present or absent) | Early perimenopause 34 | | | | | current 22.5% | | | No 67 | | Yes 36.1% | Yes 24.1% | | | | | | | menopause status, race/ethnicity, education, marital status, smoking, availability of perceived social support, number close friends/relatives, paying for basics, perceived health. | menopause status, race/ethnicity, education, smoking, availability of perceived social support, close friends/relatives, paying for basics, perceived health, health limitations, difficulty sleeping, vasomotor symptoms, age | | AA, H, J, Chinese race as compared to W race was associated with decreased odds of psychological distress (OR 0.73, 0.65, 0.61, 0.43).
| | | | | | | | H 13.5 | mean 46.4 without distress | | | | | | Late perimenopause 5.8 | | | | | past 23 | | | Those with vasomotor flushes (36.6%) were more likely than those without (18.0%) to have psychological distress (p<0.001). | | No 62.7 | No 75.9 | | | | | | | | Not significant: | | The presence of vasomotor symptoms was associated with increased odds of psychological distress (OR1.96).
| | | | | | | | J 6.3 | | | | | | | Post-menopause 16.8 | | | | | never 53.6 | | | | | Those with difficulty sleeping (39.7%) were more likely than those without (15.4%) to have psychological distress (p<0.001). | | | | | | | | | employment status, marital status, site, physical activity, number of reported medical conditions,
| | | | | | | | W 49.2 | | | | | | | Proportion with psychological distress:
| | | | | | | | | | | | | | | Premenopause 20.9 %
| | | | | | | | | | | | | | | Early perimenopause 28.9
| | | | | | | | | | | | | | | Late perimenopause 25
| | | | | | | | | | | | | | | Post-menopause 22
Bromberger, 2003 | SWAN | 3,161 | Cross-sectional | N/A | N/A | _ | _ | AA 28.3 % | 42–52 | White or site-predetermined ethnicity, menses within the previous 3 month, have uterus and at least one ovary, not pregnant, no use of reproductive hormones or birth control pills within the previous 3 months. | _ | 95.73% | N/A | Symptom checklists, SF-36 Role Emotional scale, Medical Outcomes Study Social Support Survey, modification of Psychiatric Epidemiology Research Interview, adapted Baecke questionnaire | Premenopausal 53.4 % | Ineligible | Ineligible | NR | Ineligible | Nonsmokers 82.9 % | N/A | NR | None 89% | NR | Disturbed 31% | Use of medication for nervous condition 10% | NR | Pain: | NR | NR | NR | NR | _ | Study site, menopausal status, ethnicity, age, difficulty of paying for basic necessities, use of medication for nervous conditions, pain, disturbed sleep, vasomotor symptoms, possible premenstrual syndrome, social support, number of upsetting events, relationship presence/quality, recreational/sport activity, study site | Logistic regression models for each of four mood symptoms: Feeling blue, irritable, nervous, or experiencing mood changes on >= 6 days in preceding 2 weeks. | In comparison to premenopause, early perimenopause was associated with increased odds of : | _ | Early perimenopause was associated with increased odds of mood symptoms and dysphoric mood particularly among women with lower educational attainment.
| | | | | | | | Chinese 7.7 | mean 46.2 | 141 excluded because of missing data for dysphoric mood and menopausal status | | | | Dysphoric mood = summary scale 0–16 (dichotomized 0–6 v 7–16) of the 4 mood measures feeling blue, feeling irritable, feeling nervous, or experiencing mood changes on ≥ 6 days in preceding 2 weeks. | Early perimenopausal 46.6 % | | | | | | | | | | | possible PMS 15.3% | | severe/very severe 7.1% | | | | | | | Logistic regression model of dysphoric mood. | feeling irritable (OR 1.33)
| | | | | | | | H 8.2 | | | | | | | | | | | | | | | | | | | | moderate 22% | | | | | | | Menopausal status, study site, age, race/ethnicity forced into all adjusted models. | feeling nervous (OR 1.54)
| | | | | | | | J 8.7 | | | | | | | | | | | | | | | | | | | | very mild/mild 54.2% | | | | | | | | experiencing mood changes (OR 1.52). dysphoric mood score >= 7 (OR 1.8)
| | | | | | | | W 47.2 | | | | | | | | | | | | | | | | | | | | | | | | | | | | dysphoric mood in previous 2 weeks (OR 1.62).
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | In comparison to W women, AA had decreased odds of:
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | feeling blue (OR 0.62)
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | feeling irritable (OR 0.61)
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | feeling nervous (OR 0.46)
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Chinese women had decreased odds of:
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | feeling blue (OR 0.35)
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | feeling irritable (OR 0.30);
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | J women had decreased odds of:
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | feeling blue (OR 0.44)
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | feeling nervous (OR 0.51).
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Vasomotor symptoms were associated with all of the mood symptoms (p<0.001).
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Lower education level was associated with increased odds of dysphoric mood:
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | some college (OR 2.04)
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | high school or less (OR 2.35)
Brown, 2002 Australia | Australian Longitudinal Study on Women's Health | 8,236 | Cohort | Internal | 2 years | 41,500 women selected from all over Australia using national Medicare health insurance database with over-representation of women living in rural and remote areas. The mid-age cohort (age 45–50 years) was targeted for survey 2 in 1998. | _ | NR | Mean age 49.7 (sd 1.5) yreas at survey 2 | _ | _ | 14,065 mid-age women responded to the mailed survey; 54% of them agreed. For survey 2, 92% of 12,328 women responded (12,328 represents women who consented to further contact and had not died). | 6.5% did not return the survey, 1.5% declined participation in survey 2 | Menopausal status: self-reported bleeding history or HRT (4 categories); 6 change categories. | _ | _ | _ | _ | _ | _ | _ | _ | Relative to pre-pre: | _ | Difficulty sleeping: | _ | _ | Stiff or painful joints (compared to pre-pre): | Leaking urine (compared to pr-pre): | _ | _ | _ | _ | _ | Adjusted for symptom score at survey 1, physical activity , weight, weight change, life events, smoking status, occupation, country of birth, marital status, and area of residence and age. | _ | _ | Using pre-pre as the reference group, 1. Headache: OR were not significantly different between groups (all CI crossed 1)
| | | | | | | | | | | | | | | | | | | | | | | Pre-peri: OR 1.3 (1.1, 1.5) | | Pre-peri: 1.3 (1.1, 1.5) | | | Pre-peri: 1.3 (1.1, 1.5) | Pre-peri: 1.0 (0.8, 1.2) not significant | | | | | | | | | 2. Eyesight problems: OR were not significantly different between groups (all CI crossed or included 1),
| | | | | | | | | | | | | | | | | | | | | | | Peri-peri: 1.3 (1.1, 1.5) | | Per-peri: 1.4 (1.2, 1.7) | | | Peri-peri: 1.6 (1.4, 1.9) | Peri-peri: 1.3 (1.1, 1.6) | | | | | | | | | 3. Severe tiredness: OR were highest for HRT (OR 1.5, CI 1.3–1.8), then per-peri (OR 1.3, CI 1.1–1.5) and peri-peri (OR 1.3, CI 1.1–1.5) and lowest for pre/peri-post (OR 0.9, 0.7–1.1) and post-post (OR 1.0, CI 0.7–1.3).
| | | | | | | | | | | | | | | | | | | | | | | Pre/peri-Post: 1.0 (0.8, 1.2) Not significant | | Pre/peri-Post: 1.5 (1.2, 1.8) | | | Pre/peri-Post: 1.1 (0.9, 1.4) | Pre/peri-Post: 1.0 (0.8, 1.3) not significant | | | | | | | | | 4. Stiff or painful joints
| | | | | | | | | | | | | | | | | | | | | | | Post-post: 0.9 (0.7, 1.2) not significant | | Post-post: 1.2 (0.9, 1.6) not significant | | | Post-post: 1.3 (1.0, 1.7) | Post-post: 0.8 (0.6, 1.1) not significant | | | | | | | | | 5. Back pain
| | | | | | | | | | | | | | | | | | | | | | | HRT: 1.5 (1.3, 1.8) | | HRT : 1.5 (1.3, 1.7) | | | HRT: 1.4 (1.2, 1.7) | HRT: 1.0 (0.8, 1.2) not significant | | | | | | | | | 6. Leaking urine
| | | | | | | | | | | | | | | | | | | | | | | | | | | | Back pain (compared to pre-pre): | | | | | | | | | | 7. Constipation
| | | | | | | | | | | | | | | | | | | | | | | | | | | | Pre-peri: 1.2 (1.0, 1.4) | | | | | | | | | | 8. Difficulty sleeping
| | | | | | | | | | | | | | | | | | | | | | | | | | | | Peri-peri: 1.3 (1.1, 1.5) | | | | | | | | | | 9. Hot flashes
| | | | | | | | | | | | | | | | | | | | | | | | | | | | Pre/peri-Post: 1.0 (0.8, 1.2) | | | | | | | | | | 10. Night sweats
| | | | | | | | | | | | | | | | | | | | | | | | | | | | Post-post: 1.1 (0.9, 1.4)
| | | | | | | | | | | | | | | | | | | | | | | | | | | | HRT: 1.2 (1.0, 1.4)
Busch, 1994 | National Health Examination Follow-up Study | 395 naturally menopausal women + 178 surgically menopausal women. | Cohort (also has cross-sectional data) | Internal | 10 years | NHANES (stratified probability sample of U.S.) | U.S. | NR | 40–60 | Women who had participated in NHANES at baseline and the 10 year follow-up study. Included those who were not menopausal at the baseline assessment. | _ | _ | _ | Women were selected at random to receive the CES-D and the GWB (Global Well-Being) questionnaires. Sleep disturbance measures by three NHEFS items summed to form a scale: “How often do you have trouble falling asleep?”; “How often to you have trouble with waking up during the night?”; “How often do you have trouble with waking up too early and not being able to fall sleep again?” | _ | 178/573 had “surgical menopause” | NR | NR | NR | NR | NR | NR | NR | NR | No significant differences between women in different menopausal change groups, or between those of surgical vs. natural menopause | No significant differences between women in different menopausal change groups, or between those of surgical vs. natural menopause (Mean CES-D score (s.d.) time 1 vs. time 2) : | NR | NR | NR | NR | NR | No significant differences between women in different menopausal change groups, or between those of surgical vs. natural menopause (mean (s.d.) at time 1 vs. time 2): | _ | None | No MV modeling | _ | NA | Assume that the categories used to report symptoms are those ascertained at 10 year assessment, because everyone was pre-menopausal at baseline in order to be included.
| | Drawn from a sample of 3,049 women age 40–60 in NHANES | | | | | | | | Exclusions: | | | | | | | | | | | | | | | | Pre-pre: 8.9 (9.1) vs. 7.8 (9.0), n=172 | | | | | | pre-pre:48.0 (10.9)vs 49.3(11.1), n=352.
| | | | | | | | | | 1. Insufficient data to determine menopausal status | | | | | | | | | | | | | | | | Pre-Peri: 10.3 (9.4 vs. 7.8 (6.5), n=58. | | | | | | Pre-peri: 47.1 (12.6)vs. 47.7 (11.1), n=125.
| | | | | | | | | | 2. Cessation of menstruation for reasons other than natural or surgical menopause | | | | | | | | | | | | | | | | Pre-Natural Menopause: 8.4 (8.1vs 7.8 (7.5), n=114. | | | | | | pre-Natural Menopause: 49.2(10.7) vs. 49.5 (10.1), n=281.
| | | | | | | | | | 3. Reporting surgical menopause but still having a uterus and ovaries | | | | | | | | | | | | | | | | Pre-Surgical Menopause: 9.6 (7.5)vs 9.4 (11.1) n=50 | | | | | | pre-Surgical Menopause: 45.8 (12.3) vs. 47.0 (13.1).
| | | | | | | | | | 4. Reporting continued menstruation after age 58.
Dennerstein, 1993 Australia | Melbourne Women's | 1,897 | Cross-sectional | _ | _ | _ | _ | _ | _ | _ | _ | 1897/2001 (94.8%) were available for analysis | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | By menstrual status: | _ | Trouble sleeping by menstrual status: | Feeling sad or downhearted by menstrual status: | Difficulty in concentrating by menstrual status: | _ | Problems with urine control by menstrual status: | _ | _ | _ | _ | _ | _ | _ | _
| | | | | | | | | | | | | | | | | | | | | | | Post 39.4% | | Post 41.5% | Post 48.7% | Post 18.3% | | Post 14%
| | | | | | | | | | | | | | | | | | | | | | | Peri 31.5% | | Peri 35.2% | Peri 33% | Peri 27.5% | | Peri 16%
| | | | | | | | | | | | | | | | | | | | | | | Pre 9.8% | | Pre 24% | Pre 24.7% | Pre 20.3% | | Pre 9.2%
Dennerstein, 1994 Australia | Melbourne Women's | 1,879 | Cross-sectional | _ | _ | _ | _ | _ | _ | Current oc users excluded. | _ | _ | _ | Sexual interest, frequency, dyspareunia | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | Age, menopausal status, well-being, employment status, years of education, vasomotor symptoms, cardiopulmonary symptoms, skeletal symptoms | Logistic regression model of decrease in sexual interest over the preceding year | Natural menopause | 1.93 (1.22–3.06) | Decline in sexual interest was associated with natural menopause, decreased well-being, decreasing employment, vasomotor symptoms, skeletal symptoms, and cardiopulmonary symptoms. It was not associated with age.
| | | | | | | | | | | | | | sociodemographic and lifestyle variables | | | | | | | | | | | | | | | | | | | | | | On HRT | 2.27 (1.42–3.63)
| | | | | | | | | | | | | | health status, menopausal status | | | | | | | | | | | | | | | | | | | | | | well-being | 0.76 (0.67–0.87)
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | part-time employment | 1.81 (1.34–2.45)
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | no employment | 1.56 (1.16–2.10)
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | 11–12 years of education | 0.65 (0.50–0.87)
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | vasomotor symptoms | 1.25 (1.05–1.48)
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | cardiopulmonary symptoms | 0.72 (0.61–0.84)
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | skeletal symptoms | 1.32 (1.11–1.50)
Dennerstein, 1997 | Melbourne Women's | 405 | Longitudinal | _ | 4 years | _ | _ | _ | 45–55 | Inclusion: | Face to face interview | Subset of cohort of 2001 women | 92% retention rate after the 4th round of interviews | Affectometer 2 (modified) | Pre 37% | Excluded | NR | NR | NR | _ | NR | _ | (% in the last 2 weeks) | _ | _ | Positive affect increased with age (p<0.05) and negative affect decreased with age (p<0.05) only in the postmenopausal categories. In the pre- and peri-menopausal categories, there were no significant age effects. | _ | _ | _ | _ | _ | _ | _ | _ | Data from years 1–4 was pooled an analyzed as a whole. | Significant coefficients after adjustment for age and hot flashes. | _ | _
| | | | | | | | | | Women who were still experiencing menstrual cycles, or who had no more than 3 months of amenorrhea, who were not taking hormone therapy, or oral contraceptives, had an intact uterus, and at least one ovary | | | | E_2_ | Early Peri 34% | | | | | | | | 12.6 | | | | | | | | | | | | Generalized linear regression, forward stepwise approach. | None were significant for positive affect in any of the menopausal groups compared with premenopausal group.
| | | | | | | | | | Exclusions: | | | | FSH | Late Peri 17% | | | | | | | | 18.4 (p<0.05) | | | | | | | | | | | | | The mean negarive affect score was higher in early peri (Beta 0.079, p<0.01) and 1–2 year post menopause (Beta 0.120, p<0.05) groups compared to premenopausal group.
| | | | | | | | | | HRT use, surgical removal of uterus and/or ovaries, women who refused blood draws | | | | Total Testosterone (T) | 1–2 years post 9% | | | | | | | | 54.3 (p<0.001) | | | | | | | | | | | | | Overall, well being tended to decrease with increasing menopausal status, with the lowest in the 1–2 years postmenopausal group (p<0.01), followed by an increase in levels of well being in the > 2 years postmenopause group.
| | | | | | | | | | | | | | SHBG | > 2 years post 3% | | | | | | | | 57.0 (p<0.001)
| | | | | | | | | | | | | | Free Androgen Index (FAI) | Mean age increased across the menopausal categories from 49.4 (pre) to 54.4 (> 2 years post), p<0.001. | | | | | | | | 48.8 (0.001)
| | | | | | | | | | | | | | | | | | | | | | | p values as compared to pre-menopausal group
Dennerstein, 1999 Australia | Melbourne Women's | 354 | Longitudinal | _ | 6 years | _ | _ | _ | 48.1 at baseline | Exclusions: dropouts (49), surgical menopause (29), oral contraceptive use at any year (6). | Questionnaires, physical exam, blood samples, telephone interview | Retention rate for longitudinal arm 90% at 6 years. | _ | Affectometer-2 | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | Significant decrease in negative mood with time (p=.005) | _ | _ | _ | _ | _ | _ | _ | _ | _ | Significant predictors of Magnitude of Negative Mood (p = 0.002 – 0.02): | _ | No direct link between the menopausal transition and negative mood level.
| | | | | | | | | | | | Percentage of original cohort eligible for this analysis 80.8%. | | sociodemographic variables, menopausal status, 22 symptom checklist, self-rated health, lifestyle factors, blood samples FSH, E2, Inhibin, Factor 1 of Personal Experiences Questionnaire | | | | | | | | | | | | | | | | | | | | | | premenstrual complaints, negative attitudes to aging and menopause, parity of one child, number of symptoms, poor self-rated health, negative feelings for the partner, lack of a partner, current smoking, exercising < once a week, ≥3 daily hassles, moderate or high interpersonal stress | | However, menopausal transition interacts (amplifies negative effects of these variables on mood) with paid work, self-rated health, daily hassles.
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Significant predictors of Change in Negative Mood (mood changes if factor changes) (p < 0.001 to p=0.05):
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | symptoms, self-rated health, feelings for partner, marital status, interpersonal stress
Dennerstein, 2000 Australia | Melbourne Women's | 172 | Longitudinal | _ | 7 year follow-up | _ | _ | _ | 50.3 | 172 women of the 438 in the longitudinal cohort were included. They were premenopausal at baseline and either perimenopausal or postmenopausal at follow-up. | Questionnaires, physical exam, blood samples, telephone interview | 89% for longitudinal cohort at 7year follow-up. | _ | North American symptom checklist, sociodemographic, health and well-being, menstrual calendars, blood samples E2, FSH | By post-menopause, the average total number of symptoms reported increased by 17% from 4.2 to 4.9 (p<.001) | _ | _ | _ | _ | _ | _ | 33.6% BMI>25 | Night sweats (p<0.01) and hot flushes (p<0.001) increased in the late peri and post-menopause . Magnitude of change between early and late perimenopause +27% for hot flushes, +17% for night sweats. | Vaginal dryness increased in late perimenopause and post-menopause (P<0.001). Magnitude of change between early and late perimenopause +17%. | Trouble sleeping severity score increased in late peri and post-menopause (p<0.05). Magnitude of change +6% between early and late perimenopause (gradual increase across menopausal categories). | _ | _ | Somatic symptoms (other than breast soreness) did not change significantly with transition to late-peri or post-menopause. | Urinary symptoms did not change significantly with transition to late-peri or post-menopause. | _ | _ | | Breast soreness severity scores were reduced in late peri and post-menopause compared to pre and early perimenopause (p<0.001), Magnitude of change -21%. | FSH, E2, all predictors used in the model are not listed | Logistic regression to determine predictors of symptoms in late perimenopause | Hot flash model: | | E2 is the best predictor for vasomotor symptoms.
| | | | | | | | | | For women who had hysterectomy, bilateral oophorectomy, endometrial ablation (n=10) or took HRT (n=53), only information prior to the intervention was used. | | Percentage of original cohort eligible for this study 39%. | | | | | | | | | | | | | | | | | | | | | E2 decreased sharply and FSH increased sharply between early and late perimenopause. | | | number of symptoms > 4 | 6.2
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | occupation professional | 0.1
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | occupation sales/white collar | 0.2
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | smoking pack years at early perimenopause >10 | 7.0
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | estradiol at late perimenopause 30–100 | 20.5
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | estradiol at late perimenopause <30 | 5.0
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Night sweats model:
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | change in E2 from early to late perimenopause | 1.1
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Vaginal dryness model:
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | education >12 y | 0.3
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Trouble sleeping model:
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | well-being at early perimenopause 1.7–2.3 | 0.3
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | well-being at early perimenopause >2.3 | 0.1
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Agree to statement of beliefs about menopause | 5.5
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Hot flushes at late perimenopause - yes | 5.0
Dennerstein, 2001a Australia | Melbourne Women's | 283 | Longitudinal | Internal | 8 years | _ | _ | _ | 48.5 at baseline | Included: | Questionnaires, blood samples, telephone interview | 88% retention at 8 years, percentage eligible for this study 64.6%. | _ | Personal Experiences Questionnaire (SPEQ, based on the McCoy Female Sexuality Questionnaire). PEQ factors include: feelings for partner, sexual responsivity, frequency of sexual activities, libido, partner problems, vaginal dryness/dyspareunia | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | Total SPEQ scores fell from early to late perimenopause (p<0.001). Sexual responsivity (SPEQ2) decreased signifi-cantly (p<0.0001). Sexual frequency, libido, and vaginal dyspareunia did not change significantly. | _ | In control group A (pre- or early perimenopausal), the only parameter to show change with time (1st to 7th year) was sexual responsivity (mean change -0.67, p=0.0005). FSH levels increased (+19.3, p<0.0001) between years 1–7, E2 levels decreased (-212, p<0.01) between years 3–8. | _ | _ | _ | _ | Sexual responsivity (SPEQ2) decreases with time across all groups. The other five domains of sexual functioning were not affected by time but changed with the menopausal transition.
| | | | | | | | | | Group M = 197 women who transitioned through menopause | | | | FSH, E2, menopausal status/menstrual diaries | | | | | | | | | | | | | | | | | Partner's problems with sexual performance in-creased significantly (p<0.001) and women's positive feelings for partner declined significantly (p<0.05). | | In control group B (post-menopausal), the only parameter to show change was sexual responsivity (mean change -0.42, p=0.036). No significant change in FSH or E2.
| | | | | | | | | | Group A = 44 stayed pre-or early perimenopausal | | | | | | | | | | | | | | | | | | | | | From late peri to postmenopause total SPEQ score declined further (p<0.01) as did scores for sexual responsivity (p<0.01), libido (p<0.01), and frequency of sexual activities (p<0.05).
| | | | | | | | | | Group B = 42 stayed postmenopausal between years 3 and 8 | | | | | | | | | | | | | | | | | | | | | Significant increase in vaginal dyspareunia (p<0.01) and partner's problems with sexual performance (p<0.05).
| | | | | | | | | | Excluded: dropouts, surgical menopause, oral contraceptive use at any year, had not passed through enough menopausal categories.
Dennerstein, 2001b Australia | Melbourne Women's | 267 | Longitudinal | _ | 8 years | _ | _ | _ | 48.8 years at baseline | Excluded: dropouts (57), surgical menopause (36), oral contraceptive use at any year (5), lack of baseline data on some measures (5), failure to reach late perimenopause during 8 years of study (26), HRT use before reaching late perimenopause (42). | Questionnaires, physical exam, blood samples, telephone interview | 88% retention at 8 years, percentage eligible for this study 61%. | _ | Affectometer-2, menstrual status, sociodemographic variables, lifestyle variables | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | Mean positive mood scores by study year did not show any linear trend with time. | _ | _ | _ | _ | _ | _ | _ | _ | General linear model of factors affecting positive moods during midlife. | Premenopausal positive mood scores were significantly influenced by baseline interpersonal stress (B=-0.113, p=0.009) and baseline attitudes to aging (B=0.054, p=0.026). | _ | The most important predictor of positive mood in late peri- and post-menopause is positive mood in pre- and early perimenopause.
| | | | | | | | | | | | | | | | | | | | | | | | | | No significant change in positive mood over the menopausal transition. | | | | | | | | | Final model: Predictors of Positive Mood Late in the Menopausal Transition | Postmenopausal positive mood scores were significantly influenced by premenopausal positive mood scores (B=0.717, p=0.000), dysphoric symptom change (B=-0.085, p=0.000), change in marital status (B=0.342, p=0.007), major life events (B=-0.124, p=0.042), daily hassles (B=-0.016, p = 0.014), work satisfaction (B=0.493, p=0.000). | | BMI was not a significant predictor of positive mood.
| | | | | | | | | | | | | | | | | | | | | | | | | | Premenopausal positive mood scores correlated significantly with late perimenopausal (r=0.61) and postmenopausal (r=0.66) positive mood scores. | | | | | | | | | | Premenopausal positive mood scores (B=0.730, p=0.000) dysphoric symptom change (B=-0.108, p=0.000) change in marital status (B=0.353, p=0.004) major life events (B=-0.136, p=0.019) daily hassles (B=-0.015, p = 0.011) work satisfaction (B=0.456, p=0.000). | | Smoking was not a significant predictor of positive mood.
| | | | | | | | | | | | | | | | | | | | | | | | | | Late perimenopause positive mood scores correlated with post-menopause positive mood scores (r=0.68)
Dennerstein, 2002a Australia | Melbourne Women's | 226 | Longitudinal | _ | 8 years | _ | _ | _ | | Participants included in this analysis could provide at least one measure of well-being during early menopausal transition, late transition and post-menopause. Yearly measures associated with HRT were excluded. | Questionnaires, physical exam, blood samples, telephone interview | Retention rate for longitudinal arm 88% at 8 years. Percentage of original cohort (438) used in this study 51.6%. Percentage of those eligible for this analysis 66.5%. | _ | Well-being using Affectometer-2 | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | No significant change in positive mood scores with menopausal transition. Significant decrease in negative mood and significant improvement in well-being scores between early and late perimenopause and early and post-menopause. | _ | _ | _ | _ | _ | _ | _ | 14 predictors including baseline measures of physical and mood symptoms, lifestyle measures, and well-being | Multifactor model of well-being change during midlife - late menopausal transition model. | Well-being in the early menopause was the only baseline variable that influenced well-being in the late menopause. | _ | As women transition from early to late perimenopause and post-menopause there is an improvement in measures of well-being. Well-being appears to be influenced by psychosocial factors.
| | | | | | | | | | The original longitudinal cohort of 438 had 57 drop out, 36 had surgical menopause, 5 used oral contraceptives. 226 of 340 eligible participants were included. | | | | symptoms | | | | | | | | | | | | | | | | | | | | | Influence of vasomotor symptoms and vaginal dryness on well-being. | Well-being before late menopause (B 0.72, p 0.00)
| | | | | | | | | | | | | | demographics | | | | | | | | | | | | | | | | | | | | | Influence of hormone levels on well-being. | dysphoric symptoms (B -0.20, p 0.00)
| | | | | | | | | | | | | | lifestyle factors | | | | | | | | | | | | | | | | | | | | | Final model of well-being in the late menopausal transition using findings from the previous models. | changing marital status (becoming married or taking a partner (B 0.46, p 0.02)
| | | | | | | | | | | | | | BMI | | | | | | | | | | | | | | | | | | | | | (Results were the same for post-menopause.) | change in satisfaction with work (B 0.63, p 0.00)
| | | | | | | | | | | | | | menopausal status | | | | | | | | | | | | | | | | | | | | | Regression analysis on change in well-being from early to late menopausal transition. | experiencing a severe life event (B -0.2, p 0.03)
| | | | | | | | | | | | | | FSH, E2, Testosterone | | | | | | | | | | | | | | | | | | | | | | increase of hassles (B -0.02, p 0.04).
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | No significant effect of vasomotor symptoms, vaginal dryness, or hormones on well-being.
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Well-being before late menopause (B 0.63, p 0.00)
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | changing marital status (becoming married or taking a partner (B 0.54, p 0.01)
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | change in satisfaction with work (B 0.71, p 0.00)
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | experiencing a severe life event (B -0.17, p 0.06)
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | increase of hassles (B -0.03, p 0.00)
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Changing marital status (becoming married or taking a partner (B 0.71, p 0.00)
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | change in satisfaction with work (B 0.80, p 0.00)
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | experiencing a severe life event (B -0.23, p 0.03)
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | constant difference (between menopausal categories) (B 0.16, p 0.00)
Dennerstein, 2002b Australia | Melbourne Women's | 226 | Longitudinal | _ | 8 years | _ | _ | _ | Year 1 - mean age of women in early menopausal transition was 49.1 years. | Women were excluded from analysis if they dropped out, had surgical menopause, took oral contraceptives or hormones, or did not complete the sexuality measure or blood sampling. 226 of original 438 were available for analysis. | Questionnaires, physical exam, blood samples, telephone interview | 88% retention at 8 years, percentage eligible for this study 51.6%. | _ | Personal Experiences Questionnaire (SPEQ, based on the McCoy Female Sexuality Questionnaire), Affectometer 2, FSH, E2, T (testosterone), DHEAS, SHBG (sex hormone-binding globulin, menopausal status/menstrual diaries | _ | Excluded | _ | _ | _ | _ | _ | _ | _ | _ | _ | Positive and negative mood did not correlate with any of the hormone measures. Positive mood increased with age (B 0.01, p 0.042) and negative mood decreased with age (B -0.009, p 0.012). | _ | _ | _ | _ | 42% of women in early menopausal transition at year 1 had SPEQ scores in-dicating sexual dysfunction com-pared with 88% of postmenopausal women at year 8 of follow-up. | _ | _ | _ | “Repeated-measures linear regression was used to model total and domain scores on SPEQ and mood scores as a function of age, log of free testosterone index, and log of free estradiol index.” | Total SPEQ score: | _ | “Female sexual functioning declines with the natural menopause transition.” No association of androgen levels with sexual functioning. However, there was an association of decreasing estrogen levels with decline in sexual functioning.
| | | | | | | | | Year 8 - mean age of postmenopausal women was 57.1 years. | | | | | | | | | | | | | | | | | | | | | | | | | | | age (B -0.2, p 0.0)
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | log estradiol (B 0.13, p 0.01)
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | log free estradiol index (B 0.12, p 0.014)
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Sexual responsivity:
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | age (B -0.07, p 0.0)
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | log estradiol (B 0.04, p 0.052)
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Frequency of sexual activities:
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | age (B -0.05, p 0.0)
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Libido:
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | age (B -0.45, p 0.0)
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | log estradiol (B 0.087, p 0.001)
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | log free estradiol index (B 0.08, p 0.001)
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | No aspect of sexual functioning was correlated with any of the androgen measures.
Freeman, 2004 | Penn Ovarian Aging Study | 332 | Longitudinal | _ | 4 years | Random digit dialing to all households in Philadelphia County | African American and White women | AA 50% | 35–47 | 75% of eligible participants were enrolled in the full cohort (218 AA, 218 W), 353 of these provided data for this study, 332 did not have usable blood samples and were thus excluded | Questionnaire and interview | 75% | _ | CES-D, DSM-IV criteria for MDD | Women were initially all premenopausal (n=332), by year | Excluded | _ | _ | _ | _ | _ | _ | _ | _ | _ | CES-D scores of 16 or higher incrased during the transition to menopause and were lower after menopause (p=0.047) | _ | _ | _ | _ | _ | _ | _ | Race, age, history of depression, menopausal status, severe PMS, poor sleep, not employed, hot flashes, FSH, antidepressant medications | Multivariate models of CES-D scores and MDD | CES-D | See Significant Predictors column | Only relevant significant predictiors listed for these models. There were other significant predictors in the models.
| | | | | | | | W 50% | | | | | | | Breakdown: | | | | | | | | | | | MDD present in 10–13% of premenopausal and ≤ 4% in transition phases | | | | | | | | | | Menopausal status (pre is reference group)
| | | | | | | | | | | | | | | Pre 227/312 | | | | | | | | | | | | | | | | | | | | | Early transition OR 1.55 (CI 1.04–2.32)
| | | | | | | | | | | | | | | Early transition 64/312 | | | | | | | | | | | | | | | | | | | | | Late transition OR 2.89 (CI 1.29–6.45)
| | | | | | | | | | | | | | | Late transition 10/312 | | | | | | | | | | | | | | | | | | | | | Postmenopausal OR 0.78 (CI 0.1–6.17)
| | | | | | | | | | | | | | | Post 11/312 | | | | | | | | | | | | | | | | | | | | | Race (White is reference)
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | AA OR 1.89 (CI 1.35–2.63)
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | History of depression OR 2.45 (CI 1.61–3.72)
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | MDD
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Race (White is reference)
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | AA OR 1.52 (1.03–2.24)
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Menopausal status NS
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | History of depression OR 4.75 (CI 3.17–7.13)
Glazer, 2002 | Ohio | 208 | Cohort | Internal | 27 months | Community recruitment | NR | 57% White | 40–60 (mean 48) | Reported | Kupperman Index | 208 recruited | _ | Coping Scale | Pre: 38% | NR | NR | NR | NR | Evaluated | NR | _ | _ | _ | _ | _ | _ | _ | NR | NR | NR | NR | Menstrual irregularity and hysterectomy associated with significant level of increased anxiety in univariate analysis, but not multivariate analysis | Menopausal status included in models | Multivariate with 3 outcomes | Predictors of anxiety: | _
| | | | | | | | 43% African American | | | | 175 to 1st follow-up | | Kaufert and Syrotvik Index | Peri: 17% | | | | | | | | | | | | | | | | | | | Education coping effectiveness of resources | | Loss of resources
| | | | | | | | | | | | 165 completed | | Hobfoll Core Evaluation | Post: 14% | | | | | | | | | | | | | | | | | | | Attitude toward menopause | | Education level
| | | | | | | | | | | | | | Bowles Menopause Attitude Scale | SMP: 33% | | | | | | | | | | | | | | | | | | | Coping use | | Coping effectiveness
| | | | | | | | | | | | | | Depression Scale | | | | | | | | | | | | | | | | | | | | Age | | Predictors of depression:
| | | | | | | | | | | | | | Health Promoting Activities | | | | | | | | | | | | | | | | | | | | Race | | Loss of resources
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Job | | Education
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Income | | Predictors of health promoting activities:
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Marital status | | Coping effectiveness
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Religion | | Attitude towards menopause
Gold, 2000 | SWAN | 12,425 | Cross-sectional (baseline survey 1995-7) | N/A | N/A | _ | _ | AA 29.5% | 40–55 range %: | 3640 of 16065 were excluded because 1) menses had stopped because of medication, radiotherapy, pregnancy/lactation, or extreme weight change, 2) reported use of exogenous female hormones in the past 3 months, 3) reported race/ethnicity as mixed/other. | _ | 77.34% | | Yes/No questions regarding presence of vasomotor, psychological, and physical symptoms during the previous 2 weeks | Surgical 16% | 1988/12425 (16%) | NR | NR | NR | Smoking: | _ | BMI: | By menstrual status: | By menstrual status: | Difficulty sleeping by menstrual status: | _ | Forgetfulness by menstrual status: | Stiff/sore by menstrual status: | Urine leakage by menstrual status: | NR | NR | NR | _ | Age, education, employment status, difficulty paying for basics, race/ethnicity, marital status, parity, menstrual status, BMI, smoking, physical activity, study site, parity | Several multiple logistic regression models for the following symptoms: hot flashes/night sweats, urine leakage, vaginal dryness, stiff/sore, heart pounding, forgetful, difficulty sleeping. | See Table 3 p.468 (Key points) | _
| | | | | | | | C 46.5 | 40–43 28.3% | | | | | | Postmenopausal 14.2 | | | | | current 23.4% | | <19 6.4% | surgical 46.9% | surgical 19.4% | surgical 43.5% | | surgical 43.8% | surgical 59.4% | surgical 22.1% | | | | | | | -All symptoms were more frequent in women who were not premenopausal (p<0.05).
| | | | | | | | J 5.7 | 44–47 31.0% | | | | | | Late perimenopausal 4.9 | | | | | past 23.3 | | 19–26.9 42.7% | post 48.8% | post 21.2% | post 40.4% | | post 42% | post 54.8% | post 17.7% | | | | | | | -Hot flashes/night sweat prevalence was associated with BMI >=27 (p<0.05).
| | | | | | | | Chinese 4.4 | 48–51 24.0% | | | | | | Early perimenopausal 28.6 | | | | | never 53.3 | | 27–31.9 21.5% | late peri 56.8% | late peri 18.2% | late peri 43.9% | | late peri 44.8% | late peri 58.4% | late peri 19.6% | | | | | | | -Vaginal dryness was not associated with BMI.
| | | | | | | | H 13.8 | 52–55 16.7% | | | | | | premenopausal 36.3 | | | | | | | >=32 19.4% | early peri 36.9% | early peri 12.9% | early peri 40.6% | | early peri 44% | early peri 57.9% | early peri 20.6% | | | | | | | -Hot flashes were not associated with an increased BMI in late perimenopausal and postmenopausal women (data not shown).
| | | | | | | | | | | | | | | | | | | | | | | pre 19.4% | pre 7.1% | pre 30.9% | | pre 31.2% | pre 45.8% | pre 12.3% | | | | | | | -Compared to W women, J and Chinese had decreased odds of hot flashes (OR 0.63, 0.65), AA women had increased odds (OR 1.56). H had increased odds of vaginal dryness (OR 1.85)
| | | | | | | | | | | | | | | | | | | | | | Compared to BMI 19–26.9, OR for hot flashes (p<0.05): | Compared to premenopausal status (p<0.05): | Compared to premenopausal status (p<0.05): | Compared to premenopausal status (p<0.05): | | Compared to premenopausal status (p<0.05): | Compared to premenopausal status (p<0.05): | Compared to premenopausal status (p<0.05):
| | | | | | | | | | | | | | | | | | | | | | 27–31.9 OR 1.15 | surgical OR 2.4 | surgical OR 2.39 | surgical OR 1.52 | | surgical OR 1.27 | surgical OR 1.50 | surgical OR 1.64
| | | | | | | | | | | | | | | | | | | | | | ≥ 32 OR 1.18 | post OR 2.81 | post OR 2.57 | post OR 1.37 | | post OR 1.28 | post OR 1.31 | post OR 1.24
| | | | | | | | | | | | | | | | | | | | | | | late peri OR 4.32 | late peri OR 2.30 | late peri OR 1.48 | | late peri OR 1.43 | late peri OR 1.48 | late peri OR 1.42
| | | | | | | | | | | | | | | | | | | | | | | early peri OR 2.06 | early peri OR 1.77 | early peri OR 1.25 | | early peri OR 1.44 | early peri OR 1.48 | early peri OR 1.67
Gracia, 2004 | Penn Ovarian Aging Study | 326 | Cross-sectional analyses from cohort | Internal | 4 years | Women in Philadephia County indentified through random digit dialing | Community-based, Philadephia | AA 48–51% | 35–47 | Excluded: | Serum blood samples | Of 578 eligible, 75% agreed to participate. Of those participating, 326 were eligible for this analysis. | 3 for medical problems, 6 for family conflicts, 5 moved, 2 deceased, 8 too busy, 26 lost to f/u, 27 had insufficient hormone measures, 3 withdrew consent, 30 gave no reason. | CES-D | Premenopausal 147 (45%) | Excluded | Excluded | NR | Excluded | NR | Excluded if HRT or any hormone within past 3 months | Mean BMI 28 | | | | | | | | | At 4 years (6th assessment): 27% (87 of 326 women) reported a decreased in libido or sexual interest vs 73% (239) reported no change. | | | Variables in the model: age, BMD, race, marital status, depression (CES-D), presence of child <18 yr old at home, vaginal dryness, mean testosterone level. | multivariate models | In MV analysis, vaginal dryness was strongly associated with decreased libido (OR 3.5, CI 1.8, 6.6), as was depression (OR 3.4, CI 1.9, 6.1) | Significant predictors of decreased libido were: | No results for hormone levels or libido by menoapusal status.
| | | | | | | | | | Serious illness with potential to effect hormone levels | Questionnaires | | | Total testosterone, DHEAS | Early menopausal (variable cycle lengths) 140 (42%) | | | | | | | | | | | | | | | | Women with decreased libido were more likely to report vaginal dryness (38% vs 13%) and depressive symptoms (52% vs 28%) | | | | | Depression remained a significant predictor of decreased libido eeven after excluding women on anti-depressants | Having children < age 18 at home OR 1.4 (CI 1.1, 1.7), p=0.014 | No adjustment for menopausal status in the MV analysis.
| | | | | | | | | | Any hormone use in past 3 months | | | | FSH, LH, E2 | Late menopausal (3–11 mo of ammenorrhea) | | | | | | | | | | | | | | | | | | | | | Fluctuation in testosterone was associated with decreased libido | Depression OR 3.4 (1.9, 6.1), p<0.0001
| | | | | | | | | | Preganancy, lactation, or use of psychotropic drugs | | | | Libido assessed with one question “Have you experience a decrease in libido?” | Post-menopausal 14 (4.3%) | | | | | | | | | | | | | | | | | | | | | Overal levels of testostertone and DHEAS were no different between those with decrease in libido and those with no change. | Vaginal dryness OR 3.5 (1.8, 6.6), p<0.0001
| | | | | | | | | | Use of alcohol/illicit drugs in past 1 yr | | | | | | | | | | | | | | | | | | | | | | | | | | Fluctuation of other hormones was not relatex to libido. | Degreee of testosterone fluctuation was divided into quartiles. All quartiles (2, 3,4) were significant predictors compared to lowest quartile. (OR for 4th quartile vs 1st: 4.0 (CI 1.62, 10.03), p=0.003.
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Age, BMI and Causasian race were not associated with decreased libido.
Guthrie, 1996 Australia | Melbourne Women's | 453 | Cross-sectional | _ | 3rd year of follow-up | _ | _ | _ | By menstrual group | Longitudinal cohort, excluded if they had undergone hysterectomy by the time of follow-up | _ | _ | _ | _ | _ | _ | _ | _ | _ | No significant difference in smoking status between women who did and did not have hot flashes for the whole cohort and by menstrual group. | _ | BMI in kg/m2 did not differ across menstrual groups (p=.239) | ≥ 1 in last 2 weeks by menstrual status (p<.001): | _ | _ | _ | _ | _ | _ | _ | _ | _ | FSH, E2, and inhibin (INH) levels by menstrual group. Compared to no change group (p<0.05): FSH levels were higher in all groups but change in flow and change in frequency. E2 and INH were lower in both amenorrhea groups, INH was lower in HRT group. | Hormonal, physical, and lifestyle variables | Effect of variables on presence of vasomotor symptoms multiple linear logistic regression conducted in peri- and post-menopausal women. | Peri: | _
| | | | | | | | | No change 50.2 | | | | | | 12% | | | | | | | 26.6 | post 62% | | | | | | | | | | FSH 13 | | | premenstrual complaints 1.42 (1.04–1.93)
| | | | | | | | | Change in flow 50.1 | | | | | | 19% | | | | | | | 27.4 | peri 37% | | | | | | | | | | E2 249.3 | | | FSH 1.71 (1.15–2.55)
| | | | | | | | | Change in frequency 59.8 | | | | | | 6% | | | | | | | 25.6 | pre 13% | | | | | | | | | | Inhibin 187.4 | | | Estradiol NS
| | | | | | | | | Change in flow and frequency 51.2 | | | | | | 20% | | | | | | | 25.9 | HRT users 15% | | | | | | | | | | FSH 13.8 | | | Post:
| | | | | | | | | Amenorrhea >3<12 months 52.4 | | | | | | 15% | | | | | | | 26.7 | As the frequency of hot flash reporting increased the FSH levels increased and E2 levels decreased. | | | | | | | | | | E2 243.7 | | | premenstrual complaints NS
| | | | | | | | | Amenorrhea >12 months 53.7 | | | | | | 15% | | | | | | | 26.2 | | | | | | | | | | | Inhibin 189.6 | | | FSH NS
| | | | | | | | | Hormone therapy 52.7 | | | | | | 24% | | | | | | | 25.3 | | | | | | | | | | | FSH 19.7 | | | Estradiol NS
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | E2 196.8
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Inhibin 170.2
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | FSH 19.5
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | E2 256.9
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Inhibin 165.2
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | FSH 69.2
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | E2 81.4
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Inhibin 98.9
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | FSH 93.9
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | E2 37.9
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Inhibin 76.2
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | FSH 26
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | E2 357.4
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Inhibin 89.5
Hallstrom, 1985 Sweden | Gothenburg | 899 | Cohort | Internal | 6 years | Systematic sampling of Gothenburg Sweden population using Taxation Office Register. Sampling methods described elsewhere. Unclear in this paper how the “psychiatric population” was selected from the larger sample | _ | NR | 38–60 | _ | _ | 899 participated in the first wave, of these 800 were examined. Of those 800 677 (84.6%) were examined in the second wave | 12 died, 30 moved or could not be reached, 81 refused. | <age 38 considered pre-climacteric | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | Cross-sectional data at baseline: | _ | _ | _ | _ | _ | _ | _ | _ | No MV modeling | _ | _ | Proportion of women developing a mental disorder within one year after the menopause compared with the proportion of women developing a mental disorder without life events one year before: 9 (15.8%) after menopause vs. 15 (12.8%) prior to menopause and without a life event (NS by Fisher's exact).
| | | | | | | | | | | | | | age>44 and regularly menstruating=premenopausal | | | | | | | | | | | | Major depression N=55 (6.9%) | | | | | | | | | | | | Lumped all mental disorders together.
| | | | | | | | | | | | | | irregular | | | | | | | | | | | | anxiety N=18 (2.3%)
| | | | | | | | | | | | | | menstruations=perimenopausal | | | | | | | | | | | | Neurasthenic state N=14 (1.8%)
| | | | | | | | | | | | | | amenorrhea for 12–35 months=early menopause | | | | | | | | | | | | Phobic disorder N=10 (1.3%)
| | | | | | | | | | | | | | amenorrhea for 36 months=post-menopause. | | | | | | | | | | | | Obsessive compulsive disorder N=2 (0.3%)
| | | | | | | | | | | | | | Global assessment of functioning, disability grade, diagnostic interview for diagnoses of major depression, anxiety states, neurastenic state, phobic disorder, obsessive compulsive disorder, psychoses, alcoholism. | | | | | | | | | | | | Pyschosis N=4 (0.5%)
| | | | | | | | | | | | | | | | | | | | | | | | | | Alcoholism N=2 (0.3%)
| | | | | | | | | | | | | | | | | | | | | | | | | | 1 year onset rate of any psychiatric symptoms:
| | | | | | | | | | | | | | | | | | | | | | | | | | Pre climacteric: N=78 (15.5%) age <38
| | | | | | | | | | | | | | | | | | | | | | | | | | Pre menopause: N=190 (37.8%)
| | | | | | | | | | | | | | | | | | | | | | | | | | Peri: N=126 (25.1%)
| | | | | | | | | | | | | | | | | | | | | | | | | | Early Post menopasue: N=54 (10.8%) (12–35 months after menopause)
| | | | | | | | | | | | | | | | | | | | | | | | | | Late postmenopause: N=54 (10.8%) (menopause > 3 years ago)
Hardy, 2002 Britain | Medical Research Council (MRC) National Survey for Health and Development | 1572 | Cohort | Internal | 52 years | Socially stratified sample of all births in March 1943 in Britain | Socially stratified birth cohort in Britain, those interviewed in 1993 (age 43) were representative of the native population of that age. | NR | 52 | _ | _ | 2548 women enrolled at birth (March1946). | 232 living abroad; 296 refused to participate; 88 could not be located; 154 had died as of 1993. | Checklist of 20 health problems (1–4 for each symptom) | _ | _ | _ | _ | _ | _ | _ | _ | Vasomotor symptom score: | _ | _ | Psychological change score: | _ | _ | _ | _ | _ | _ | Found the largest change in percentage vasomotor symptom score between women who were premenopausal and became postmenopausal (17.73) and those who were premenopausal and started HRT (19.25). Change scores were high among those who were peri-menopausal and remained peri-menopausal after 6 years (12.31). Those who were post-menopausal and remained post-menopausal had the lowest change score (0.29). | _ | MV models adjusted for prior psychological status and personality (neuroticism score at age 16, present state examination (PSE) for anxiety and depression at age 36), health related behaviors, socio-economic status (highest education, job held at age 43), attitude to menopause, smoking, BMI at age 36, age and baseline score. | Change in menopausal status. | _
| | | | | | | | | | | | 1778 still in contact as of 1993. | | | | | | | | | | | Peri-peri: 12.31 (10.44, 14.18) | | | Pre-post: 4.74 (-1.74, 11.23) | | | | | | | Change in percentage psychological symptom score was highest among those women who were premenopausal and became post-menopausal (4.74); those who were pre-menopausal and went on HRT (6.4), and those who were peri-menopausal and went on HRT (4.38). | | | Change in work stress.
| | | | | | | | | | | | 1572 women returned at least one questionnaire (84–90% RR) over the next 4 years for this study. | | | | | | | | | | | Post-post: 0.29 (-1.55, 2.12) | | | Pre-HRT: 6.4 (2.12, 10.69) | | | | | | | Lowest psychological change scores were found in those who were post- and remained post (-0.12) and those who were peri and had a hysterectomy (-1.12). | | | Change in family stress.
| | | | | | | | | | | | | | | | | | | | | | | Hysterectomy-hysterectomy: 3.46 (1.72, 5.19) | | | Peri-HRT: 4.38 (1.54, 7.21) | | | | | | | | | | (true for both HR and psychological outcomes)
| | | | | | | | | | | | | | | | | | | | | | | HRT-HRT: -2.93 (-4.6, -1.26) | | | Post-post: -0.12 (-1.40, 1.15)
| | | | | | | | | | | | | | | | | | | | | | | Pre-peri: 8.44 (6.11, 10.79) | | | Peri-Hysterectomy: -1.12 (-8.36, 6.15)
| | | | | | | | | | | | | | | | | | | | | | | Vasomotor change in % score: | | | Peri-Post: 1.58 (-0.65, 3.81)
| | | | | | | | | | | | | | | | | | | | | | | Pre-post: 17.3 (6.33, 29.13) | | | Peri-peri: 0.98 (-0.30, 2.26)
| | | | | | | | | | | | | | | | | | | | | | | Pre-HRT: 19.25 (12.96, 25.52) | | | Hysterectomy-hysterectomy: 0.41 (-0.75, 1.57)
| | | | | | | | | | | | | | | | | | | | | | | Pre-hysterectomy: 9.87 (-0.37, 20.10) | | | Pre-peri: 1.57 (-0.15, 3.29)
| | | | | | | | | | | | | | | | | | | | | | | Pre-Peri: 8.44 (6.11, 10.76) | | | Pre-hysterectomy: 2.43 (-4.78, 9.63)
| | | | | | | | | | | | | | | | | | | | | | | Post-Post: 0.29 (-1.55, 2.12)
Hunter, 1989 London | None | 682 | Cross-sectional | _ | _ | Newspaper ads, radio program, volunteers for ovarian cancer screening | Women aged 45–65 years predominantly from London and South-East England | NR | 52.3 (45–65) | Excluded: Women receiving estrogen therapy, women who had undergone hysterectomy | Questionnaires | 78% (850/1090) to initial postal survey, 62.6% after exclusions | _ | “Women's Health Questionnaire” developed by the authors | Premenopausal 18% | Excluded | _ | _ | _ | _ | _ | _ | Vasomotor symptoms increased with menopausal status. 55% of peri- and postmenopausal vs. 15% premenopausal women (p<0.000). | Vaginal dryness increased with menopausal status. 25% of pre- and perimenopausal vs. 45% postmenopausal women (p NR). | Sleep problems increased with menopausal status (p <0.005) even when controlling for age. | Depressed Mood category of symptoms increased with transition to peri- and post-menopause (p<0.002) but there were only two items in this group that increased significantly “lack of enjoyment” and "no feelings of well-being, reported by 5% of premenopausal and 15% of peri- and postmenopausal women. | No significant difference by menopausal status. | No significant difference by menopausal status. | _ | _ | Sexual problems increased with menopausal status (p<0.04). | _ | _ | Menopausal status, age, reported current illness, marital status, social class, employment status (only 45–54 year olds included). | Multiple regression for each factor score (symptom group) | Symptoms groups with menopausal status as a significant predictor (p<0.05). | | Factor analysis done prior to use of scores for ANCOVA and regression analysis.
| | | | | | | | | | | | | | Pilowsky Hypochondriasis Questionnaire | Perimenopausal 26% | | | | | | | | | | | | | | | | Sexual interest decreased significantly in peri- and post-menopausal women even when controlling for age. Sexual satisfaction did not change with menopausal status. | | | | | Depressed Mood: | B 0.17
| | | | | | | | | | | | | | General Health Questionnaire | Postmenopausal 56% | | | | | | | | | | | | | | | | | | | | | menopausal status | B 0.17
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Somatic symptoms: | B 0.29
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | menopausal status | B 0.16
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Vasomotor symptoms: | B 0.11
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | menopausal status
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Sexual problems:
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | menopausal status
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Sleep problems:
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | menopausal status
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Menopausal status was not a significant predictor for cognitive difficulties and anxiety/fears.
Kaufert, 1992 | Manitoba | 469 | Cross-sectional and longitudional | _ | 3 years | Mail survey of women from general population of Manitoba, Canada | Manitoba, Canada | NR | 45–55 (mean 48.4) | Inclusion: menstruated in the last 3 months, or had previously had a hysterectomy, age 45 or older | Mail and telephone surveys | 68% to mail survey | _ | CES-D | _ | 136 (no differentiation by oophorectomy status) | NR | NR | NR | _ | _ | _ | _ | _ | _ | Depression | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _
| | | | | | Age 40–59 years | | | | | | 87% of those eligible for longitudional follow up agreed to participate | | Modified Worsley's ‘Role Problem Checklist’ | | | | | | | | | | | | 26% of all women were depressed at one interview or another. Across all 5 interviews, the percentage of women with CES-D ≥ 16 was 9–11%. All depression data was collapsed across the 5 interviews to look at the association between depression and transition from one menopausal status to another. A woman's menopausal status does not significantly alter the likelihood of her becoming depressed (hysterectomized women excluded). Hysterectomized women who were not depressed at baseline were more likely than women in any other menopausal category to become depressed (OR 1.7, CI 1.15, 2.6).
| | | | | | | | | | | | | | Questions regarding recent life events, menses, 4 health conditions (arthritis, allergies, high blood pressure, thyroid problems), and present state of health (good, fair, or poor)
Koch, 1995 | University of Minnesota and Tremin Trust Longitudinal Study | 391 | Cross-sectional from cohort | Internal | Prevalence | College class | 852 eligible participants from college class of 1963 and the Tremin Trust Longitudinal Study | 99% White | Mean 46 | Specified | Survey | _ | _ | Survey | Excluded | NR | NR | NR | NR | NR | NR | 24% reported | 36% in perimenopausal group | NR | NR | NR | NR | NR | NR | 46% noted change in prior year | NR | NR | Age | Change in desire, marital status, vaginal dryness, enjoyment with partner, age. | Logistic regression | Only Betas and x^2^ reported for each predictor variable | _ | Premenopausal: 21%
| | | | | | | 505 surveys returned | | | | | | | | | | | | | | | Significantly related to age and menopausal status | | | | | | | | | | | Marital status | Menopausal status not related to reduced desire, reduced orgasm, or less enjoyment. | | | | Perimenopausal: 79%
| | | | | | | 391 eligible | | | | | | | | | | | | | | | | | | | | | | | | | | Menopausal status
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Vaginal dryness
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Hot flashes
Koster, 1993a | Copenhagen | 621 | Cross-sectional from cohort | Internal | 4 years | NR | Danish women born in 1936, from 4 municipalities in Copenhagen | 100% Danish | 51 year olds | Inclusion: | Questionnaire | 526 (88%) | By 1987, 22 died, 2 emigrated (n=597) from original cohort | Postal questionniare and telephone contact | In 1987 | Examined | _ | _ | _ | _ | Excluded | _ | Increased prevalence within groups | _ | _ | Increased prevalence of moodiness within groups | _ | Increased prevalence of fatigue within groups | _ | _ | _ | _ | _ | Not significant: | Logistic regression models | _ | OR (see symtom columns) | Prevalence data reported.
| | | | | | | | | | In 1976, all 40 year old women born in 1936, resident in 4 municipalitites in Copenhagen, in good general health | | | 526 usable questionnaires returned | | Pre 47 (9%) | | | | | | | | Pre to peri: beta 0.81 (p<0.0001) OR 2.24 (1.90–2.64) | | | Pre to peri: beta 0.17 (p<0.017) OR 1.19 (1.03–1.37) | | Pre to peri: beta 0.24 (0.004) OR 1.27 (1.08–1.49) | | | | | | Headache, depression, moodiness from peri - post menopausal status
| | | | | | | | | | | | | | | Peri 91 (7%) | | | | | | | | Peri to post: beta 0.41 (p<0.0001) OR 1.51 (1.25–1.81) | | | | | Peri-post: beta 0.21 (p<0.041) OR 1.23 (1.01–1.50)
| | | | | | | | | | | | | | | Post 129 (25%)
| | | | | | | | | | | | | | | HRT 175 (33%)
| | | | | | | | | | | | | | | SM 84 (16%)
| | | | | | | | | | | | | | | In 1986
| | | | | | | | | | | | | | | Pre 66 (13%)
| | | | | | | | | | | | | | | Peri 121 (23%)
| | | | | | | | | | | | | | | Post 93 (18%)
| | | | | | | | | | | | | | | HRT 163 (31%)
| | | | | | | | | | | | | | | SM 83 (16%)
| | | | | | | | | | | | | | | In 1985
| | | | | | | | | | | | | | | Pre 135 (26%)
| | | | | | | | | | | | | | | Peri 95 (18%)
| | | | | | | | | | | | | | | Post 129 (25%)
| | | | | | | | | | | | | | | HRT 144 (27%)
| | | | | | | | | | | | | | | SM 81 (15%)
| | | | | | | | | | | | | | | In 1984
| | | | | | | | | | | | | | | Pre 205 (39%)
| | | | | | | | | | | | | | | Peri 67 (13%)
| | | | | | | | | | | | | | | Post 51 (10%)
| | | | | | | | | | | | | | | HRT 125 (24%)
| | | | | | | | | | | | | | | SM 78 (15%)
Koster, 1993b | Copenhagen | 621 | Cross-sectional from cohort | Internal | 11 years | NR | Danish women born in 1936, from 4 municipalities in Copenhagen | 100% Danish | 40–51 year olds | Inclusion: | Questionnaire and interview | NR | 474 (76%) of original cohort in this study | Questionnaire, interview, clinical assessment from a trained psychiatrist using diagnostic criteria developed by Bollerup for The Glostrup Population Studies (psychological health status), criteria from The Danish National Institute of Scoial Research (social status) | See Koster 1993 | Examined | _ | _ | _ | _ | Excluded | _ | _ | _ | _ | _ | _ | _ | _ | _ | Anticipation of decreased sexuality at 40 years was only significant predictor of decreased sexual desire (p<0.01) at 51 years. | _ | _ | Not significant: | Multiple logistic regression models | Age
| | | | | | | | | | In 1976, all 40 year old women born in 1936, resident in 4 municipalitites in Copenhagen, in good general health | | | | | | | | | | | | | | | | | | | | | | | | Social background (education, marital, and social status), life-style (smoking, alcohol-intake, physical fitness) | | Marital status
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Emplyment status
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Social status
Koster, 2002 Denmark | Copenhagen | 621 invited | Cross-sectional | Internal | 20 years | NR | Women in Denmark | NR | 40 at baseline | NR | Survey | 65–88% | NR | Survey evaluating sociodemographic, attitudes, symptoms, general health, sexualty, body image, medication, life events, aging. | | Assessed by numbers NR | NR | NR | NR | Assessed (see measures used column) | NR | NR | [underlined: Prevalence by age (%):] | NR | | [underlined: Depression by age (%):] | _ | [underlined: Headache by age (%):] | NR | NR | [underlined: Decreased sexuality by age (%):] | _ | _ | Strongest predictor of woman's menopause experience was prior health. Sexuality depended on prior sexual experiences. No association between menopausal/peri-menopausal and depression/moodiness, but hot flashes and fatigue correlated with transition. Also, hot flashes with fatigue associated with various psychosocial factors, which explained much variation in symptoms. | _ | _ | _ | _
| | 548 initially enrolled | | | | | Age 40 in 1976 | | | | Telephone questionnaires or personal interview | | | | | | | | | | | | 40: NR | | | 40: NR | | 40:56 | | | 51:37
| | | | | | | | | | | | | | | | | | | | | | | 45: NR | | | 45: NR | | 51:49 | | | 60:67
| | | | | | | | | | | | | | | | | | | | | | | 51:56 | | | 51:18 | | 60:38
| | | | | | | | | | | | | | | | | | | | | | | 60:29 | | | 60:20 | | [underlined: Headache by menopausal status (%):]
| | | | | | | | | | | | | | | | | | | | | | | [underlined: Prevalence by menopausal status (%):] | | | [underlined: Depression by menopausal status (%):] | | Pre: 44
| | | | | | | | | | | | | | | | | | | | | | | Pre: 31 | | | Pre: 12 | | Peri: 49
| | | | | | | | | | | | | | | | | | | | | | | Peri: 46 | | | Peri: 21 | | Post: 38
| | | | | | | | | | | | | | | | | | | | | | | Post: 68 | | | Post: 16 | | HRT: 56
| | | | | | | | | | | | | | | | | | | | | | | HRT: 56 | | | HRT: 28 | | Surgical menopause: 61
| | | | | | | | | | | | | | | | | | | | | | | Surgical menopause: 61 | | | Surgical menopause: 38 | | [underlined: Fatigue by age (%):]
| | | | | | | | | | | | | | | | | | | | | | | | | | [underlined: Moodiness by age (%):] | | 41:41
| | | | | | | | | | | | | | | | | | | | | | | | | | 51:28 | | 51:34
| | | | | | | | | | | | | | | | | | | | | | | | | | 60:31 | | 60:29
| | | | | | | | | | | | | | | | | | | | | | | | | | [underlined: Moodiness by menopausal status (%):] | | [underlined: Fatigue by menopausal status (%):]
| | | | | | | | | | | | | | | | | | | | | | | | | | Pre: 33 | | Pre: 21
| | | | | | | | | | | | | | | | | | | | | | | | | | Peri: 34 | | Peri: 30
| | | | | | | | | | | | | | | | | | | | | | | | | | Post: 32 | | Post: 26
| | | | | | | | | | | | | | | | | | | | | | | | | | HRT: 49 | | HRT: 35
| | | | | | | | | | | | | | | | | | | | | | | | | | Surgical menopause: 60 | | Surgical menopause: 56
Kravitz, 2003 | SWAN | 12,603 | Cross-sectional | Internal | N/A | Random digit dialing | Random selection of women from multiple sites (Los Angeles, Pittsburgh, Newark, Boston, Chicago, Detroit, and Oakland) | W=6,304 | 40–44 (N=4,233) | _ | Self report questionnaires and interviews | 81% | _ | 12-item symptom questionnaire | Pre=4,425 | 701/12,603 | NR | NR | NR | NR | NR | NR | _ | _ | Overall prevalance of sleep difficulty=38% | _ | _ | _ | _ | _ | _ | _ | _ | Ethnicity and age | Bivariate associations bewtween each covariate and sleep difficulty were examined using X^2^ tests. | Ethnicity | Surgical post = 1.55 (1.25–1.92) | _
| | | | | | | | AA=3,464 | 45–49 (N=4,600) | | | | | | Early peri=3,521 | | | | | | | | | | Most prevalent in surgical post=48% | | | | | | | | | | Multivariate associations ere examined using a multiple logistic regression. | Age | Late peri = 1.33 (1.07–1.65)
| | | | | | | | Chinese=573 | 50–55 (N=3,770) | | | | | | Late peri=607 | | | | | | | | | | Least prevalent in pre=31% | | | | | | | | | | | | Natural post = 1.21 (1.03–1.43)
| | | | | | | | Japanese=606 | | | | | | | Natural post=1,739 | | | | | | | | | | Caucasian (40%) and Hispanic (38%) women reported highest rates of sleep difficulty. | | | | | | | | | | | | Post on HRT = 1.12 (0.95–1.31)
| | | | | | | | Hispanic=1,656 | | | | | | | Surgical post=701 | | | | | | | | | | | | | | | | | | | | | | Early peri = 1.11 (0.99–1.24)
| | | | | | | | | | | | | | | Post on HRT=1,610 | | | | | | | | | | | | | | | | | | | | | | Pre = 1.00
Kuh, 1997 Britain | Medical Research Council (MRC) | 1498 (84% of those who were sent the question-naire) | Cross-sectional | Internal | N/A | National prospective birth cohort in England, Scotland and Wales | Socially stratified birth cohort in Britain, those interviewed in 1993 (age 43) were representative of the native population of that age. | _ | NR | _ | Mailed questionnaire | 84% | _ | Symptom checklist | All women in study (all age 47) | 215 (14.3%) salpingo hysterectomy, analyzed separately | NR | NR | NR | NR | 172 (11.4%) on HRT, analyzed separately | NR | Hot flashes (n=1465): | Vaginal Dryness (n=1399): | Trouble sleeping: | Anxiety or depression (n=1427): | Forgetfulness: | Aches and pains (n=1422): | Urinary frequency (n=1410): | NR | Difficulties with intercourse (n=1381): | NR | Skin crawling sensations (n=1383): | _ | _ | _ | _ | Women were all aged 47 years; anxiety and depression (assessed by PSE), and health status was assessed at age 36.
| | | | | | | | | | | | | | | | | | | | | | | bothered a lot: 7% | bothered a lot: 4.2% | bothered a lot: 13.7% | bothered a lot:16.8% | bothered a lot: 13.1% | bothered a lot:17.1% | bothered a lot:7.9% | | bothered a lot: 3.9% | | bothered a lot: 3.3%
| | | | | | | | | | | | | | | | | | | | | | | bothered a little: 24.4% | bothered a little 15.7% | bothered a little 35.7% | bothered a little: 36.0% | bothered a little: 31.2% | bothered a little: 42.5% | bothered a little:18.6% | | bothered a little: 9.1% | | bothered a little: 11.1%
| | | | | | | | | | | | | | | | | | | | | | | none or not bothered: 68.7% | none or not bothered 80.1% | none/not bothered 50.5% | none/not bothered:50.5% | none/not bothered: 55.7% | none/not bothered: 39.7% | none/not bothered: 73.5% | | none/not bothered: 87.0% | | none/not botherred:85.5%
| | | | | | | | | | | | | | | | | | | | | | | Cold/night sweats (n=1454): | | | irritability (n=1419): | | severe headaches (n=1413): | | | | | skin wrinkling (n=1389)
| | | | | | | | | | | | | | | | | | | | | | | bothered a lot: 6.2% | | | bothered a lot:14.6% | | bothered a lot: 10.9% | | | | | bothered a lot: 3.3%
| | | | | | | | | | | | | | | | | | | | | | | bothered a little: 20.0% | | | bothered a little: 40.2% | | bothered a little: 20.9% | | | | | bothered a little:15.5%
| | | | | | | | | | | | | | | | | | | | | | | none/not bothered:73.8% | | | none/not bothered: 45.2% | | none/not bothered: 68.2% | | | | | none/not bothered: 81.6%
| | | | | | | | | | | | | | | | | | | | | | | | | | tearfulness (n=1414) | | breast tenderness (n=1422): | | | | | hair loss (1383):
| | | | | | | | | | | | | | | | | | | | | | | | | | bothered a lot:11.7% | | bothered a lot: 10.1% | | | | | bothered a lot: 2.1%
| | | | | | | | | | | | | | | | | | | | | | | | | | bothered a little:30.1% | | bothered a little:33.4% | | | | | bothered a little:5.9%
| | | | | | | | | | | | | | | | | | | | | | | | | | none/not botherred:58.1% | | none/not bothered: 56.5% | | | | | none/not botherred:92.0%
| | | | | | | | | | | | | | | | | | | | | | | | | | feelings of panic (1392): | | palpitations (1406):
| | | | | | | | | | | | | | | | | | | | | | | | | | bothered a lot: 7.2% | | bothered a lot: 6.3%
| | | | | | | | | | | | | | | | | | | | | | | | | | bothered a little: 17.2% | | bothered a little:22.4%
| | | | | | | | | | | | | | | | | | | | | | | | | | none/not bothered: 75.6% | | none/not bothered: 71.3%
| | | | | | | | | | | | | | | | | | | | | | | | | | | | pins and needles (n=1399):
| | | | | | | | | | | | | | | | | | | | | | | | | | | | bothered a lot: 5.4%
| | | | | | | | | | | | | | | | | | | | | | | | | | | | bothered a little:20.2%
| | | | | | | | | | | | | | | | | | | | | | | | | | | | none/not bothered: 74.4%
| | | | | | | | | | | | | | | | | | | | | | | | | | | | dizziness (n=1395):
| | | | | | | | | | | | | | | | | | | | | | | | | | | | bothered a lot:4.2%
| | | | | | | | | | | | | | | | | | | | | | | | | | | | bothered a little: 23.6%
| | | | | | | | | | | | | | | | | | | | | | | | | | | | none/not bothered: 72.2%
Kuh, 1997 Britain (continued) | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | Premenopausal women | _ | _ | _ | _ | _ | _ | _ | Bothered by hot flashes (p≤0.001): | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | Logistic regression models to predict bothered a little/lot adjusting for menopausal status, life stress at age 36, physical and emotional health at age 36, smoking behavior in earlier adult life, educational background. | For vasomotor symptoms: significant predictors included menopausal status, educational qualifications, work stress worse in past 12 months, smoking at any time in past, 3+health problems at age 36. Stress in family life was not a significant predictor. | Adjust OR for vasomotor symptoms (post compared to pre)=4.7 (95%CI 2.6, 8.5). Other groups: peri 2.5**, hysterectomy 2.5**, HRT 3.4** compared to pre. | ** data approximated from histogram or OR figure, referred to generally in text.
| | | | | | | | | | | | | | | | | | | | | | | pre: 17%
| | | | | | | | | | | | | | | | | | | | | | | peri: 40%
| | | | | | | | | | | | | | | | | | | | | | | post: 60%
| | | | | | | | | | | | | | | | | | | | | | | HRT: 40%**
| | | | | | | | | | | | | | | | | | | | | | | hysterectomy:42%**
| | | | | | | | | | | | | | | | | | | | | | | bothered by cold/night sweats (p<0.001)
| | | | | | | | | | | | | | | | | | | | | | | pre: 16%
| | | | | | | | | | | | | | | | | | | | | | | peri: 32%
| | | | | | | | | | | | | | | | | | | | | | | post: 45%
| | | | | | | | | | | | | | | | | | | | | | | HRT: 34%**
| | | | | | | | | | | | | | | | | | | | | | | hysterectomy: 36%**
Kuh, 1997 Britain (continued) | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | Bothered by vaginal dryness (p<0.01) | _ | _ | _ | _ | _ | _ | Difficulties with intercourse (bothered a little or a lot, p<0.001) | _ | _ | _ | _ | Significant predictors include: menopausal status, work stress and previous history of 2+health problems at age 36. Not significant were: education, smoking, anxiety/depression in past, family life stress. | Adjusted OR for sexual dysfunction (combines vaginal dryness and difficulties with intercourse=~4**; Also increased were OR for peri (2.2)**, hysterectomy (3.2)**, and HRT (2.4)** groups compared to pre. | ** data approximated from figure showing Ors for groups. Referred to in text as "almost fourfold increase post vs. pre.
| | | | | | | | | | | | | | | | | | | | | | | | pre: 11% | | | | | | | pre: 8%
| | | | | | | | | | | | | | | | | | | | | | | | peri:25% | | | | | | | peri: 13%
| | | | | | | | | | | | | | | | | | | | | | | | post:35% | | | | | | | post: 24%
| | | | | | | | | | | | | | | | | | | | | | | | HRT:25% | | | | | | | HRT:19%
| | | | | | | | | | | | | | | | | | | | | | | | hysterectomy: 28% | | | | | | | hysterectomy: 19%
Kuh, 1997 Britain (continued) | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | Difficulty sleeping (p<0.001) | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | Significant predictors: menopausal status, current stress at home and at work, poorer physical and emotional health at age 36. | Adjusted OR for trouble sleeping: | _
| | | | | | | | | | | | | | | | | | | | | | | | | pre: 40% | | | | | | | | | | | | post=3.4 (95% CI 1.9, 6.2); peri =1.5 (95% CI 1.1–02.0); hysterectomy 2.6 (95% CI 1.8, 3.7); and hysterectomy 2.3 (95% CI 1.5, 3.4) compared to pre.
| | | | | | | | | | | | | | | | | | | | | | | | | peri:50%
| | | | | | | | | | | | | | | | | | | | | | | | | Post: 63%
| | | | | | | | | | | | | | | | | | | | | | | | | HRT:61%
| | | | | | | | | | | | | | | | | | | | | | | | | hysterectomy:64%
Kuh, 1999 Britain | MRC | 1378 | Cross-sectional from cohort | _ | _ | _ | _ | _ | 48 years | All women with whom the investigators were still in contact from the original cohort of 2548 women | Postal questionnaire sent to 1486 women when they were 48 years old | 93% to questionnaire | _ | Questionnaire regarding incontinence (incont) symptoms (no statement of questionnaire validation) | Stress incont symptoms by menopausal status: | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | 55% in the cohort reported incontinence, see menopausal status for breakdown by group, odds of stress symptoms were lower in the postmenopausal versus not menopausal group (OR 0.57, CI 0.33–0.95), no association of urge symptoms or severe incontinence with menopausal status | _ | _ | _ | _ | _ | _ | _ | _ | _
| | | | | | | | | | | | | | | Pre 49.8%
| | | | | | | | | | | | | | | Peri 52.7%
| | | | | | | | | | | | | | | Post 36.3 %
| | | | | | | | | | | | | | | Hyst 53.7%
| | | | | | | | | | | | | | | HRT 47.9%
| | | | | | | | | | | | | | | Urge incont symptoms by menopausal status
| | | | | | | | | | | | | | | Pre 18.1%
| | | | | | | | | | | | | | | Peri 23.8%
| | | | | | | | | | | | | | | Post 18.6%
| | | | | | | | | | | | | | | Hyst 28.8%
| | | | | | | | | | | | | | | HRT 21.0%
| | | | | | | | | | | | | | | Severe incont symptoms by menopausal status
| | | | | | | | | | | | | | | Pre 7.3%
| | | | | | | | | | | | | | | Peri 6.0%
| | | | | | | | | | | | | | | Post 9.8%
| | | | | | | | | | | | | | | Hyst 9.8%
| | | | | | | | | | | | | | | HRT 5.0%
Kuh, 2002 Britain | Medical Research Council (MRC) National Survey of Health & Development | 2547 women in initial cohort. 1023 were available and completed all six questionnaires between 1993-1998 | Cohort with Cross-sectional data | Internal | _ | All births to non-manual and agricultural workers and one in four births to manual workers in the 2nd week of march 1946. | Britain, Scotland, Wales | _ | 52 | _ | Mailed questionnaires | _ | _ | _ | Pre 272 | 240/1284 | NR | NR | NR | _ | HRT users 255/1284 | NR | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | Menopausal status was not a significant predictor of psychological stress in multivariate modeling, adjusting for child and adult behavioral and psychological factors. | Age adjusted OR for psychological symptom score: “Women reporting higher levels of psychological symptoms in midlife were much more likely than their less symptomatic peers to have had health problems previously during their adult life. There was no variation in psychological symptoms according to menopausal stage but HRT users had a higher level of (psychological) symptoms.” | Tables report regression coefficients rather than OR.
| | | | | | | | | | | | | | | Peri 309 | | | | | | | | | | | | | | | | | | | | | | OR shown on Table 3, all cross 1 except OR for HRT users (Regression Coefficient=0.44 (0.20, 0.69).
| | | | | | | | | | | | | | | Post 208 | | | | | | | | | | | | | | | | | | | | | | Test for interaction (to see if effect of perimenopause on the symptom score was greater for women reporting concurrent family stress): perimenopausal women reporting stress had fewer symptoms than premenopausal women reporting stress (p=0.002 for test of interaction).
| | | | | | | | | | | | | | | Hysterectomy 240
| | | | | | | | | | | | | | | HRT 255
Maartens, 2001 Netherlands | Eindhoven | 2450 | Cohort | Internal | _ | Invitation, method NR | All women living in Eindhoven responding to screening recruitment age 46–53 at baseline | _ | 46–53 | Inclusion: | Questionnaires | 2450 responded and eligible | _ | Population Survey | _ | Excluded | _ | _ | _ | NR | NR | NR | Prevalence | Prevalence | Prevalence | Multivariate adjusted OR for change (increase) in depression score | No statistical difference | No statistical difference | No urinary symptoms by stage | NR | Pain with intercourse: | NR | NR | Physical symptoms | Chi square | _ | _ | _
| | | | | | | (n=8503; 6648 agreed to participate) | | | 1. Dutch, Caucasian women | | | | | | | | | | | | | HF OR 5.9 comparing pre to peri menopausal status and OR 1.9 comparing peri to post menopausal status and OR 13.4 comparing pre to post menopausal status | peri vs. post OR 1.6 | peri vs. post OR 1.3 (insomnia) | Transition: | | | | | Pre-peri: not significant | | | Demographic | Logistic regression
| | | | | | | | | | 2. Natural menopause | | | | | | | | | | | | | | | | Pre to peri: not significant | | | | | Peri-post: 1.86 (statistically significant) | | | Cognitive/Mental Symptoms
| | | | | | | | | | 3. No HRT | | | | | | | | | | | | | | | | Pre to post: 0.57 (statistically significant) | | | | | Pre-post: 2.13
| | | | | | | | | | Exclusion:
| | | | | | | | | | 1. Women with hysterectomy or bilateral oophorectomy
| | | | | | | | | | 2. HRT without surgical menopause
| | | | | | | | | | 3. Non-compliance with questionnaire
Maartens, 2002 Netherlands | Eindhoven | 6648 | Prevalence and prospective cohort | Internal | 5 years | Invitation to all women in Eindhoven of which 6648 (78%) participated | All women living in Eindhoven responding to screening recruitment age 46–53 at baseline | White | 46–53 | [underlined: Inclusion:] | Questionnaire | Prevalence: 78% | _ | Mailed Edinburgh depression scale | _ | Excluded | NR | NR | NR | Evaluated | Evaluated | NR | NR | NR | NR | Prevalence depression at baseline | NR | NR | NR | NR | NR | NR | _ | Demographic | T tests for change | Multivariate adjusted OR for depression: | _ | Not adjusted for sleep disturbance
| | | | | | | (n=8503; 6648 agreed to participate) | | | 1. Dutch, Caucasian women | | Follow-up of 2748 with natural menopause and no HRT: 76% | | Gynecologic history | | | | | | | | | | | | Mean Score: | | | | | | | | Major life events | | Transition peri-post 1.8 (1.3–2.6)
| | | | | | | | | | 2. Natural menopause | | 2103 (76%) participated | | General medical history | | | | | | | | | | | | pre - 5.6 | | | | | | | | Prior episodes depression | | Transition pre-peri 1.8 (1.10–3.3)
| | | | | | | | | | 3. No HRT | | | | Demographic data | | | | | | | | | | | | per - 6.5 | | | | | | | | Time between baseline and follow-up exam | | Prior depression 2.2 (1.6–3.0)
| | | | | | | | | | [underlined: Exclusion:] | | | | | | | | | | | | | | | | post - 7.8 | | | | | | | | | | Unemployment 2.4 (1.2–4.6)
| | | | | | | | | | 1. Women with hysterectomy or bilateral oophorectomy | | | | | | | | | | | | | | | | Prevalence depresssion at follow-up | | | | | | | | | | Death of partner 2.4 (1.1–5.6)
| | | | | | | | | | 2. HRT without surgical menopause | | | | | | | | | | | | | | | | pre - 6.8 | | | | | | | | | | Financial problems 3.4 (1.5–7.8)
| | | | | | | | | | 3. Non-compliance with questionnaire | | | | | | | | | | | | | | | | per - 7.0
| | | | | | | | | | | | | | | | | | | | | | | | | | post - 7.8
McKinlay, 1987 | Massachu-sett's Women's Health Study | 2500 | Cross-sectional analyses from cohort | Internal | 27 months | Random sample of 8,050 women ages 45–55 in Massachusetts; 2,500 identified as premenopausal. 77% RR | Population based recruitment of premenopausal women | NR | _ | _ | CES-D given once during 1st 27 months; combined into single cross sectional data set "after determining that depression scores did not depend on the follow-up in which the CES-D scale was administered. | 77% | _ | CES-D | _ | _ | NR | NR | NR | _ | _ | _ | _ | _ | _ | Percentage of women with CES-D score≥16 (estimated from figure 1): | _ | Women reporting ≥ 2 physical symptoms are about 4 times as likely to be depressed as women reporting ≤ 1 symptom (15.7% vs. 4.3%). | _ | _ | _ | _ | _ | 1. sociodemographic variables: marital status, education, age, employment status, total number of persons in household | Logistic regression with CES-D ≥16 as outcome | Education and marital status were significantly associated with a CES-D score of ≥16; personal stress caused by others (person-induced worry); number of health problems; use of tranquilizer medications | Not given. RR presented for each of the significant variables in predictor model. | “menstrual change associated with the menopause appears to have no significant effect on depression … those with a recent surgical menopause were the most depressed group.”
| | | | | | | | | | | | | | | | | | | | | | | | | | pre: 7.5% (n=527) | | | | | | | | 2. health status: self-assesssed health, physical symptoms, restricted activity and chronic conditions.
| | | | | | | | | | | | | | | | | | | | | | | | | | peri: 10.5% (n=1632) | | | | | | | | 3. utilization behavior: formal and informal health resources, lay consultations, medication use
| | | | | | | | | | | | | | | | | | | | | | | | | | natural menopause: 8% (n=262) | | | | | | | | 4. sources of potential stress
| | | | | | | | | | | | | | | | | | | | | | | | | | surgical menopause 18% (n=78)
McKinlay, 1989 | Massachu-sett's Women's Health Study | 2,466 | Cross-sectional and prospective cohort | Internal | 4.5 years | Random sample | 8051 women in the Commonwealth of Massachusetts born 1926-1936. | NR | 45–55 in 1982 | A cohort of premenopausal women was chosen from the entire sample of women (8050) | Questionnaires | 77% to initial survey, 85% overall in follow-up | _ | CES-D | Change in menstrual status over 3 years of follow-up (T0-T3, n=2466): | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | CES-D score related cross-sectionally to menstrual status reveals women who have undergone surgical menopause in previous 3 months were twice as likely as the rest of the cohort to have CES-D scores ≥16 (19% v 10%). | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | “Change in menstrual status associated with the menopause appears to have no significant effect on depression, as defined by a CES-D score of 16 or greater.” (Minimal data available for this finding.)
| | | | | | | | | | | | | | | menses in 3 months prior to T3 42.9% | | | | | | | | | | | | | | | | | | | | | | | Some data reported in this study is the same as that reported in McKinlay, 1992
| | | | | | | | | | | | | | | menses changed to irregular 16.9%
| | | | | | | | | | | | | | | amenorrhea < 12 months 15.5%
| | | | | | | | | | | | | | | amenorrhea ≥ 12 months 20.4%
| | | | | | | | | | | | | | | Surgical menopause 4.4%
McKinlay, 1992 | Massachu-sett's Women's Health Study | 2,570 | Longitudinal and cross-sectional analysis of cohort data | Internal | 5 years | Random sample of 8,050 women ages 45–55 in Massachusetts, derived from census lists. Of these, 2,570 were identified as having menstruated in the past 3 months, having a uterus and > one ovary | 8050 women in the Commonwealth of Massachusetts born 1926-1936. | NR | 45–55 in 1982 | Premenopausal women selected from initial sample of 8,050 | Questionnaires or telephone interviews if questionnaires not received. | 77% of 8,050 responded. Had 94–99% retention of the 2,570 premenopausal cohort | _ | Symptoms checklist (any in past 2 weeks): hot flashes, cold sweats, vertigo, feeling blue or depressed, headaches, insomnia, palpitations, lack of energy, diarrhea and/or constipation, persistent cough, backaches, upset stomach, aches/stiffness in joints, shortness of breath, sore throat, loss of appetite, menstrual problems, fluid retention, difficulty in concentrating, nervous tension, urinary tract/bladder infections and “pins and needles” in hand or feet. | _ | Excluded | Excluded | NR | NR | 33.5% of premenopausal cohort (n=1178) were current smokers | 1% of premenopausal cohort (n=1178) were using HRT | NR | 13.4% of premenopausal cohort had HF (n=1178) at baseline. | NR | NR except in aggregate with all symptoms | NR | NR | NR | NR | NR | NR | NR | Lumped HF, sweats and insomnia into “menopausal symptoms,” and all other symptoms into non-menopausal symptoms: found that at Time 6, the following proportions of women report both types of symptoms: | _ | _ | _ | _
| | | | | | | | | | | | | | | | | | | | | | | For women 27 mo prior to perimenopause: 10% had HFs; Following the cessation of menses 50% have HF; 4yrs post-menopause 20% have HF. | | | | | | | | | | pre - 27%
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | peri - 46.3%
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | post - 37.7%
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | "Women who were perimenopausal for only one contact were consistently less likely to report hot flashes before, during and after the menopause than were women with a longer perimenopause.
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Women with short or no perimenopause: 39% had HF vs. remainder of women 51% of whom had HF.
Milsom, 1993 | Goteberg, Sweden | 7,459 | Cross-sectional | _ | _ | Random sampling of population register | Birth cohorts of 1900, 1905, 1910, 1915, 1920, 1930, 1940 from Sweden | _ | 46–86 | _ | Questionnaire regarding urinary incontinence | 74.60% | _ | _ | _ | Hysterectomy was associated with increased risk of incontinence in the whole cohort, but not within the individual age groups | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | Menopausal status was not associated with incontinence (postmenopausal versus premenopausal) | _ | _ | _ | _ | _ | _ | _ | _ | Prevalence data is by birth cohort, not by menopausal status.
Mishra, 2003 Australia | Australian Longitudinal Study on Women's Health | 8,623 | Cohort | Internal | 2 years | Mailed questionnaires | Random selection of Australian women aged 45–50 in 1996 who completed questionnaires in 1996 and 1998 | NR | Mean age at baseline 47.7 | Exclusions: | Survey 1996 and 1998, mail (long version, n=11,637) and phone (shorter for those who couldn't/didn't complete the mailed version, n=691) | 90.4% response rate for those who were alive at the time of the second survey. | 6.9% did not return the survey, 1.5% declined participation at follow-up, 1.1% withdrew from the study. | SF-36 scores | Defined on the basis of self-reported bleeding history. | Excluded | NR | NR | NR | Current smoking | NR | Similar body weights among groups. | NR | NR | NR | Adjusted mean score (s.e.) for “general mental health” from the SF-36 at baseline | NR | Adjusted mean score for bodily pain from the SF-36 at baseline | NR | NR | NR | Adjusted mean score (s.e.) or “general health perception” at baseline | _ | All mean scores calculated after adjusting after adjusting for age, physical activity level, weight, number of life events, smoking status, occupation, country of birth, marital status, and area of residence. | MV modeling only reported in terms of adjustments | NR | _
| | | | | | | | | | 1. Women salpingo hysterectomy or oophorectomy (n=3014) | | | | | Pre: bleeding in last 12 months and with same frequency as in the previous year (55.1% at BL). | | | | | pre: 12.5% | | Proportion overweight or obese: | | | | pre: 73.4 (0.5) | | pre: 72.5 (0.7) | | | | pre: 73.4 (0.6) | | All mean changes calculated after adjusting for SF-36 scores at baseline, physical activity levels at baseline and follow-up, weight at baseline, change in weight, change in number of life events, age smoking status, occupation, country of birth, marital status, and area of residence.
| | | | | | | | | | | | | | | Peri: bleeding in last 12 months but not in last 3 months (25.4% at BL) | | | | | peri: 17.9% | | pre: 42.4% | | | | peri: 70.7 (0.6)* | | peri: 68.2 (0.8)* | | | | peri: 68.2 (0.8)*
| | | | | | | | | | | | | | | Post: no bleeding in past 12 months (7.0% at BL) | | | | | post: 23.1% | | peri: 45.6% | | | | post: 71.0 (0.8)* | | post: 70.3 (1.1)* | | | | post: 70.3 (1.1)
| | | | | | | | | | | | | | | HRT: on HRT (12.1% at BL; 20.2 at 2 years) | | | | | HRT: 20.6% (p<0.0001) | | post: 43.6% | | | | HRT 68.1 (0.7)* | | HRT 65.0 (0.9)* | | | | HRT: 65. (0.9)*
| | | | | | | | | | | | | | | | | | | | | | HRT: 44.7% | | | | * ;<0.01 in mean adjusted for multiple comparisons when compared to pre-pre group. | | * ;<0.01 in mean adjusted for multiple comparisons when compared to pre-pre group. | | | | * ;<0.01 in mean adjusted for multiple comparisons when compared to pre-pre group.
| | | | | | | | | | | | | | | | | | | | | | | | | | Adjusted mean change score (s.e.) for “general mental health” from the SF-36 after 2 years. | | Adjusted mean change score (s.e.) for “bodily pain” from the SF-36 after 2 years | | | | Adjusted mean change score (s.e.) for “general health perception” from SF-36 after 2 years.
| | | | | | | | | | | | | | | | | | | | | | | | | | pre-pre: -0.7 | | pre-pre: 0.6 (0.7) | | | | Pre-pre: 0.6 (0.5)
| | | | | | | | | | | | | | | | | | | | | | | | | | pre-peri: -0.4 (0.7) | | pre-peri: -0.5 (0.8) | | | | pre-peri: -0.2 (0.6)
| | | | | | | | | | | | | | | | | | | | | | | | | | peri-peri: -1.2 (0.7) | | peri-peri: -1.8 (0.8)* | | | | peri-peri: -1.5 (0.6)*
| | | | | | | | | | | | | | | | | | | | | | | | | | pre/peri-post: -1.0 (0.8) | | pre/peri-post: -1.2 (1.0) | | | | pre/peri-post:-0.7 (0.7)
| | | | | | | | | | | | | | | | | | | | | | | | | | post-post: 0.0 (0.9) | | post-post: -0.6 (1.2) | | | | post-post:-0.8 (0.8)
| | | | | | | | | | | | | | | | | | | | | | | | | | HRT -2.1 (0.6)* | | HRT: -2.7 (0.8)* | | | | HRT:-1.8 (0.5)*
| | | | | | | | | | | | | | | | | | | | | | | | | | * ;<0.01 in mean change adjusted for multiple comparisons when compared to pre-pre group. | | * ;<0.01 in mean change adjusted for multiple comparisons when compared to pre-pre group. | | | | * ;<0.01 in mean change adjusted for multiple comparisons when compared to pre-pre group.
Mitchell, 1996 | Seattle | 508 entered study | Cohort | N/A | 3 years | Women in households within census tracts with mixed ethnicity and income contacted by phone | Census tracts in Seattle | W 79% | 35–55 | [underlined: Exclusion:] | Interview, cycle diary, health update | 11,222 phone contacts | NA | Washington Women's Health Diary | _ | Excluded | NR | NR | NR | NR | NR | NR | NR | NR | NR | At baseline dysphoric mood explained 23.8% of variance among symptom clusters - highly stable over 3 years. | NR | Somatic symptoms explain 6.5% of variance - highly stable over 3 years. | NR | NR | NR | NR | _ | Factor analysis | _ | NA | NA | All premenopausal or early perimenopausal.
| | 301 year 1 | | | | 11,222 - from which 820 eligible | | AA 8.3% | | 1. Amenorrhea > 1 year | | 820 eligible | | | | | | | | | | | | | | | | | | | | | | Important factors identified included dysphoric mood, vasomotor symptoms, insomnia, neuromuscular symptoms, somatic symptoms. | | | | Findings suggest that many symptoms described at baseline are stable over time and MP transition explains none over 3 years.
| | 215 year 2 | | | | | | Asian 8.6% | | 2. Pregnant | | 508 entered study | | | | | | | | | | | | | | | | | | | | | | Dysphoric mood very stable over 3 years (explained 77% of variance).
| | 200 year 3 | | | | | | Native Am 3.3% | | 3. TAH BSO | | | | | | | | | | | | | | | | | | | | | | | | Neuromuscular symptoms stable (explained 74% of variance).
| | | | | | | | | | 4. Could not read or speak English | | | | | | | | | | | | | | | | | | | | | | | | Vasomotor symptoms moderately stable over 3 years.
| | | | | | | | | | 5. Irregular menstrual cycles
| | | | | | | | | | 6. HRT use
Mitchell, 2001 | Seattle | 230 | Cross-sectional | Internal | Prevalence | Women in households within census tracts with mixed ethnicity and income contacted by phone | Census tracts in Seattle | 91% White | Mean 46.7 | [underlined: Exclusion:] | Interviews | 508 initially; this survey conducted among women still participating 96–97 | _ | Cycle analysis | NR | NR | NR | NR | 68% partnered | NR | NR | NR | NR | NR | NR | 142 women reported memory change compared with 88 without memory change. | _ | _ | NR | NR | NR | NR | _ | _ | _ | _ | This study really only evaluates women's attributions of causes for change in memory (self-reported). Stress, physical health, and aging most frequently cited as attributing to memory change. | Based on cycle analysis
| | | | | | | | 5% Asian American | | 1. Amenorrhea > 1 year | | N=230 | | | | | | | 24% divorced/separated | | | | | | | No association with age, education, income between the 2 groups. | | | | | | | | | | | | Premenopausal: early menopause transition stage (MTS) 53
| | | | | | | | 3% African American | | 2. Pregnant | | | | | | | | | 6% never partnered | | | | | | | | | | | | | | | | | | | Mid-menopausal: MTS 54
| | | | | | | | | | 3. TAH BSO | | | | | | | | | Mean education 16 years | | | | | | | | | | | | | | | | | | | Late menopausal: MTS 27
| | | | | | | | | | 4. Could not read or speak English | | | | | | | | | Mean income 42,000 | | | | | | | | | | | | | | | | | | | Postmenopausal: MTS 12
| | | | | | | | | | 5. Irregular menstrual cycles | | | | | | | | | | | | | | | | | | | | | | | | | | | | 96 on hormones or hysterectomy or were not classifiable
| | | | | | | | | | 6. HRT use
Randolph, 2003 | SWAN | 2930 | Cross-sectional | _ | _ | _ | _ | AA 27.6% | 46.3 | 253 of 3302 were excluded because of missing data | _ | 92.30% | | Height, weight, demographic and lifestyle data. | Premenopausal 54.3% | _ | _ | _ | _ | Smoking: | _ | Mean 28 kg/m2 | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | Unadjusted mean hormone levels by menopausal status: | Ethnicity, menopausal status, study site, day of cycle, BMI, age, smoking, and alcohol | Adjusted models for mean serum hormone concentrations | E2: | _ | Adjusted FSH levels were significantly higher in AA and H than W and Asian women.
| | | | | | | | Chinese 7.4% | | | | | | Menopausal status, FSH, DHEAS, SHBG and E2 from venipuncture on day 2–7 of a spontaneous menstrual cycle occurring within 60d of recruitment then annually. | early perimenopausal 45.7% | | | | | never 57.6% | | For all ethnic groups, SHBG, FSH, E2, and DHEAS levels declined with increasing BMI, and testosterone levels increased with increasing BMI. | | | | | | | | | | | E2 pg/ml (p NS): | | | No affect of menopausal status and ethnicity | | Adjusted FSH levels were significantly higher in early perimenopausal than premenopausal women.
| | | | | | | | H 8.8% | | | | | | | | | | | | past 25.4% | | For SHBG only did BMI and ethnicity interact. | | | | | | | | | | | pre 74 | | | FSH: | | Adjusted DHEAS levels were 73% higher in Chinese than AA.
| | | | | | | | J 9.0% | | | | | | | | | | | | current <10/d 5.0% | | BMI distribution varied across ethnicities. | | | | | | | | | | | early peri 77 | | | Ethnicity (p<0.05) | | Adjusted testosterone levels were slightly lower in in AA and H than W and Asian women.
| | | | | | | | W 47.1% | | | | | | | | | | | | current ≥10/d | | | | | | | | | | | | | FSH IU/L (p ≤0.0001): | | | Menopausal status (p≤0.0001)
| | | | | | | | | | | | | | | | | | | | 12.10% | | | | | | | | | | | | | pre 19.7 | | | T:
| | | | | | | | | | | | | | | | | | | | Higher mean FSH, testosterone, and SHBG levels for current compared to never smokers in unadjusted analyses (p≤0.0001) | | | | | | | | | | | | | early peri 29.8 | | | Ethnicity (p<0.05)
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Testosterone ng/ml (p NS): | | | No affect of menopausal status
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | pre 46 | | | DHEAS:
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | early peri 48 | | | Ethnicity (p≤0.0001)
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | DHEAS mcg/dl (p<0.05): | | | No affect of menopausal status
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | pre 135
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | early peri 128
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | SHBG nM (p NS):
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | pre 45
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | early peri 46
Rodstrom, 2002 Sweden | Gothenburg | 1462 | Cohort | Internal | 25+ years | Randomly selected from population | 1968-69 1462 women aged 38–60 | White | Initially 38–60 | None specified other than those with surgical menopause | Standardized interview | _ | _ | _ | | Excluded | NR | NR | NR | NR | NR | NR | Prevalence of hot flashes increased in linear manner from 11% at age 38, to maximal prevalence of 60% at ages 52–54, to 30% at age 60, 15% at age 66, 9% at age 72. | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | Only age, MP status, and cohort | Chi Square | _ | _ | _
| | | | | | | 1302 re-examined 1974–75 (89%) | | | | | | | | | | | | | | | | Hot flashes reported significantly less often among women aged 50 in 1980-81 cohort than the age 50 women in the 1968-69 cohort.
| | | | | | | 1154 re-examined 1980-81 plus 47 new women born in 1930 | | | | | | | | | | | | | | | | Cohort differences statistically significant.
| | | | | | | 4th exam 1992-93
Sherburn, 2001 Australia | Melbourne Women's | 1897, 373 | Cross-sectional, longitudinal | _ | 7 year follow-up | _ | _ | _ | _ | _ | _ | _ | _ | _ | Baseline % noted above. | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | _ | Urinary incontinence at baseline by menopausal status: | _ | _ | _ | _ | _ | Logistic regression model of factors associated with urinary incontinence | BMI | 1.5 | “Urinary incontinence in middle-aged women is more closely associated with mechanical factors than with menopausal transition.”
| | | | | | | | | | | | | | | At 7 year follow-up n=373: | | | | | | | | | | | | | | pre 10.4% | | | | | | | Other gynecologic surgery | 2.17
| | | | | | | | | | | | | | | stayed pre/peri 13.7% | | | | | | | | | | | | | | peri 17.3%* | | | | | | | participating in lawn bowls | 2.26
| | | | | | | | | | | | | | | became post 54.7% | | | | | | | | | | | | | | post 14% | | | | | | | urinary tract infection | 4.75
| | | | | | | | | | | | | | | HRT user 22.8% | | | | | | | | | | | | | | HRT 19%* | | | | | | | diarrhea or constipation | 1.95
| | | | | | | | | | | | | | | had surgical menopause 8.8% | | | | | | | | | | | | | | surgical 17.7%* | | | | | | | parity | 1.47
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | Total 15.3% | | | | | | | arthritis | 1.55
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | *p<0.005 compared to pre. | | | | | | | negative mood score (menopausal status was not significant in this model) | 1.64
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | Incidence rate (%) at 7 yr:
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | stayed pre/peri 34%
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | became post 37%
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | HRT user 27%
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | surgical menopause 54%
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | total 35%
| | | | | | | | | | | | | | | | | | | | | | _
Sowers, 2000 (methods paper for SWAN) | SWAN | 16,065 Cross-sectional | Cross-sectional and multisite longitudinal study | | Ongoing since 1995 | Census data, lists, random-digit dialing, “snow-balling” | Community based. | Each site enrolled non-Hispanic Caucasians and one site-specific minority African-American, Japanese, Chinese, or Hispanic. | 40–55 | Eligibility criteria for cross-sectional study: | Interview, written/oral survey, questionnaires, clinic measurements, specimen data, menstrual calendars, abstract medical records for hysterectomy. Materials available in all relevant languages. | 46.6% cross-sectional | | Too extensive to list | _ | None at enrollment | By definition ineligible for longitudinal study | NR | Ineligible | _ | _ | _ | _ | _ | _ | _ | NR | NR | NR | NR | _ | _ | _ | _ | _ | _ | _
| | 3306 longitudinal | | | | | Pittsburgh, Boston, Detroit, Chicago, Los Angeles, Oakland, Newark | | | 1) primary residence in designated geographic area, 2) ability to speak English or other designated language, 3) age 40–55 years at time of contact, 4) cognitive ability to provide verbal informed consent, 5) membership in a specific site's targeted ethnic groups | | 50.7% longitudinal
| | | | | | | | | | Eligibility criteria for longitudinal study:
| | | | | | | | | | 1) aged 42–52 years, 2) no surgical removal of the uterus and/or both ovaries, 3) not currently using exogenous hormone preparations affecting ovarian function, 4) at least one menstrual period in the previous 3 months, 5) self-identification with one of each site's designated race/ethnic group | | | | | | | | | | | | | | | | | | | _
Woods, 1997 | Seattle | 347 | Cohort | Internal | 2 years | 822 eligible | Seattle | 80% Whites | 35–45 (median 41) | Inclusion criteria: | _ | 508 of 820 of which 75% completed first year and 90% second year | _ | CES-D Scale | _ | Excluded | NR | NR | NR | NR | NR | NR | NR | NR | NR | Patterns (chronic, resolved, emerging) of depressed mood related to stressful life context, past/present health status, and social learning about midlife. | _ | _ | _ | _ | _ | _ | | _ | Factors prediction | Social learning about midlife | NA | Baseline: all premenopausal
| | | | | | 508 participated in interviews | Population-based sample chosen to over represent minorities | 8 African Americans | | 1) Non-lactating | | | | Menopausal Changes | | | | | | | | | | | | Menopausal status did not differentiate woen with depression from non-depressed. | | | | | | | | | | Stress life context | | At year 2 follow up: 22% perimenopausal, 31% hot flashes
| | | | | | 347 completed years 1 and 2 surveys | Sampling frame based on phone numbers | 8 Asian Americans | | 2) Non-pregnant | | | | Norbechs LES (Stressful Life Context) | | | | | | | | | | | | | | | | | | | | | | Past/present health status
| | | | | | | | | | 3) Menses within last year | | | | Feminine Socialization
| | | | | | | | | | 4) English reading | | | | Socialization for Midlife
| | | | | | | | | | 5) No hysterectomy | | | | Health Status
| | | | | | | | | | 6) Had at least 1 ovary | | | | Family Resources

Key/Abbreviations

AA = African American

BL = Baseline

BMI = Body mass index

BSO = Bilateral Salpingo Oopherectomy

CES-D = Center for Epidemiologic Studies Depression Scale

DHEAS = Dehydroepiandrosterones

E2 = Estradiol

GWB = Global well-being

H = Hispanic

HF = Hot flash

HRQL = Health related quality of life

HRT = Hormone replacement therapy

INH = Inhibin

ISRO = Index of Sex Role Orientation

J = Japanese

LES = Life event stress

MRC = Medical Research Council

MTS = Menopausal transition stage

MV = Multivariate

NA = Not applicable

NHANES = National Health and Nutrition Examination Survey

NHEFS = National Health Examination Follow-up Study

NR = Not reported

NS = Not significant

oc =Oral contraceptives

OR = Odds ratio

PEQ = Personal Experiences Questionnaire

peri = Perimenopausal

PHS = Perceived health status

PMS = Premenstrual syndrome

post = Postmenopausal

pre = Premenopausal

PSE = Present state examination

RR = Relative risk

sd = Standard deviation

SES = Socioeconomic status

SPEQ = Sexuality questionnaire of Personal Experiences Questionnaire

SWAN = Study of Women's Health Across the Nation

T = Testosterone

T0 = Time zero

T1 - Time one

T2 = Time two

T3 = Time three

TAH = Total abdominal hysterectomy

W = White

Evidence table 6-2. Key Question 3A Estrogens for depression

| | | | | | | | Specific Characteristics of Population | | | | | | | | Treatment | | Main Outcomes
Study/Year | N | Type of Trial | Comparison | Length of Trial | Population | Inclusion/Exclusion Criteria | Measures Used | Hyster-ectomy (#/n) | Bilateral Oophorec-tomy(#/n) | Premature Ovarian Failure(#/n) | Breast Cancer(#/n) | Use of SERMS(#/n) | Behavior or Lifestyle Factors(#/n) | Recent discontin-uation of HRT(#/n) | High or Low BMI(#/n) | Main Drug type; dose;regimen | Other Drugs type; dose; regimen | Hot Flashes | Vaginal Dryness | Sleep | Mood | Cognitive | Somatic | Urinary | Uterine Bleeding | Sexual Dysfunc-tion | Quality of Life | Other Outcomes | Withdrawals | Withdrawals due to AEs | Adverse Effects | Comments
Ditkoff, 1991 | 36 | RCT | P | 3 months | Asymptomatic American-born Latina women, aged 45–60, Salpingo hysterectomy, living in East LA. Recruitment info NR. | Inclusion: | 1. Minnesota Multiphasic Personality Inventory-168 | 36/36 | NR | NR | 0 | NR | NR | 0 | NR | CEE, 0.625mg or 1.25mg, PO qd for days 1–25 each month | Placebo | None in either group | NR | NR | 1. No change in Minnesota Multiphasic Personality Inventory; | No change | NR | NR | NR | NR | NR | NR | NR | 0 | None
| | | | | | 1. Age 45–60 | 2. Profile of Adaptation to Life | | | | | | | | | | | | | | 2. Significant decrease in Beck Depression Inventory for both doses of CEE pre-post; scores increased with placebo, but change not significant; no comparison between CEE and placebo given.
| | | | | | 2. Previous hysterectomy | 3. Beck Depression Inventory | | | | | | | | | | | | | | 3. Significant improvement in income management scale pre-post in both CEE groups; no change with placebo; no comparison between CEE and placebo.
| | | | | | 3. American born Latina | 4. Wechsler Adult Intelligence Scales of digit span and digit symbol
| | | | | | 4. Estradiol <20
| | | | | | 5. No subjective HF
| | | | | | 6. No HRT for 2 months
| | | | | | 7. No medical illnesses
| | | | | | 8. No hypnotics or mood altering drugs
Furuhjelm, 1984 | 48 | Cross-over | P | 42-month periods | Postmenopausal women with climacteric complaints attending outpatient clinic in Sweden | Inclusion: | 1. Sabbatsberg General Symptom Scale (for somatic and mental disturbances) | NR | NR | NR | NR | NR | NR | 0 | NR | Period A: 2mg estradiol-17B and 1mg estriol for 12 days, then 2mg estrodiol 17B, 1mg estriol, and 1mg noretristone acetate for 10 days, then 1mg estradiol-17B and 0.5mg estriol;Period B: 4mg estradiol-17B and 2mg estriol for 12 days, then 4mg estrodiol 17B, 2mg estriol, and 1mg noretristone acetate for 10 days, then 1mg estradiol-17B and 0.5mg estriol; Period C: 2mg estrodiol-17B and 1mg estriol for 28 days | Period D: placebo | All groups improved in pre-post comparison during hormone treatment; placebo did not change; no comparison to placebo given. All regimens grouped together. | NR | NR | All groups improved in pre-post comparison of mental distress during hormone treatment (p<0.01). Only depressed group had improvement in depression scores during hormone treatment (p<0.001); non-depressed groups and placebo did not change; no direct comparison to placebo given. All regimens grouped together. | NR | NR | NR | NR | NR | NR | NR | 10/58 | 3/58 | 3 with heavy bleeding | Odd analysis of crossover-style study; can't separate out first treatment.
| | | | | Group 1: N=28 with high depression/mental distress scores | 1. No clinical or laboratory signs of endocrine, biliary, GI or renal malfunction | 2. Sabbatsberg Distress Self-Rating Scale (for depression)
| | | | | Group 2: N=9 with mild depression/mental distress scores | 2. No HRT for at least 2 months | 3. Eysenck Personality Inventory
| | | | | Group 3: N=11 with no depression/mental distress | 3. Complaints of various climacteric disturbances | 4. Sabbatsberg Sexual Self-Rating Scale
| | | | | | 4. > 1-year post-menopausal | 5. Hormone levels, chemistry, physical exam, pap
Hall, 1998 | 60 | RCT | P & HH | 1 year | Postmenopausal women aged 44–75 with CAD in Sweden. Recruitment info NR | NR | Nottingham health profile and “others evaluated by Wiklund et. al.” | NR | NR | NR | NR | NR | NR | NR | “all were overweight”; mean BMI 25.9. | CEE 0.625mg, alone for 18 days, in combo with medroxyprogesterone 5mg for 10 days | Patch TTS E2 50 mcg alone for 18 days, in combo with medroxyprogesterone 5mg for 10 days | NR | NR | No change. | Significant improvement in depressed moods (p=0.054) in CEE group; no change in E2 or placebo; no comparison given between groups. Overall improvement in mood reported in all groups with no difference between groups. | Improved in all 3 groups; no difference between groups. | NR | NR | NR | NR | NR | NR | 14/60 | 7/60 | Heavy bleeding, edema, allergic skin reaction, palpitations, headache. (Numbers only given for those that withdrew, not total sample.)
Hlatky, 2002 | 2,763 | RCT | P | 36 months | Postmenopausal women with CAD in HERS study from 20 US clinical centers | Inclusion: | 1. Duke Activity Status; | 0 | NR | NR | NR | NR | NR | 0 | NR | CEE, 0.625mg and medroxyprogesterone acetate 2.5mg PO qd | Placebo | Reported elsewhere | Reported elsewhere | Reported elsewhere | RAND mental health inventory had small decline in all patients over time (p=0.05); no significant interaction between treatment group and time (p=0.10). | NR | NR | Reported elsewhere | Reported elsewhere | NR | More rapid decline over time in physical function scores in women on HRT (p=0.03). In women without flushing, HRT had greater decline in physical function (-4.2 vs. -3.3, p=0.04) and worsening of energy/fatigue (-4.6 vs. -3.1, p=0.03) compared to placebo. No significant difference in women with flushing. | Energy/fatigue scores declined overall (P<0.001); faster declines in energy/fatigue in women on HRT (p=0.05). | 1/2763 missing all data; 169/1383 on P and 180/1380 on HRT missing some data. | NR | Reported elsewhere | Secondary analysis of HERS trial
| | | | | | 1. < 80 | 2. RAND 4-item scale on energy/fatigue; | | | | | | | | | | | | | | Depressive symptoms decreased more over time among patients on HRT (p=0.005).
| | | | | | 2. Postmenopausal: | 3. RAND mental health inventory; | | | | | | | | | | | | | | In women with flushing at entry, HRT group had improved mental health (+2.6 vs. -0.5, p=0.04) and depressive symptoms (-0.5 vs. +0/007, p=0.01) compared to placebo. No significant change in women without flushing.
| | | | | | a) age ≥55 and no menses for 5 years | 4. 8-item depression scale developed for National Study of Medical Outcomes;
| | | | | | b) no menses for 1 year and FSH >40
| | | | | | c)documented bilateral oophorectomy
| | | | | | d)reported oophorectomy and FSH > 40 and E2 < 25
| | | | | | 3. CAD:
| | | | | | a) prior MI
| | | | | | b)angiography showing >50% narrowing of major vessel
| | | | | | c) prior coronary revascularization procedure
| | | | | | Exclusion:
| | | | | | 1. MI or revascularization procedure within 6 months
| | | | | | 2. Prior hysterectomy
| | | | | | 3.Contraindication to HRT
| | | | | | 4. HRT within 3 months
| | | | | | 5. Other life-threatening illnesses
| | | | | | 6. Unable to return for follow-up visits.
Strickler, 2000 | 398 (373 in analysis) | RCT | P and HH | 1 year | Asymptomatic postmenopausal women aged 47–60; 2–8 years after last menses; 32 study sites; recruitment info NR; | Inclusion: | Women's Health Questionnaire | NR | NR | NR | NR | NR | NR | 0 | 0 | CEE 0.625 | Raloxifene 60mg or 150mg qd or placebo | HRT improved vasomotor symptoms compared to Raloxifene (p<0.001) and placebo (p<0.001). | NR | No significant difference | No significant difference in depressed mood. Anxiety improved in Raloxifene 60mg (0.165) compared with placebo (0.028, p=0.03) and estrogen (-0.017, p=0.003). No difference with Raloxifene 150mg (0.076). | No difference in memory/ concentration | No difference in somatic symptoms | NR | Menstrual symptoms: estrogen (-0.169) worse than placebo (0.01, p=0.003). Comparisons with Raloxifene 60mg (-0.73) and 150mg (-0.063) not statistically significant. | No difference in sexual behavior | NR | NR | 25/398 | NR | NR | Asymptomatic postmenopausal population. Possible error due to multiple comparisons.
| | | | | | 1. Age 47–60
| | | | | | 2. 2–8 years with no menses
| | | | | | 3. E2 < 20
| | | | | | 4. BMD within 2.5 SD of premenopausal normal women.
| | | | | | Exclusion:
| | | | | | 1. Intolerable menstrual symptoms requiring treatment
| | | | | | 2. Uterine bleeding of unknown cause
| | | | | | 3. BMI < 18 or >31
| | | | | | 4. History of DVT
| | | | | | 5. Use of corticosteroids, estrogen or progestin < 6 months
| | | | | | 6. Chronic illness.
Thomson, 1977 | 42 | RCT | P | 8 weeks | 45–55 yo women referred by local general practitioners. | Inclusion: | Daily visual analogue scales for mood and anxiety and number of hot flashes. Hamilton anxiety and depression scales. | NR | NR | NR | NR | 0 | NR | NR | NR | Piperazin oestrone sulphate 1.5mg BID | Placebo | No significant difference | NR | Improved sleep (intervening wakefulness, frequency of awakenings, and stage of sleep) compared to placebo (p<0.05) | No difference between groups; both groups improved (p<0.001) | NR | NR | NR | NR | NR | NR | No difference in anxiety between groups; both groups improved (p<0.001). | 8 of 42 | NR | NR
| | | | | | 1. 45–55 years old
| | | | | | 2. Amenorrhea ≥ 3 months
| | | | | | 3. Symptoms of insomnia, depression, anxiety, and hot flashes
| | | | | | Exclusion:
| | | | | | 1. Other medications, contraindications to estrogen therapy
Vestergaard, 2002 | 1,006 | RCT (Open label) | No HRT | 5 years | 45–58 year old women; recruited by mailing to random sample. | Inclusion: | Modified Greene scale (visual analogue scale from 0–4 for severity of symptoms.) | 192/1006 | NR | NR | 0 | NR | NR | 0 | NR | First line: E2 2mg days 1–12; E2 mg and norethisterone 1mg days 13–22; E2 1mg days 23–28 for women with uterus. E2 2mg po qd for women without uterus. Women allowed to use other regimens if they requested change. | None | HRT reduced severity of HF compared to placebo (p<0.01). | HRT less vaginal dryness (p<0.01) | Less sleeping difficulties related to HF on HRT (p<0.01). No difference in sleeping difficulties unrelated to HF (p=0.17). | No significant difference in mood swings. | NR | No significant difference in headaches. | No significant difference in voiding frequency or incontinence. | NR | Trend toward less reduction in libido with HRT (p=0.08) | NR | Blood pressure decreased overall; no difference with HRT. | 54/502 on HRT; 55/504 not on HRT | NR; 40% changed HRT regimen or terminated HRT due to AEs | 39 headaches; 14 edema/fluid retention; 21 mood swings/ depression | Open label study; high rate of contamination; outcome measures single items, less well-validated. Part of Danish Osteoporosis Prevention Study.
| | | | | | 1. Women aged 45–58
| | | | | | a) 3–24 months past last period or
| | | | | | b) experiencing perimenopausal symptoms (irregular menses) with elevated FSH or
| | | | | | 2. Women aged 45–52 Salpingo hysterectomy with elevated FSH.
| | | | | | Exclusion:
| | | | | | 1. Metabolic bone disease / osteoporosis
| | | | | | 2. HRT within 3 months
| | | | | | 3. Current or past treatment with glucocorticoids > 6 months
| | | | | | 4. Malignancy
| | | | | | 5. Newly diagnosed or uncontrolled chronic disease
| | | | | | 6. Alcohol or drug addiction.
Voss, 2002 | 1,008 | RCT | HH | 6 month | Healthy postmenopausal women in 129 gynecological practices in Europe, South Africa and Israel. | Inclusion: | Women's Health Questionnaire | 0 | 0 | NR | 0 | 0 | NR | 0 | NR | Oestradiol 2mg and norethisterone acetate 1mg | Raloxifene 60mg qd | HRT: -0.21 | NR | HRT: -0.08 | Depressed mood: HRT +0.03, R:-0.02, p=0.004 favoring Raloxifene. | Memory/concentration: | HRT: -0.02; | NR | Menstrual symptoms: | HRT: -0.11 | NR | Greater treatment satisfaction (p=0.004) and compliance (p<0.01) with R than HRT | 54/495 on R; 116/513 on HRT | 24/495 on R; 65/513 on HRT | Vaginal bleeding (R 6.8%, HRT 55%, p<0.01)
| | | | | | 1. Healthy ambulatory women age ≥65 | | | | | | | | | | | | R: -0.03 | | R: -0.04 | Anxiety/fears: HRT 0.00; R: -0.01; p=0.6. | HRT: -0.04; | R: -0.01; | | HRT +0.10; | R:-0.02;
| | | | | | 2. Natural menopause ≥ 2 years earlier | | | | | | | | | | | | p<0.001 favoring HRT | | P=0.086 | | R: +0.02; | p=0.3. | | R: +0.02; | p=0.007 favoring HRT
| | | | | | 3. Elevated FSH in women age < 57 | | | | | | | | | | | | | | | | p=0.02 favoring HRT | | | p<0.001 favoring Raloxifene
| | | | | | Exclusion:
| | | | | | 1. Hysterectomy, ovariectomy, breast cancer, estrogen-dependant cancer
| | | | | | 2. Any other cancer within 5 years
| | | | | | 3. DVT, liver disease, thyroid disease
| | | | | | 4. Did not qualify for therapy according to prescribing information for E2 or NETA
| | | | | | 5. Endometrial pathology
| | | | | | 6. Severe postmenopausal symptoms requiring HRT
| | | | | | 7. Treatment with estrogens within 6 months
| | | | | | 8. Treatment with hypolipidemic drugs within 3 months
| | | | | | Note: intravaginal estrogens and oral estriol up to 2mg/day allowed before and during study.
Wheatley, 1977 | 58 | RCT | P | 4 weeks | Depressed women | NR | Global rating; Hamilton Depression Scale; Hopkins Symptom Checklist | NR | NR | NR | NR | NR | NR | NR | NR | Piperazin oestrone sulphate 1.5mg BID (with amitryptline) | Placebo (with amitryptiline) | NR | NR | NR | No difference between groups; both groups improved. | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR

Abbreviations

AE = Adverse Effect

CEE = Conjugated Equine Estrogens

E2 = Estrodial

HH = Head to head

HRT = Hormone Replacement Therapy

NETA=norethidrone acetate

NR = Not reported

P = Placebo

RCT = Randomized Controlled Trial

HF = Hot flash

GI = Gastrointestinal

SD = Standard deviation

MI = Myocardial infarction

CAD = Coronary artery disease

DVT = Deep vein thrombosis

R = Raloxifene

HERS = Heart and Estrogen/Progestin Replacement Study

RAND = RAND Mental Health Inventory

BMI = Body mass index

SERMs = Selective Estrogen Receptor Modifiers

BMD = Bone mineral density

Evidence table 6-3. Key Question 3C Testosterone

| | | | | | | | Specific Characteristics of Population | | | | | | | | | | Main Outcomes
Study/Year | | | | | | | Measures Used | Hysterectomy (#/n) | Bilateral Oophorectomy (#/n) | Premature Ovarian Failure (#/n) | Breast Cancer (#/n) | Use of SERMS (#/n) | Behavior or Lifestyle Factors (#/n) | Recent discontinuation of HRT (#/n) | High or Low BMI (#/n) | Main Drug type; dose; Regimen | Other Drugs type; dose; regimen | Hot Flashes | Vaginal Dryness | Sleep | Mood | Cognitive | Somatic | Urinary | Uterine Bleeding | Sexual Dysfunction | Quality of Life | Other Outcomes | Withdrawals | Withdrawals due to AEs | Adverse Effects | Comments
Barrett-Connor, 1999 | 311 in 4 groups | DB RCT | HH | 2 years | Surgically menopausal White women. Mean age approx 45 (21–65) | Inclusion: | Modified Kupperman Scale | 311 | 311 | NR | 0 | NR | NR | No HRT in prior 6 weeks | Approximately 25 | CEE 0.625 mg/day oral (CEE-L); CEE 1.25 mg/day oral (CEE); | E2 0.625 mg + MT 1.25 mg/day oral (E+ A-L); E2 1.25 mg + MT 2.5 mg/day oral (E + A) | Improved in all treatment groups (p value not reported) | Improved in all treatment groups (p value not reported) | NR | NR | NR | No significant difference between treatment groups. | NR | NR | Non-significant trend toward greater improvement in well-being and sexual interest in the E + A groups (data on Kupperman scale.) | NR | Significantly increased BMD in the E+A group at lumbar spine and hip in comparison to the CEE group at 24 months. No statistically significant differences in hirsutism scores between treatment groups (Ferriman-Gallwey scale) | 112 (non drug related-24, protocol violation-21, loss to follow-up-22) | 45 | Nausea (6% E+A-L; 3% E+A; 11% CEE-L and 22% CEE) Acne/hirsutism/chloasma (3 in E+A-L; 4 in E+A;1 CEE) | Participants in study not selected based on presence/severity of menopausal symptoms.
| | | | | | 1. White women
| | | | | | 2. 21–65 years old
| | | | | | 3. Surgically menopausal: Undergone bilateral oophorectomy and hysterectomy > 3 months before but < 5 years prior to screening
| | | | | | 4. Within 75–125% of ideal body weight
| | | | | | 5. In stable relationship for > 6 months
| | | | | | Exclusion:
| | | | | | 1. Receiving estrogens or HRT in previous 6 weeks
| | | | | | 2. Receiving psychotropic drugs in the previous 4 weeks
| | | | | | 3. History of pelvic or breast malignancy
| | | | | | 4. Dependence on alcohol, tobacco, or illicit drugs
Braunstein, 2003 (abstract only) | 447 | DB RCT | P | 24 weeks | Surgically menopausal women with hypoactive sexual desire | Inclusion: | SAL | 447/447 | NR | NR | NR | NR | NR | 0 | NR | Testosterone 150, 130, or 450 mcg/day Transdermal patch twice per week | Oral estrogen | NR | NR | NR | NR | NR | NR | NR | NR | In the 300 mcg/d group, a 30% increase in satisfying sexual activity observed in T vs. P (p<0.05) and 81% increase from baseline (p<0.05) on SAL. Sexual desire score also increased (p<0.05) on PFSF. | NR | Increased mean concentrations of free and bioavailable T. | NR | NR | NR
| | | | | | 1. Surgically menopausal women | PFSF
| | | | | | 2. Had Hypoactive Sexual Desire Disorder
Davis, 2003 (abstract only) | 77 | DB RCT | P | 24 weeks | Surgically menopausal women with hypoactive sexual desire | Inclusion: | SAL | 77/77 | 77/77 | NR | NR | NR | NR | 0 | NR | Testosterone 300 mcg/day Transdermal twice per week | Transdermal estrogen | NR | NR | NR | NR | NR | Statistically significant positive effect on the composite score of PGWB in T group, p<0.05 | NR | NR | Increase in sexual desire score on PFSF in T group compared to P, p<0.05 | NR | Increased mean concentrations of free and bioavailable T. | NR | NR | NR
| | | | | | 1. Surgically menopausal women | PFSF
| | | | | | 2. Had Hypoactive Sexual Desire Disorder | PGWB
| | | | | | | PDS
Dobs, 2002 | 40 | DB RCT | HH | 16 weeks | Menopausal women | Inclusion: | BISF - W | NR | 21/40 | NR | NR | NR | NR | 0 | NR | E2 1.25 mg/day + MT 2.5 mg/day oral or | E2 1.25 mg/day oral | Improved in E2/MT at week 4 (p=0.024) and week 10 (p=0.003) | NR | Improved in E2/MT at week 4 (p=0.024) and week 10 (p=0.003) | No significant change | No significant change | Improved in E2/MT group at week 4 (p=0.004) and week 10 (p=0.021) | NR | NR | Frequency/psycho-sexual (p=0.05) and pleasure/orgasm (p=0.041) scores of BISF-W increased. | See QUALMS data | Sex hormone levels | 3 | 3 | Bloating/weight gain (E2/MT) | Sexual function and quality of life secondary outcome.
| | | | | Mean age 56.9 (41.4–76.3) | 1. Surgically or naturally menopausal women | SRS | | | | | | | | | | | QUALMS Scale | | QUALMS Scale | | | QUALMS Scale | | | Total SRS score improved in E2/MT (p value not reported) | | | | (E2/MT - 2 E2 - 1) | Migraine (E2/MT) | Healthier baseline sexual function reported in E2 group compared to E2/MT (specific data not reported)
| | | | | | 2. Required to have been on HRT for > 3 months before screening to remove confounding hypoestrogenic symptoms | SIQ | | | | | | | | | | | | | | | | | | | Improved SIQ score in E2/MT at week 10 (p=0.031) and week 16 (p=0.014). | | | | | Hirsutism (E2/MT)
| | | | | | Exclusion: | QUALMS | | | | | | | | | | | | | | | | | | | | | | | | Insomnia, breast swelling, headache (E2)
| | | | | | 1. Uncontrolled hypertension or hyperlipidemia
| | | | | | 2. Medication known to affect lipids
| | | | | | 3. Poorly controlled diabetes mellitus
| | | | | | 4. Unstable angina or congestive heart failure
| | | | | | 5. Myocardial infarction < 3 months of study
| | | | | | 6. Preexisting liver disease
| | | | | | 7. Renal impairment
| | | | | | 8. Hepatic adenoma
| | | | | | 9. History of breast or uterine cancer
| | | | | | 10. Gall bladder disease
| | | | | | 11. History of thromboembolic events
Floter, 2002 | 50 in 2 groups | RCT Cross-over | HH | 24 weeks | Surgically menopausal women | Inclusion: | McCoy's Sex | 50/50 | 50/50 | NR | 0/50 | NR | NR | NR | Mean 25.7 | Estradiol valerate 2 mg/day | Estradiol valerate 2 mg/day + testosterone undecanoate 40 mg/day | NR | NR | NR | Both treatment groups with significant improvement, p< 0.001 | NR | NR | NR | NR | Both treatment groups with significant improvement (p< 0.01) on McCoy Sex Scale. | Both treatment groups with significant improvement on PGWB Index, p< 0.05 | Sex hormone levels | 6 | 1 | Migraine
| | | | | Mean age 54 (45–60) | 1. 45–60 years old | Scale PGWB-I | | | | | | | | | | | | | | PGWB Index | | | | | | | | | | Acne
| | | | | | 2. History of hysterectomy and bilateral salpingo ophorectomy for benign disorders | | | | | | | | | | | | | | | | | | | | | | | | | Hirsutism
| | | | | | 3. Body mass index between 18 and 29 kg/m2 | | | | | | | | | | | | | | | | | | | | | | | | | Body swelling
| | | | | | 4. Blood pressure > 170 mmHg systolic and/or 105 mmHg diastolic
| | | | | | 5. Normal mammogram within past year
| | | | | | Exclusion:
| | | | | | 1. Previous use of HRT within past 2 months
| | | | | | 2. Other medication within past 2 months (other sex hormones, anabolic steroids, corticosteroids, danazol, calcium antagonists, beta-blocking agents, barbiturates, carbamazepines, griseofulvins, hydantion, rifampicin, herbal/homeopathic therapy)
| | | | | | 3. History of or present premalignancies/malignancies
| | | | | | 4. Liver disease
| | | | | | 5. Cardiovascular, cerebrovascular, or thromboembolic disorders
| | | | | | 6. Present psychiatric disease
| | | | | | 7. Regular use of tranquillizers and/or antihistamines, alcohol abuse, or smoking of > 10 cigarettes/day was allowed
Hickok, 1993 | 26 in 2 groups | DB RCT | HH | 6 months | Postmenopausal White women 40–60 years | Inclusion: | 4 point menopausal symptom scale (0–3) | NR | NR | NR | NR | NR | Non-smokers | NR | NR | E2 0.625 mg + MT 1.25 mg/day oral | E2 0.625 mg/day oral | Decrease in symptom severity in both groups, p<.01. No significant difference between groups. | Decrease in symptom severity in both groups, p<.01. No significant difference between groups. | Decrease in symptom severity in both groups, p<.01. No significant difference between groups. | NR | NR | NR | NR | NR | NR | NR | Decreased symptom severity in other symptoms measured. | 0 | 0 | Acne (E2 + MT - 5) | Menopausal symptoms measured on 4 point scale (0=absent to 3=severe): hot flushes, cold sweats, vaginal dryness, cold hands and feet, breast pain or tenderness, numbness and tingling, skin crawls, edema, increased facial or body hair, voice deepening, acne, trouble sleeping, heart pounding, dizzy spells, pressure or tightness in head or body.
| | | | | Mean age: | 1. Women from Department of Obstetrics and Gynecology at Oregon Health and Science University | | | | | | | | | | | | | | | | | | | | | | No significant differences between the 2 groups. | | | Facial hair (E2 + MT - 2; E2 - 1)
| | | | | E2=50 | 2. Caucasian
| | | | | E2 + MT= 52 | 3. 40–60 years old
| | | | | | Exclusion:
| | | | | | 1. Menstrual bleeding in the last 12 months
| | | | | | 2. History of steroid ingestion in 4 weeks prior to study
| | | | | | 3. Receiving adrenergic agonists or antagonists, peripheral vasodilators, cholesterol-lowering agents, beta-blockers, beta-mimetics, or thyroid hormones
| | | | | | 4. Smoking within the past 12 months
| | | | | | 5. History of genital tract disease
| | | | | | 6. Current or previous estrogen-dependent malignancy
| | | | | | 7. History of jaundice or elevated liver enzymes, gallbladder disease, or cardiovascular disease
| | | | | | 8. Current hypertriglyceridemia or severe hypertension
Lobo, 2003 | 218 in 2 groups | DB RCT | HH | 4 months | Postmenopausal women with hypoactive sexual desire. Mean age approx 53 (40–65) | Inclusion: | SIQ | NR | Approximately 68/218 (30.8 % EE/MT and 31.5% EE) | NR | NR | NR | NR | None | E2 26.7 ± 5.4 and E2/MT 25.5 ± 4.6 | E2 0.625 mg/day oral and E2 0.625 mg/day + MT 1.25 mg/day oral | NR | NR | NR | NR | NR | NR | NR | NR | NR | SIQ scores for mean sexual interest/desire and responsiveness significantly increased, p=.047 and p=.002, respectively. | NR | Mean bioavailable T levels increased in E2/MT group, p< .010, decreased in HDL in EE/MT, p<.010. | E2 16/111 E2/MT 20/107 | E2: 5 | Headache (E2/MT 9.3% vs. E2 7.2%)
| | | | | | 1. Healthy postmenopausal women (natural or surgical > 6 months) | BISF-W | | | | | | | | | | | | | | | | | | | | | | | E2/MT: 9 | Infection (E2/MT 9.3% vs. E2 6.3%)
| | | | | | 2. 40–65 years old | | | | | | | | | | | | | | | | | | | | | | | | | Acne (E2/MT 5.6% vs. E2 2.7%)
| | | | | | 3. Receiving estrogen (0.625 mg of conjugated equine estrogens for > 3 months or equivalent of 0.9 mg if dose decreased for last cycle before study) | | | | | | | | | | | | | | | | | | | | | | | | | Hot flushes (E2/MT and E2 7%)
| | | | | | 4. Experienced hypoactive sexual desire associated with onset of menopause (not overt mood disorders) scoring higher than 3.0 on Thoughts/Desire Dimension of the BISF-W | | | | | | | | | | | | | | | | | | | | | | | | | Breast pain (E2/MT 3.7% vs. E2 7%)
| | | | | | 5. History of adequate sexual interest before onset of menopause | | | | | | | | | | | | | | | | | | | | | | | | | Acne (E2/MT 5.6% vs. E2 3%)
| | | | | | Exclusion: | | | | | | | | | | | | | | | | | | | | | | | | | Rhinitis (E2/MT 4% vs. E2 6%)
| | | | | | 1. Dyspareunia
| | | | | | 2. Unresolved or recent sexual abuse
| | | | | | 3. Depressive or anxiety symptoms
| | | | | | 4. Physical limitations that interfered with normal sexual functioning
| | | | | | 5. Abnormal mammogram
| | | | | | 6. Relevant clinical laboratory test abnormalities
| | | | | | 7. Recent previous high-dose HRT or other sex hormones
| | | | | | 8. Lipid-lowering agents
| | | | | | 9. Antidepressants (including SSRI's)
| | | | | | 10. Anxiolytics
| | | | | | 11. Thyroid replacement medication (unless a stable dose)
| | | | | | 12. Antihypertensive drugs
Penotti, 2001 | 40 in 2 groups | Open RCT | HH | 8 months | Postmenopausal women. Mean age: | Inclusion: | VAS | 0 | 0 | NR | NR | NR | NR | None | HRT + T =24.1 and HRT =24.9 | HRT + Testosterone undecanoate 40 mg/day oral | HRT: E2 50 mcg/day Transdermal + MPA 10 mg/day for 12day/month | NR | NR | NR | NR | NR | NR | NR | NR | No difference observed between the 2 groups of VAS scores at any of the time points (baseline, 4 months, 8 months) | NR | NR | HRT 2/20 and HRT + T 5/20 | HRT + T: 3 | Hyperandrogenism | VAS (visual analogue scale ) used to evaluate changes in psychological well-being and sexual desire and satisfaction
| | | | | HRT + T 57.4 | 1. Attending the Menopause Clinic of the Second Department of Obstetrics and Gynecology, University of Milan | | | | | | | | | | | | | | | | | | | | | | | | | Nausea, nervousness, and Aggressiveness in 2 patients
| | | | | HRT 55.3 | 2. Receiving HRT > 1 year
| | | | | | 3. Receiving Transdermal E2 (50 ug/d) for between 1–5 years and cyclic medroxyprogesterone acetate (10 mg/d) for 12 days every 2 months
| | | | | | Exclusion:
| | | | | | 1. Suffering from any major disease including hypertension, heart disease, diabetes, renal or peripheral vascular diseases
| | | | | | 2. Undergone surgical removal of the uterus or ovaries
Raisz, 1996 | 18 in 2 groups | Open RCT | HH | 9 weeks | Postmenopausal women. Mean age: | Inclusion: | Modified Kupperman with 0–3 scale | 0 | CEE 3/15 | NR | 0 | NR | Non-smokers only | No estrogen for 6 months prior | CEE =25.1 and E2/MT =26.5 | CEE 1.25 mg/day oral or | Oyster shell calcium tablet (Oscal) 500 mg 1 or 2 tablets/day oral | Decreased in both groups, p<.05 | Decreased in both groups, p<.05 | Improved in E + A group, p<.05 | Improved in E2/MT group, p<.05 | NR | Significant relief in E2/MT group, p<.05 | NR | CEE 5 | NR | NR | Markers of bone formation and resorption, lipids, and SHBG | NR | NR | Headache (6 CEE; 2 E2/MT) | [underlined: Results reported by 3 groupings:]
| | | | | CEE 65.7 | 1. Postmenopausal women (last spontaneous menstrual cycle occurred > 5 years) | | | | | | | | | | E2 1.25 mg + MT 2.5 mg/day oral | | | | | | | | | E2/MT 4 | | | | | | Breast pain (6 CEE; 3 E2/MT) | Somatic symptoms: hot flashes, sweating episodes, vaginal dryness
| | | | | E2/MT 59.8 | 2. Within 25% of ideal body weight | | | | | | | | | | | | | | | | | | | | | | | | | Acne (1 CEE; E2/MT) | Psychosomatic symptoms: fatigability, insomnia, palpitations
| | | | | | 3. Non-smoker | | | | | | | | | | | | | | | | | | | | | | | | | Bleeding (CEE 5; E2/MT 4) | Psychological symptoms: irritability, nervousness, depression, anxiety, decreased concentration.
| | | | | | 4. Negative mammogram and Pap smear within 1 year and normal electrocardiograms
| | | | | | Exclusion:
| | | | | | 1. Receiving estrogens within last 6 months
| | | | | | 2. Prior history of estrogen-dependent cancer, hypercortisolism, hyperthyroidism, or metabolic bone disease
| | | | | | 3. Any prior treatment with drugs that might affect bone metabolism, other than calcium supplements and estrogens, or with drugs known to alter hepatic enzymes (including excess vitamin A and D, steroid hormones, cholesterol-lowering agents, heparin, anticonvulsants, high dose nonsteroidal anti-inflammatory drugs, and high dose thyroid hormone replacement
Shifren, 2000 | 75 | DB RCT | P | 36 weeks | Surgically menopausal women with impaired sexual function. Mean age 47 (31–56) | Inclusion: | BISF-W | 75/75 | 75/75 | NR | NR | NR | NR | 0 | 25.8 (19.5–33.5) | Testosterone 150 + 300 mcg/day Transdermal | Oral CEE 0.625 mg/day - 41 | No change from baseline | NR | NR | Significant increase in depressed - mood measure of PGWBI in testosterone 300 mcg/d group only, p=0.03 | NR | NR | NR | NR | Composite score of BISF increased for all treatment groups, p=0.05 | Mean composite score of PGWBI increased for all treatment groups, p=0.04 | No significant effects on total cholesterol, HDL, LDL, triglycerides, fasting glucose or insulin, blood counts, or LFT's. | 18 | 4 | Anxiety - 2 | Participants on variable doses of estrogen.
| | | | | | 1. Women 31–56 years old at nine clinics in the United States | PGWB | | | | | | | | | | CEE 0.9 mg/day - 12 | | | | | | | | | | | | | | Nipple discharge - 1
| | | | | | 2. Undergone bilaterial salpingo-oophorectomy and hysterectomy before natural menopause between 1–10 years earlier | | | | | | | | | | | CEE 1.25 mg/day - 20 | | | | | | | | | | | | | | Skin reaction - 1
| | | | | | 3. Had serum testosterone concentrations < 30 ng/deciliter or serum free testosterone concentrations < 3.5 pg/milliliter | | | | | | | | | | | CEE 1.8 mg/day - 1
| | | | | | 4. Received CEE of > 0.625/day orally for > 2 months | | | | | | | | | | | CEE 2.5 mg/day - 1
| | | | | | 5. Been in stable, monogamous, heterosexual relationship for > 1 year
| | | | | | 6. Had BMI between 19.5 – 33.5
| | | | | | 7. Impaired sexual function determined by questionnaire (score < 33.6 on Brief Index of Sexual Functioning for Women)
| | | | | | Exclusion:
| | | | | | 1. Received oral, topical, or vaginal androgen therapy in previous 3 months, or injectaable or implantable androgen therapy in previous 6 months
| | | | | | 2. Had > 20 moderate or severe hot flashes per week
| | | | | | 3. Had severe acne (grade 3 on Palatsi et al scale)
| | | | | | 4. Mild or severe hirsutism (score of > 6 on Loprinzi scale)
| | | | | | 5. Hyperlipidemia
| | | | | | 6. Psychiatric illness
| | | | | | 7. Dyspareunia
| | | | | | 8. Physical limitations that interfered with normal sexual functioning
| | | | | | 9. Receiving glucocorticoids, selective serotonin-reuptake inhibitors, tricyclic antidepressants, antiandrogen agents, ginseng, yohimbine, phytoestrogens, dehydroepiandrosterone, or melatonin
Simon, 1999 | 93 in 5 groups | RCT | P | 3 months | Naturally menopausal women with mild to moderate vasomotor symptoms. | Inclusion: | Kupperman | 0 | 0 | NR | 0 | 0 | 100% non-smokers | NR | Mean 27.1 | E2 0.625 + MT 1.25 mg/day | E2 0.625 mg/day | All active treatment groups shared significant improvement (p ≤ 0.05) | All active treatment groups shared significant improvement (p ≤ 0.05) | No treatment effect | No treatment effect | NR | All active treatment groups shared significant improvement (p ≤ 0.05) | NR | | NR | NR | Sex hormone levels | 3 | 1 - high dose estratest | Rash | Only somatic symptoms reported
| | | | | Mean age 53.7 | 1. Naturally menopausal women with both ovaries intact | | | | | | | | | | E2 1.25 + MT 2.5 mg/day | E2 1.25 mg/day
| | | | | | 2. Recruited from Georgetown University (Washington, DC), The Worcester Foundation for Experimental Biology (Worcester, MA), The Middleton Foundation (Olympia, WA)
| | | | | | 3. Experienced amenorrhea > 6 months duration (range 6 months - 14 years) prior to study
| | | | | | 4. Had follicle-stimulating hormone levels > 55 mIU/mL, normal clinical laboratory test results (biochemistry, hematology, thyroid function, and lipid profile), normal Pap smear, EKG, and mammogram prior to entering study
| | | | | | 5. Experienced mild to moderate vasomotor symptoms
| | | | | | 6. Non-smoker
| | | | | | 7. Within + 25% of ideal body weight (based on Metropolitan Life Insurance tables)
| | | | | | 8. In heterosexual relationships of > 1 year duration
| | | | | | Exclusion:
| | | | | | 1. Receiving estrogens, progestins, androgens, or anabolic steroids within 8 weeks of study enrollment
| | | | | | 2. Active breast, uterine, or ovarian cancer or history thereof
| | | | | | 3. Recent history of vaginal bleeding
Watts, 1995 | 66 in 2 groups | DB RCT | HH | 2 years | Surgically menopausal women | Inclusion: | Modified Kupperman with 0–7 scale | 66/66 | 66/66 | NR | 0 | NR | NR | NR | E2-24.9 | E2 1.25 mg/day oral | E2 1.25 mg/day + MT 2.5 m/day oral | No difference between treatment groups at baseline or after treatment | No difference between treatment groups at baseline or after treatment | No difference between treatment groups at baseline or after treatment | NR due to small numbers of symptomatic patients | NR | NR due to small numbers of symptomatic patients | NR | NR | NR | NR | Lipids and Spinal bone mineral density | E2 3 | E2 3 | Headache (E2 16; E2/MT 9) | Modified Kupperman scale used to assess menopause symptoms.
| | | | | | 1. 21–60 years old | | | | | | | | | E2/MT-25.8 | | | | | | | | | | | | | | E2/MT 7 | E2+MT 5 | Hot flashes (E2 7; E2/MT 3)
| | | | | | 2. Surgically menopausal: Undergone bilateral oophorectomy and hysterectomy at least 4 weeks before study entry | | | | | | | | | | | | | | | | | | | | | | | | | Rdema (E2 10; E2/MT 10)
| | | | | | Exclusion: | | | | | | | | | | | | | | | | | | | | | | | | | Breast pain (E2 9; E2/MT 13)
| | | | | | 1. Had concomitant illness | | | | | | | | | | | | | | | | | | | | | | | | | Hair disorder (E2 1; E2/MT 12)
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Acne (E2 2; E2/MT 10)

Key/Abbreviations

A = Androgen

BISF-W = Brief Index of Sexual Function for Women

BMD = Bone mineral density

BMI = Body mass index

CEE= Conjugated equine estrogens

DB = Double blind

E = Estrogen

E2 = Estradiol

EE = Esterified Estrogen

HH = Head to head

HRT = Hormone replacement therapy

MT = Methyltestosterone

NR = Not reported

P = Placebo

PDS = Personal Distress Scale

PFSF = Profile of Female Sexual Function

PGWB = Psychological General Well-Being

PGWB-I = Psychological General Well-Being Index

QUALMS = Quality of Life Menopause Scale

RCT = Randomized controlled trial

SAL = Sexual Activity Log

SERMs = Selective Estrogen Receptor Modifiers

SIQ = Sexual Interest Questionnaire

SRS = Sabbatsberg Revised Sexual Rating Scale

SSRI = Selective Serotonin Reuptake Inhibitor

T = Testosterone

VAS = Visual Analogue Scale

Evidence table 6-4. Key Question 3C DHEA

| | | | | | | | Specific Characteristics of Population | | | | | | | | Treatment | | Outcomes
Study/Year | N | Study design | Compari-son | Length of Trial | Population | Inclusion/Exclusion Criteria | Measures Used | Hyster-ectomy (#/n) | Bilateral Oophorec-tomy (#/n) | Premature Ovarian Failure (#/n) | Breast Cancer (#/n) | Use of SERMS (#/n) | Behavior or Lifestyle Factors (#/n) | Recent discontin-uation of HRT (#/n) | High or Low BMI (#/n) | Main Drug type; dose; regimen | Other Drugs type; dose; regimen | Hot Flashes | Vaginal Dryness | Sleep | Mood | Cognitive | Somatic | Urinary | Uterine Bleeding | Sexual Dysfunc-tion | Quality of Life | Other Outcomes | Withdrawals | Withdrawals due to AEs | Adverse Effects | Comments
Barnhart, 1999 | 60 in 2 groups | DB | P | 3 months | Perimenopausal women with altered mood and well-being. Mean age 48 (45–55) | Inclusion: | DSR (0–4 scale), Profile of Mood Scale, Ham-D, SmithKline Beecham Quality of Life Self-Report Questionnaire, Buschke Immediate Recall and Delayed Recall, Symbol Copying and Digit Symbol Substitution Tests | NR | NR | NR | NR | NR | NR | NR | NR | DHEA 50 mg/day oral | Placebo | No significant difference between study groups | No significant difference between study groups | No significant difference between study groups | No significant difference between study groups | No significant difference between study groups | No significant difference between study groups | No significant difference between study groups | NR | No significant difference between study groups | No significant difference between study groups | Sex hormones and lipids | 6 | 3 | Rash (placebo) | Subjects from both study groups had decreased total perimenopausal symptoms and improvements in components of health-related quality of life, p<0.01.
| | RCT | | | | 1. Perimenopausal women | | | | | | | | | | | | | | | | | | | | | | | | | Abdominal pain/fatigue (placebo)
| | | | | | 2. 45–55 years old | | | | | | | | | | | | | | | | | | | | | | | | | Paresthesia (DHEA)
| | | | | | 3. Symptoms include fatigue, lack of energy, anxiety, tension, irritability, depression, insomnia, forgetfulness, concentration difficulties, decreased libido, or global reports of a decreased sense of well-being
| | | | | | Exclusion:
| | | | | | 1. Any contraindication to HRT
| | | | | | 2. Exposure to injectable or implantable sex steroid within 6 months or systemic steroid within 90 days of treatment
| | | | | | 3. Used antidepressants and/or antianxiolitics
| | | | | | 4. Current diagnosis of major psychiatric disorder, diabetes mellitus, hypercholesterolemia, or cardiovascular disease
| | | | | | 5. Abnormal renal or liver function
Stomati, 1999 | 22 in 3 groups | RCT | HH | 3 months | Postmenopausal women (50–55 years) | Inclusion: | Kupperman (0–3 scale, where 0=none and 3=marked) | NR | NR | NR | NR | NR | NR | NR | NR | DHEAs 50 mg/day oral | DHEAs 50 mg/day + Estradiol 50 mg/day trans or Estradiol 50 mg/day | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | 0 | 0 | NR | Similar significant progressive improvement in Kupperman score with all treatment groups (p<0.01). Specific components of Kupperman score not reported individually.
| | | | | | 1. Postmenopausal women
| | | | | | 2. 50–55 years old
| | | | | | 3. Climacteric complaints
| | | | | | 4. Normal body mass index
| | | | | | 5. Basal plasma DHEA levels < 5 ug/ml
| | | | | | Exclusion:
| | | | | | 1. Previous or current estrogen-dependent neoplasia, thromboembolic disease, liver, pancreatic or renal disease, and diabetes mellitus

Key/Abbreviations

BMI = Body mass index

DB = Double blind

DHEA = Dehydroepiandrosterone

DSR = Daily Symptom Rating Calendar

HAM-D = Hamilton Depression Rating Scale

HH = Head to head

HRT = Hormone replacement therapy

NR = Not reported

P = Placebo

RCT = Randomized controlled trial

SERMs = Selective Estrogen Receptor Modifiers

Evidence table 6-5. Key Question 3D Tibolone

| | | | | | | | Specific Characteristics of Population | | | | | | | | | | Main Outcomes
Study/Year | N | Study design | Comparison | Length of Trial | Population | Inclusion/Exclusion Criteria | Measures Used | Hysterectomy (#/n) | Bilateral Oophorectomy (#/n) | Pre-mature Ovarian Failure (#/n) | Breast Cancer (#/n) | Use of SERMS (#/n) | Behavior or Lifestyle Factors (#/n) | Recent discontinuation of HRT (#/n) | High or Low BMI (#/n) | Main Drug type; dose; regimen | Other Drugs type; dose; regimen | Hot Flashes | Vaginal Dryness | Sleep | Mood | Cognitive | Somatic | Urinary | Uterine Bleeding | Sexual Dysfunction | Quality of Life | Other Outcomes | Withdrawals | Withdrawals due to AEs | Adverse Effects | Comments
Baracat, 2002 | 85 in 2 groups | open RCT | HH | 12 months | Postmenopausal women with intact uterus. | Inclusion: | 4 point scale, hot flashes calculated separately | 0 | 1/85 | NR | 0 | NR | NR | Excluded | CEE/MPA 25.3 | Tibolone 2.5 mg/day oral | CEE/MPA 0.625/5 mg/day oral | Decreased intensity and mean number hot flashes in both groups. No significant difference between groups | Significant improvement in both treatment groups, p value not reported. | Improvement in both groups. No significant difference between treatment groups. | Improvement in both groups. No significant difference between treatment groups. | Improvement in both groups. No significant difference between treatment groups. | Improvement in both groups. No significant difference between treatment groups. | NR | No significant difference between treatment groups. | Improvement in both groups. No significant difference between treatment groups. | NR | Cholesterol levels | CEE/MPA: 5 | CEE/MPA: 4 | HeadacheT-2.5%, CEE 6.7% | 4 point scale: 0 (absent) to 3 (severe). Hot flushes per cycled calculated as: sum of mean number of hot flushes per day multiplied by respective score 0 (absent) to 3 (severe).
| | | | | EE/MPA mean age: 53 (45–65) | 1. Ages 45–65 years | | | | | | | | | Tibolone 25.0 | | | | | | | | | | | | | Weight gain | Tibolone: 4 | Tibolone: 3 | Nausea
| | | | | Tibolone mean age: 51 | 2. Intact uterus | | | | | | | | | | | | | | | | | | | | | | | | | Breast pain T 2.5%, CEE 11%
| | | | | | 3. Natural menopause > 6 months prior | | | | | | | | | | | | | | | | | | | | | | | | | Vaginal bleeding CEE only
| | | | | | 4. > 4 hot flushes/day | | | | | | | | | | | | | | | | | | | | | | | | | Pelvic pain T5%, CEE4.4%, Fatigue/HTN/leg cramps/low back pain -T2.5% CEE2.2%, Dysuria-7.5%,
| | | | | | Exclusion:
| | | | | | 1. History or presence of clinically significant physical disease, undiagnosed vaginal bleeding, hypertension, obesity, excessive smoking, alcohol or drug abuse
| | | | | | 2. >Pap smear class III
| | | | | | 3. Use of estrogens, progestins, androgens, Tibolone, or lipid-lowering agents within 90 days of evaluation
| | | | | | 4. Known sensitivity to an investigational or a related drug
Benedek-Jaszmann, 1987 | 60 in 2 groups | DB | P | 12 months | Post-menopausal women attending a menopause clinic. | Inclusion: | 4 point scale | NR | NR | NR | 0/60 | NR | NR | NR | NR | Tibolone 2.5 mg/day | Placebo | Improved in Tibolone group throughout study, p<.05 | NR | Improved in Tibolone group at month 3 only, p<.05 | Improved in Tibolone group at month 6 only, p<.05 | NR | NR | NR | NR | NR | NR | Cholesterol, Irritability improved in Tibolone group at months 1, 6, 12, p<.05. Psychic instability improved in Tibolone group at months 1, 3, 6, 12, p<.05. | Tibolone: 6 | Tibolone: 4 | Weight gain (T-2, P-1) Limb pain (T-2, P-1) Skin problem (P-1) Nausea (P-1) | 4 point scale: 0 (absent) to 3 (severe). Clinical parameters measured at month 1, 3, 6, 9, 12.
| | RCT | | | Age 44–61 | 1. Menopausal | | | | | | | | | | | | | | | | | | | | | | | Placebo: 11 | Placebo: 4
| | | | | | Exclusion:
| | | | | | 1. Current or past h/o cancer or thromboembolic disease
Berning, 2000 | 94 in 3 groups | RCT | P | 2 years | Post-menopausal (1–3years), non-smoking, White, with a BMI < 27. Mean age 52.7 | Inclusion: | NR | 0/94 | 0/94 | NR | NR | NR | NR | NR | Median 24.3 | Tibolone 1.25 mg/day n=36 | Placebo | NR | NR | NR | NR | NR | NR | NR | Compared to placebo, Increased number bleeders in Tibolone 2.5 mg group, p<.05. Non significantly increased number bleeders in Tibolone 1.25 mg group. Total number bleeding episodes significantly increased in Tibolone 2.5 mg compared to Tibolone 1.25 mg, p<.05 and placebo, p<.01. | NR | NR | Estradiol levels and endometrial morphology | Tibolone 1.25:3 | Tibolone 1.25: 2 | Vaginal bleeding (T1.25-1), Skin reaction (T1.25-1) | This study not designed to assess effects of Tibolone on menopausal symptoms.
| | | | | | 1. White | | | | | | | | | | Tibolone 2.5 mg/day n=35 | | | | | | | | | | | | | Tibolone 2.5: 3
| | | | | | 2. Non-smoking | | | | | | | | | | Placebo n=23 | | | | | | | | | | | | | Placebo: 4
| | | | | | 3. BMI<27
| | | | | | Exclusion:
| | | | | | 1. No disease
| | | | | | 2. No medication that influences calcium metabolism
Dansuk, 2002 (Abstract only) | 140 in 2 groups | RCT | HH | 3 months | Hysterctomized postmenopausal women | Inclusion: | Kupperman | 140/140 | NR | NR | NR | NR | NR | 0 | NR | Tibolone 2.5 mg/day oral | E2 0.05 mg/day Transdermal | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | Cholesterol levels | 0 | 0 | NR | No difference in climacteric symptoms reported between the 2 treatment groups. Specific categories not reported.
| | | | | | 1. Women who were hysterectomized > 1 year prior
| | | | | | Exclusion:
| | | | | | 1. Previous estrogen use
| | | | | | 2. Use of lipid lowering drugs
De Aloysio, 1987 | 124 in 3 groups | Open RCT | P | 4 months | Post-menopausal women attending a menopause clinic. | Inclusion: | NR | 24/124 | 24/124 | NR | 0/124 | NR | NR | No HRT in prior 6 months | Tibolone approx 23 | Tibolone 2.5 mg/day n=35 | Placebo IM injection n=46 | Improved in Tibolone group, p<.01 | NR | No significant difference between treatment and placebo or control groups. | NR | NR | NR | NR | NR | NR | NR | Cholesterol, BMI, BP, electrolytes, coagulation, gonadal hormones | Tibolone: 21 | Tibolone: 5 | Uterine bleeding (T-3), Weight gain (P-1), Anxiety (P-1), GI distress (T-2)
| | | | | | 1. Post-menopausal | | | | | | | | | Placebo approx 25 | | Control n=43 | | | | | | | | | | | | Placebo: 10 | Placebo: 2
| | | | | | Exclusion: | | | | | | | | | Control approx 25 | | | | | | | | | | | | | | Control: 13
| | | | | | 1. No endometriosis, fibrocystic mastitis, estrogen-related tumors, anemia, thromboembolic or liver disease, HT preceding 6 months, medications, early menopause
Egarter, 1996 | 129 in 2 groups | Un-blinded RCT | HH | 6 months | Postmenopausal women on no HRT for at least 6 months. Mean age approximately 53.5 | Inclusion: | Kupperman Index | 0/129 | NR | NR | 0 | NR | NR | No HRT in past 6 months | NR | Tibolone 2.5 mg/day oral | CEE 0.625 mg/day + medrogestone 10 mg/day for 12 days/month | Improvement in both groups. No difference between groups. | Improvement in both groups. No difference between groups. | Improvement in both groups. No difference between groups. | Improvement in both groups. Higher significance level in Tibolone group, p<0.001 vs. p<0.01. | NR | Overall, improvement in both groups with no significant difference between groups. | NR | NR | Improvement in both groups. Higher significance level in Tibolone, p<0.001, than CEE/medrogestone p<0.05. | NR | Endometrial thickness | Tibolone: 15 | Tibolone: 3 | Weight gain T-2, HRT-4 | Treatment groups were significantly different at baseline with regard to nervousness.
| | | | | | 1. Spontaneous menopause > 12 months prior | | | | | | | | | | | | | | | | | | | | | | | CEE/medroge-stone: 18 | CEE/medroge-stone: 6 | Bleeding HRT-4
| | | | | | 2. No use of HRT in last 6 months | | | | | | | | | | | | | | | | | | | | | | | | | Headache T-2, HRT-2
| | | | | | Exclusion: | | | | | | | | | | | | | | | | | | | | | | | | | Leg pain T-4
| | | | | | 1. Use of short-acting hormones within 3 months
| | | | | | 2. Hysterectomy
| | | | | | 3. Injection of long-acting estrogens within 6 months
| | | | | | 4. Existing or suspected hormone-dependent tumors, vaginal bleeding of unknown etiology, severe liver disorders, current or previous cardiovascular or cerebrovascular disorders
Hammar, 1998 | 437 in 2 groups | DB | HH | 48 weeks | Symptomatic menopausal women | Inclusion: | 5 point scale | 0/437 | NR | NR | NR | NR | NR | NR | Tibolone 24.6 | Tibolone 2.5 mg/day oral | E2 NETA 2 mg/day oral | Improvement with both treatments. Significantly greater decrease with E2/NETA at last visit, p<0.001. | Improvement with both treatment groups, p<0.0001. | NR | NR | NR | NR | NR | Decreased in Tibolone group, p<0.0001. | NR | NR | NR | Tibolone: 54 | Tibolone: 34 | Breast tenderness T-44, E2-119 | Menopausal symptoms rated on a 5 point scale (1 = none; 5 = very severe).
| | RCT | | | | 1. Physically and mentally healthy women | | | | | | | | | E2/NETA 24.3 | | | | | | | | | | | | | | E2/NETA: 68 | E2/NETA: 55 | Edema T-72, E2-61
| | | | | | 2. > 1 year since last menstrual bleeding | | | | | | | | | | | | | | | | | | | | | | | | | Nausea T-51, E2-63
| | | | | | 3. Menopausal complaints | | | | | | | | | | | | | | | | | | | | | | | | | Bleeding T-9, E2-37
| | | | | | 4. Intact uterus
| | | | | | 5. BMI < 30kg/m2
| | | | | | Exclusion:
| | | | | | 1. Usual exclusion criteria for HRT applied
Huber, 2002 | 501 in 2 groups | DB | HH | 1 year | Postmenopausal women with intact uterus < 65. Mean age: 55 | Inclusion: | Q-LES-Q | 0/501 | NR | NR | NR | NR | < 4 alcoholic beverages per day | No HRT one month prior to trial | Tibolone 24.8 | Tibolone 2.5 mg/day oral | CEE 0.625 mg/day + MPA 5 mg/day oral | No significant difference between groups on GCS | No significant difference between groups on GCS | No significant difference between groups on GCS | No significant difference between groups on PGWBI or GCS | NR | No significant difference between groups on GCS | No signif-icant differen-ce between groups on LUCRS | Significantly decreased in Tibolone group during cycles 1–3, p=0.002 and 4–6, p=0.004. | Significantly improved sexual interest, drive, and/or performance in Tibolone group at 12 months, p=0.017 (Q-LES-Q). | Significant differences between group in sexual drive and economic domains of Q-LES-Q only (see appropriate boxes). | Economic status score of Q-LES-Q higher at 3 months for CEE/MPA group, p=0.029. | Tibolone: 62 | Tibolone: 38 | Vaginal bleeding T-20, HRT-15
| | RCT | | | | 1. Postmenopausal women with last period > 12 months prior | PGWBI | | | | | | | | CEE/MPA 24.7 | | | | | | | | | | | | | | CEE/MPA: 50 | CEE/MPA: 33 | Breast tenderness T-6, HRT-43
| | | | | | 2. Under the age of 65 years | GCS | | | | | | | | | | | | | | | | | | | | | | | | HeadacheT-22, HRT-17; Back pain T-13, HRT-11; Body pain T-4, HRT-12; Depression T-11, HRT-10; Weight gain T-9, HRT-8; Anxiety T-8, HRT-3, Uterine bleeding T-20, HRT-15
| | | | | | 3. If date of natural menopause is unknown due to HRT use, women must be > 53 years and received HRT for > 2 years with it ending with progestin phase | LUCRS
| | | | | | 4. Intact uterus
| | | | | | 5. BMI of 18–29 kg/m2
| | | | | | Exclusion:
| | | | | | 1. Presence or history of hormone-dependent malignancies, known or suspected hypercholesterolemia, hypertension, liver disease, endometrial hyperplasia, undiagnosed vaginal bleeding, prophyria, haemoglobinopathie
| | | | | | 2. Presence or history of cardiovascular, cerebrovascular or thromboembolic disorders
| | | | | | 3. Use of HRT during last month prior to start
| | | | | | 4. Previous use of implantable or injectable HRT
| | | | | | 5. Concomitant use of sex hormones or any drugs that could interfere with trial medication
| | | | | | 6. Drinking > 4 glass of alcohol/day
Hudita, 2003 | 162 in 2 groups | DB | P | 24 weeks | Non-obese postmenopausal women with intact uterus. Mean age approximately 56 (40–65). | Inclusion: | McCoy Sex Scale (modified), 5 point scale for menopausal symptoms | 0/162 | NR | NR | 0/162 | 0/162 | NR | No hormones 8 weeks prior to study | Mean approximately 25 | Tibolone 1.25 mg/day | Placebo | Significant improvement in both treatment groups at 4, 12, and 24 weeks, p<.01. Greater improvement at 4 weeks with Tibolone 2.5 mg than Tibolone 1.25 mg, p<.05 | Significant improvement in both treatment groups at 4, 12, and 24 weeks, p<.01. Greater improvement at 4 and 8 weeks with Tibolone 2.5 mg than Tibolone 1.25 mg, p<.05 | NR | NR | NR | NR | NR | Significantly increased bleeding at week 12 in both treatment groups, p<.05 | Significant improvement in both treatment groups at weeks 4, 12, and 24, p≤.05. Tibolone 1.25 mg had greater improvement at week 12 than Tibolone 2.5 mg, p<.05. Tibolone 2.5 mg had greater improvement at week 24, p<.05. | NR | Cholesterol levels | 42 | NR | Breast discomfort (Tibolone 1.25–2, Tibolone 2.5–4)
| | RCT | | | | 1. Age 40–65, intact uterus | | | | | | | | | | Tibolone 2.5 mg/day | | | | | | | | | | | | | | | Fluid retention (Tibolone 1.25–3, Tibolone 2.5–2)
| | | | | | 2. Amenorrhea for 12 months | | | | | | | | | | | | | | | | | | | | | | | | | Vaginal spotting (Placebo-2, Tibolone 1.25–4, Tibolone 2.5–2)
| | | | | | 3. FSH >30 mlU/ml | | | | | | | | | | | | | | | | | | | | | | | | | Headache (Placebo-2, Tibolone 1.25–3, Tibolone 2.5–2)
| | | | | | 4. 17 beta-estradiol <50pg/ml | | | | | | | | | | | | | | | | | | | | | | | | | Nausea (Placebo-1)
| | | | | | Exclusion:
| | | | | | 1. History of VTE disease
| | | | | | 2. GYN cancer
| | | | | | 3. Uncontrolled DM
| | | | | | 4. Abnormal mammogram/pap/ lab values
| | | | | | 5. History of kidney/liver disease
| | | | | | 6. Use of hormones 8 weeks prior to study
| | | | | | 7. Other criteria
Johannes, 1997 (abstract only) | 770 in 4 groups | DB | P | 12 weeks | Non-hysterectomized post-menopausal women. | Inclusion: | NR | 0/770 | NR | NR | NR | NR | NR | NR | 24.8 | Tibolone | Placebo | Significant decrease in incidence with 1.25, 2.5, and 5.0 mg/d dose, p<0.05. | NR | NR | NR | NR | NR | NR | Higher incidence in 5.0 mg/d group in comparison to other doses and placebo, p value not reported. | NR | NR | NR | NR | NR | Bleeding
| | RCT | | | Mean age: 52 | 1. Postmenopausal women | | | | | | | | | | 0.625 mg/day
| | | | | | 2. Non-hysterectomized | | | | | | | | | | 1.25 mg/day
| | | | | | | | | | | | | | | | 2.5 mg/day
| | | | | | | | | | | | | | | | 5.0 mg/day oral
Kö kçü, 2000 | 50 in 2 groups | RCT | HH | 1 year | Women with natural menopause. Mean age not reported. | Inclusion: | Questionnaire | NR | NR | NR | NR | NR | NR | NR | NR | Tibolone | CEE 0.625 + MPA 2.5 mg/day oral | NR | NR | NR | NR | NR | NR | NR | NR | Significantly increased sexual desire in Tibolone group, p<0.05. | NR | Both treatment groups with significant improvement in subjective well-being and vasomotor symptoms, p<0.05. | NR | NR | NR | No significant difference in side effects between treatment groups. Specific side effects not reported.
(abstract only) | | | | | | 1. Women with natural menopause | | | | | | | | | | 2.5 mg/day oral
| | | | | | Exclusion:
| | | | | | 1. Contraindication for HRT
Lam, 2004 | 100 in 2 groups | DB RCT cross-over | P | 13 months | Postmenopausal Chinese women from Hormone Replacement Clinics. Mean age approx 50. | Inclusion: | GCS, GHQ, DAS (Dyadic Adjustment Scale) | 0/100 | NR | NR | 0/100 | 0/100 | NR | No hormones in prior 6 months | NR | Tibolone 2.5 mg/day | Placebo | Both groups with significantly reduced vasomotor sub score of GCS; p<.05 | Both groups with significantly reduced urogential sub score of GCS, p<.05 | NR | Significantly reduced depression sub score of GCS in treatment group, p<.05 | NR | Significant reduction in somatic sub score of GCS in treatment group, p<.05 | Both groups with significantly reduced urogential sub score of GCS, p<.05 | NR | Both groups with significantly reduced sexual sub score of GCS, p<.05 | NR | Marital quality of couples assessed by DAS | Tibolone: 4 | NR | Muscle/bone pain (T-2; P-1) | Modified McCoy Sex Scale used 5 point system. GCS score significantly decreased in both treatment group, p<.05
| | | | | | 1. Married | | | | | | | | | | | | | | | | | | | | | | | Placebo: 2 | | Weight gain (T-2, P-1)
| | | | | | 2. Intact uterus | | | | | | | | | | | | | | | | | | | | | | | | | Headache (T-1)
| | | | | | 3. FSH> 30 IU/L
| | | | | | 4. Estradiol < 100 pmol/L
| | | | | | Exclusion:
| | | | | | 1. Breast/endometrial cancer
| | | | | | 2. Liver/kidney disease
| | | | | | 3. Thromboembolic disease
Landgren, 2002 | 775 in 5 groups | DB | P | 12 weeks | Healthy post menopausal women with hot flushes and sweating. Mean age approximately 52 (40–60). | Inclusion: | Collins and Landgren Rating Scale | 0/775 | NR | NR | 0/775 | NR | NR | NR | Placebo - 25.0 | Tibolone | Placebo | Significant decrease in frequency with 1.25 mg, 2.5 mg, and 5.0 mg doses, p<0.0125 | NR | NR | NR | NR | NR | NR | Dose-related increased vaginal bleeding and spotting. Highest incidence in the 5 mg/d group. Observed throughout 12 week study. | NR | NR | Sweating episodes significantly decreased in the 1.25, 2.5, and 5mg/d groups, p<0.0125. | 99 | 36 | Vaginal bleeding (T and P)
| | RCT | | | | 1. Non-hysterectomized women aged 40–60 years | | | | | | | | | 0.625mg group - 24.5 | 0.625 mg/day | | | | | | | | | | | | | | | others not reported
| | | | | | 2. Absence of spontaneous vaginal bleeding for > 10 months prior to start | | | | | | | | | 1.25mg group - 24.8 | 1.25 mg/day
| | | | | | 3. > 1 moderate-severe hot flush/day | | | | | | | | | 2.5mg group - 24.9 | 2.5 mg/day
| | | | | | 4. Body weight between 80%–130% of ideal weight | | | | | | | | | 5.0mg group - 24.9 | 5 mg/day
| | | | | | Exclusion:
| | | | | | 1. History or presence of any malignant disorder, cardiovascular or cerebrovascular disease, thromboembolism/thrombosis, hepatic or renal disease, epilepsy or classical migraine, vaginal bleeding of unknown etiology, hypertension, rheumatoid arthritis, diabetes mellitus, hyperlipidaemia, any serious disease or psychiatric disorder, hypersensitivity to oestrogen and/or progestin, disease for which exogenous hormonal steroids are contraindicated
| | | | | | 2. Use of sex steroids within 6 weeks
| | | | | | 3. Ethinyloestradiol within the last 6 months
| | | | | | 4. Hormone implants at any time
| | | | | | 5. One or more of the following drugs during the last two months: hydantion, barbiturates, primidone, carbamazepine, rifampicine, griseofulbin, drugs for treating climacteric symptoms
| | | | | | 6. Alcohol abuse and/or drug abuse within the last 12 months
| | | | | | 7. Smoking > 10 cigarettes/day
Lloyd, 2000 | 29 in 2 groups | DB | P | 6 months | Hypertensive post-menopausal women. | Inclusion: | GHQ | NR | NR | NR | NR | No tamoxifen within prior 3 months | 3/30 | No HRT within prior 3 months | Tibolone 33.9 | Tibolone 2.5 mg/day oral | Placebo | NR | NR | NR | NR | NR | NR | NR | NR | NR | No significant differences within or between treatment and placebo at baseline and 6 months. | Blood pressure and lipids | Tibolone: 2 | Tibolone: 1 | Headache (numbers not reported) | Primary outcome was effect of Tibolone on blood pressure and biochemical cardiovascular risk factors in hypertensive women. Quality of life reported as a secondary outcome.
| | RCT | | | Mean age approximately 61 | 1. Women with hypertension | | | | | | | | | Placebo 29.6 | | | | | | | | | | | | | | Placebo: 2 | Placebo: 1 | Nausea (numbers not reported)
| | | | | | 2. > 1 year postmenopausal | | | | | | | | | | | | | | | | | | | | | | | | | Flushing (numbers not reported), Uterine bleeding T-4 P-1
| | | | | | Exclusion:
| | | | | | 1. Intrinsic renal disease, insulin dependent diabetes, past history of an oestrogen dependent tumor
| | | | | | 2. Use of sex steroid compounds, previous HRT, progesterone, Tibolone, or tamoxifen within previous 3 months
Meeuwsen, 2002 | 85 in 2 groups | DB | P | 1 year | Health women postmenopausal for 1–15 years. Mean age approximately 54. | Inclusion: | NHP | Tibolone: 4 | 0/85 | NR | NR | NR | NR | No HRT 6 months prior to trial | 25 in both groups | Tibolone 2.5 mg/day oral | Placebo | Significantly decreased in Tibolone at cycle 12 in comparison to placebo, p<0.05 | NR | Significant improvement in Tibolone group in comparison to placebo, p<0.05 by NHP score. | No significant difference between treatment groups by NHP score. | NR | No significant difference between treatment groups in energy, pain, social isolation. | No significant difference between treatment groups. | Overall increased frequency in Tibolone group, p<0.05. | NR | No significant difference in overall NHP score between treatment groups. | NR | Tibolone: 1 | Tibolone: 1 | Malaise T-2 | NHP used to assess quality of life and organized into 6 domains: emotional reactions, energy, pain, physical mobility, sleep, and social isolation.
| | RCT | | | | 1. > 1 year but < 15 years after natural menopause | | Placebo: 5 | | | | | | | | | | | | | | | | | | | | | Placebo: 2 | Placebo: 0 | Vaginal bleeding (but no Withdrawal due to vaginal bleeding) T-16, P-4; Abnormal mammogram P-1
| | | | | | Exclusion:
| | | | | | 1. Presence or history of sex hormone dependent malignancies
| | | | | | 2. Use of HRT or other steroid medication or muscle growth affecting drugs during last 6 months
| | | | | | 3. Hypertension, active liver disease
| | | | | | 4. Presence or history of endometrial hyperplasia with or without atypia, undiagnosed vaginal bleeding
| | | | | | 5. Presence or history of cardiovascular, cerebrovascular or thromboembolic disorders
| | | | | | 6. Consumption of > 4 alcoholic drinks/day
| | | | | | 7. Pophyria, haemoglobinopathy
| | | | | | 8. Use of sex hormones, anabolcs, corticosteroids, insulin, anti-coagulants or enzyme-inducing drugs
| | | | | | 9. Participating in a clinical trial during the last 3 months
| | | | | | 10. BMI below 18 kg/m2 or above 29 kg/m2
| | | | | | 11. Concomitant medication that could interfere with the study
Mendoza, 2000 | 76 in 2 groups | RCT | HH | 1 year | Surgically menopausal women < 50. Mean age not reported | Inclusion: | Kupperman Index | 76/76 | 76/76 | NR | 0 | 0 | Alcohol: | 0 | NR | Tibolone 2.5 mg/day oral | Estradiol 50 mcg/day Transdermal | No significant difference between treatments. Both groups improved. | NR | NR | No significant difference between treatments. Both groups improved. | NR | NR | NR | NR | No significant difference between treatments. | NR | Lipids | NR | Tibolone: 3 | Headache E2-1
| | | | | | 1. Women who underwent a hysterectomy or bilateral oophorectomy for benign gynecologic process | | | | | | | Tibolone 1/36 | | | | | | | | | | | | | | | | | Estradiol: 1 | Nausea T-4, E2-1
| | | | | | 2. 3–4 months from surgery to study entry | | | | | | | Estradiol 0/37 | | | | | | | | | | | | | | | | | | Skin irritation
| | | | | | Exclusion: | | | | | | | Smoking: | | | | | | | | | | | | | | | | | | Breast tenderness E2-4
| | | | | | 1. Prior use of HRT | | | | | | | Tibolone 11/36 | | | | | | | | | | | | | | | | | | Weight gain T-1, E2-2
| | | | | | 2. Previous malignant gynecologic process, oestrogen producing tumor, endocrinological or metabolic problems, cardiovascular disease, uncontrolled hypertension, active hepatic disease, serious skin illness, intestinal sickness or chronic obstructive respiratory disease | | | | | | | Estradiol 10/37 | | | | | | | | | | | | | | | | | | Edema T-1, E2-1
| | | | | | 3. Psychiatric problems or receiving anxiolytic or antidepressive drugs | | | | | | | | | | | | | | | | | | | | | | | | | Hirsutism T-1
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Nervousness T-1
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Endometriosis T-1
Mendoza, 2002 | 165 in 3 groups | RCT | HH | 1 year | Postmenopausal women with intact uterus amenorrhea 1–5 years. Mean age approximately 50. | Inclusion: | Modified Kupperman Index | 0/165 | NR | NR | NR | NR | No alcohol use. | No HRT 3 months prior to trial. | No BMI > 32 | Tibolone 2.5 mg/day oral or | Estradiol 50 mcg/day Transdermal + progesterone 200 mg 2×/week oral. | No significant difference between treatment groups (all improved) | NR | No significant difference treatment between groups. | No significant difference treatment between groups. | No significant difference treatment between groups. | No significant difference treatment between groups. | NR | NR | No significant difference treatment between groups. | NR | Lipid profiles | Tibolone: 4 | Tibolone: 4 | Vaginal bleeding T-3, HRT-25 | Symptoms on Kupperman Scale evaluated by frequency of occurrence (frequently, occasional, never). Symptoms divided into 4 categories: vasomotor, psychological, osteoarticular, and sexual behavior.
| | | | | | 1. Intact uterus | | | | | | | Smoking Tibolone 18%. | | | Estradiol 50 mcg/day × 14 days, then Estradiol 50 mcg/day + NETA 0.25mg/day × 14 days Transdermal | | | | | | | | | | | | | Intermittent progesterone: 3 | Intermittent progesterone: 3 | Headache T-4, HRT-2
| | | | | | 2. Amenorrhea for 1–5 years | | | | | | | Cyclic combined 23.6%. | | | | | | | | | | | | | | | | Cyclic combined: 1 | Cyclic combined: 1 | Skin irritation HRT-11
| | | | | | 3. Under 60 years of age | | | | | | | Intermittent progesterone 20%. | | | | | | | | | | | | | | | | | | Varicose veins
| | | | | | Exclusion: | | | | | | | | | | | | | | | | | | | | | | | | | Hypertension T-1
| | | | | | 1. Hysterectomized women | | | | | | | | | | | | | | | | | | | | | | | | | Stomach pain T-3
| | | | | | 2. Use of HRT within 3 months prior to start | | | | | | | | | | | | | | | | | | | | | | | | | Anxiety HRT-1
| | | | | | 3. History of a malignant gynecological processes, oestrogen producing tumor, serious endocrine or metabolic disturbances, insulin dependent diabetes, obesity (BMI > 32 kg/m2), unstable hypertension, active liver disease, serious skin disease or chronic obstructive pulmonary disease | | | | | | | | | | | | | | | | | | | | | | | | | Dysmenorrheal HRT-1
| | | | | | 4. Psychiatric disturbance or use of anxiolytics or antidepressants | | | | | | | | | | | | | | | | | | | | | | | | | Mastalgia HRT-3
Nathorst-Bö ö s, 1997 | 437 in 2 groups | DB | HH | 48 weeks | Postmenopausal women of at least one year or using HRT more than 2 years. All participants > 53 | Inclusion: | McCoy Sex Scale (Swedish version) | 0/437 | NR | NR | NR | NR | NR | 437/437 discontinued one month prior | < 30 | Tibolone 2.5 mg/day oral | E2 2 mg/day + NETA 1 mg/day oral | NR | Improvement with both treatment groups. No significant difference between groups. | NR | NR | NR | NR | NR | NR | Greater improvement in the Tibolone group in regard to the frequency and enjoyment, p<0.05. | NR | NR | 122 | NR | NR
| | RCT | | | | 1. Healthy women
| | | | | | 2. > 1 year postmenopausal or using HRT > 2 years
| | | | | | 3. > 53 years old at study entry
| | | | | | 4. Suffered from hot flushes and sweating
| | | | | | 5. Had BMI < 30
| | | | | | 6. Had intact uterus
| | | | | | Exclusion:
| | | | | | 1. Receiving HRT < 1 month prior to study
| | | | | | 2. History of atypical endometrial hyperplasia
| | | | | | 3. Had severe metabolic or endocrine disease
Palacios, 1995 | 28 in 2 groups | SB | HH | 12 months | Menopausal women, ages 50–60, with no history of HRT, married once, in a stable marriage | Inclusion: | 7 point scale | 0 | 0 | NR | NR | NR | NR | 0 | NR | Tibolone 2.5 mg/day oral | Calcium 500 mg/day oral | NR | NR | NR | NR | NR | NR | NR | NR | Improved total score in Tibolone group, p<0.05 | NR | NR | 4 | 0 | NR | One primary goal of study was to demonstrate validity of sexual questionnaire designed by investigators. (10 item questionnaire scored on a 7 point scale.)
| | RCT | | | | 1. Postmenopausal women
| | | | | | 2. 50–60 years old
| | | | | | 3. Intact uterus and ovaries
| | | | | | 4. Married only once and in stable relationship
| | | | | | 5. Normal bone densitometry
| | | | | | Exclusion:
| | | | | | 1. Received hormone therapy during menopause
| | | | | | 2. Had known associated diseases
Ross, 1999 | 36 in 2 groups | RCT | HH | 3 months | Peri- and post-menopausal women with climacteric symptoms. Mean age 52 (45–65) | Inclusion: | WHQ | 0/36 | NR | NR | NR | NR | Smokers: | NR | NR | Tibolone 2.5 mg/day | CEE 0.625 mg/day | No significant difference between the treatment groups on GCS. | NR | NR | No significant difference between the treatment groups (WHQ). | No significant difference between the treatment groups (WHQ). | No significant difference between the treatment groups (WHQ). | NR | No significant difference between the treatment groups (WHQ). | No significant difference between the treatment groups (WHQ). | NR | | Tibolone: 2 | Tibolone: 2 | NR
| | | | | | 1. English speaking women > 45 years of age | IDA | | | | | | Tibolone 9/18 | | | | Norgestrol 150 mg/day | | | | | | | | | | | | CEE: 6 | CEE: 4
| | | | | | 2. Intact uterus | GCS | | | | | | CEE 14/18 | | | | 12 days of cycle
| | | | | | 3. Amenorrhea > 3 months
| | | | | | 4. No past psychotic history nor current use of antidepressants or psychotherapeutic agents
| | | | | | 5. No contraindications to estrogen therapy
Volpe, 1986 | 113 in 7 groups | RCT | P | 6 months | Postmenopausal women | Inclusion: | 4 point scale | 32/113 | 32/113 | NR | NR | NR | NR | NR | NR | 1. CE 0.625mg/day for 21 days/month + NETA 5mg/day for 10 days/month | Placebo | Improved in all treatment groups | NR | NR | NR | NR | NR | NR | NR | NR | NR | Cholesterol levels | 11 | NR | NR | Hot flushes scored on 4 point scale: 0 (absent), 3 (mild), 6 (moderate), 9 (severe). All other menopausal symptoms scored on 4 point scale: 0 (absent) to 3 (severe).
| | | | | | 1. Postmenopausal women | | | | | | | | | | 2. CE 0.625 mg/day for 21days/month + CPA 12.5 mg/day for 10 days/month
| | | | | | 2. Physiological menopause or hysterectomy and oophorectomy | | | | | | | | | | 3. Estradiol valerate 2 mg/day for 21 days/month + NETA 5 mg/day for 10 days/month
| | | | | | 3. Last menstrual period occurred 1–5 years prior to study | | | | | | | | | | 4. Estradiol valerate 2 mg/day for 21 days/month + CPA 12.5 mg/day for 10 days/month
| | | | | | Exclusion: | | | | | | | | | | 5. Estnol 2–4 mg/day
| | | | | | 1. Received hormone preparations < 8 weeks prior to study
| | | | | | 2. Histories or conditions which would contraindicate oestrogen therapy
Winkler, 2000 | 60 in 2 groups | DB | HH | 24 weeks | Healthy post-menopausal women. | Inclusion: | Karolinska Scale | 24/60 | NR | NR | NR | NR | 0 smokers | NR | Tibolone 24.7 | Tibolone 2.5 mg/day | Estradiol 2 mg/day + Estradiol 1mg/day + norethindrone acetate 1 mg/day | Improved in both groups. No significant difference between groups, p values not reported. | Improved in both groups. No significant difference between groups, p values not reported. | NR | NR | NR | NR | NR | No significant difference between treatment groups. | NR | NR | Hemostasis measurements | Tibolone: 4 | Tibolone: | Weight gain T-2 | Climacteric symptoms reported as a secondary outcome. Primary outcome was hormone effect on clotting cascade.
| | RCT | | | Mean age approximately 54 (45–70) | 1. Healthy postmenopausal women aged 45–70 years | | | | | | | | | HRT 26.0 | | | | | | | | | | | | | | HRT: 4 | HRT: 3 | Sleep disturbance T-1
| | | | | | 2. Spontaneous menopause with last period > 36 months prior or artificial menopause with FSH >30lU/L | | | | | | | | | | | | | | | | | | | | | | | | | Breast tenderness T-3.4%, HRT 25.8%
| | | | | | Exclusion: | | | | | | | | | | | | | | | | | | | | | | | | | Vaginal bleeding HRT-1
| | | | | | 1. Presence of cardiovascular, cerebrovascular or thromboembolic disorders, hypertension, hypercholesterolemia, liver, renal, thyroid, parathyroid or adrenal disorders, insulin dependent diabetes, undiagnosed vaginal bleeding, malignancy if not cured for > 10 years
| | | | | | 2. History or presence of hormone-dependent malignancy
| | | | | | 3. Chronic use of medication that might affect metabolism of sex steroid
| | | | | | 4. Drug or alcohol abuse within last 12 months
| | | | | | 5. Use of investigational drugs with the last 3 months
| | | | | | 6. Cigarette smoking
Wu, 2001 | 48 in 2 groups | SB | HH | 3 months | Postmenopausal women with at least one climacteric symptom. Mean age 51 (38–56). | Inclusion: | Mc Coy Sex Scale | NR | NR | NR | NR | NR | NR | NR | NR | Tibolone 2.5 mg/day oral | CEE 0.625 mg/day + MPA 5 mg/day | No significant difference between treatment groups. | Improved in Tibolone group, p<0.05 (GCS). | NR | No significant difference between treatment groups | NR | No significant difference between treatment groups | NR | At 3 months, Tibolone 2/16 | Improved in Tibolone group, p<0.05 (McCoy Sex Scale). | NR | Hormone and cholesterol levels | 12 | 7 (3 Tibolone, 4 HRT) | Body discomfort T-3, HRT-4
| | RCT | | | | 1. Women who were 12–36 months postmenopausal | GCS | | | | | | | | | | | | | | | | | | HRT 6/16
| | | | | | 2. > 1 climacteric symptom
Yang, 1997 (abstract only) | 40 in 2 groups | RCT | HH | 6 months | Women 1–3 years post-menopause | Inclusion: | GCS | NR | NR | NR | NR | NR | NR | NR | NR | Tibolone 2.5 mg/day oral | Premarin 0.625 mg/day oral | NR | NR | NR | NR | NR | NR | NR | Reported for both treatment groups, p value not reported. | NR | NR | Improvement of climacteric symptoms reported in both treatment groups, p value not reported. | NR | NR | NR
| | | | | | 1. Postmenopausal women (1–3 years) | | | | | | | | | | | Provera 5 mg/day day 1–12 months oral
Yang, 1999 | 40 in 2 groups | open RCT | HH | 6 months | Symptomatic postmenopausal women. | Inclusion: | GCS | NR | NR | NR | 0 | NR | NR | NR | Tibolone 21.5 | Tibolone 2.5 mg/day oral | CEE 0.625 + MPA 5 mg/day 12 days/month | Improvement in both treatment groups, p<0.05 | NR | NR | Improvement in both treatment groups, p<0.05. | Improve-ment in both treatment groups, p<0.05 | Improve-ment in both treatment groups, p<0.05 | NR | NR | Improvement in both treatment groups, p<0.05 | NR | Bone metabolism | 4 | NR | Weight gain T-1
| | | | | CEE/MPA mean age: 52 | 1. Women 1–3 years postmenopausal with significant menopausal symptoms | | | | | | | | | CEE/MPA 22.5 | | | | | | | | | | | | | Bone density | | | Uterine bleeding T-6, HRT-20
| | | | | Tibolone mean age: 51 | Exclusion: | | | | | | | | | | | | | | | | | | | | | | Cholesterol levels | | | Insomnia T-2, HRT-2
| | | | | | 1. Any of the following: known or suspected tumor; significant bone diseases; cardiovascular, cerebrovascular or thromboembolic disorders; vaginal bleeding of unknown etiology | | | | | | | | | | | | | | | | | | | | | | Effect on endometrium. | | | Backache T-1, HRT-1 (All Effects in first 3 months)
| | | | | | 2. Active gastrointestinal or liver disease or gastrointestinal surgery likely to influence drug absorption
| | | | | | 3. Diabetes, renal disease, epilepsy or history of epilepsy, rheumatic arthritis, osteoarthritis, or other arthritic processes severely restricting mobility, thyroid function disorders or adrenal disorders
| | | | | | 4. Abuse of drugs or alcohol
| | | | | | 5. Medication use that may affect bone/calcium metabolism
| | | | | | 6. Uncontrolled hypertension
| | | | | | 7. Heavy smokers

Key/Abbreviations

BMI = Body mass index

BP = Blood pressure

CE = Conjugated estrogens

CEE= Conjugated equine estrogens

CPA = Cyproterone acetate

DAS = Dyadic Adjustment Scale

DB = Double blind

DM = Diabetes mellitus

E2 = Estradiol

EE = Esterified Estrogen

GCS = Greene Climacteric Scale

GHQ = General Health Questionnaire

HH = Head to head

HRT = Hormone replacement therapy

HTN = Hypertension

IDA = Irritability, Depression, and Anxiety

LUCRS = Local Urogenital Complaints Rating Scale

MPA = Medroxyprogesterone acetate

NETA=norethidrone acetate

NHP = Nottingham Health Profile

NR = Not reported

P = Placebo

PGWB-I = Psychological General Well-Being Index

Q-LES-Q = Quality of Life, Enjoyment and Satisfaction Questionnaire

RCT = Randomized controlled trial

SB = Single blind

SERMs = Selective Estrogen Receptor Modifiers

T = Tibolone

VTE = Venous thromboembolism

WHQ = Women's Health Questionnaire

Evidence table 6-6. Key Question 3E Antidepressant drugs

| | | | | | | | Specific Characteristics of Population | | | | | | | | Treatment | | Hot Flash Outcomes | | | | Outcomes
Study/Year | N | Type of Trial | Comparison | Length of Trial | Population | Inclusion/Exclusion Criteria | Measures Used | Hysterectomy (#/n) | Bilateral Oophorectomy (#/n) | Premature Ovarian Failure (#/n) | Breast Cancer (#/n) | Use of SERMS (#/n) | Behavior or Lifestyle Factors* (#/n) | Recent discontinuation of HRT (#/n) | High or Low BMI (#/n) | Main Drug type; dose; regimen | Other Drugs type; dose; regimen | Reduction in Hot Flash Frequency | Reduction in Hot Flash Severity | Reduction in Hot Flash Composite Score | Other Hot Flash Measure | Other Outcomes | Vaginal Dryness | Sleep | Mood | Cognitive | Somatic | Urinary | Uterine Bleeding | Sexual Dysfunction | Quality of Life | Other Outcomes | Withdrawals | Withdrawals due to AEs | Adverse Effects | Comments
David 1988 | 50 | RCT | P | 4 20-day courses | Patients from menopause clinic in Israel; aged 32–81; many postmenopausal for many years | NR | HF frequency; severity of perspiration; FSH, LH, testosterone, E2 | NR | NR | NR | NR | NR | NR | NR | NR | Veralipride 100mg PO qd (V) | Placebo | Pre-post comparisons only: | NR | NR | NR | All groups had decrease in insomnia and depression with no significant differences. | NR | All groups had decrease in insomnia | All groups had decrease in depression | NR | NR | NR | NR | NR | NR | LH, testosterone, Prolactin, DHEA | 3 | 0 | NR
| | | | | | | | | | | | | | | | | | Group 1 (V × 4): 80% reported almost complete disappearance of HF.
| | | | | | | | | | | | | | | | | | Group 2 (P×2, V×2): HF frequency 18 at baseline; 12 with P, almost complete resolution with V.
| | | | | | | | | | | | | | | | | | Group 3 (V×2, P×2): baseline 15, almost complete resolution with V; up to 6–12.
Evans 2005 | 80 | RCT | P | 12 weeks | Postmenopausal, symptomatic women. Recruited through newspapers, radio, direct mailings, and flyers posted in physicians' offices. | Inclusion: | Modified Health Survey Short Form 36 mood scale; single-item 5-point scale about hot flashes interfrerence with daily living; daily hot flash diary (severity 1–4). | 16/80 | NR | NR | NR | NR | Alcohol use 14/40 in controls and 25/40 in treatment | 0 | NR | Venlafaxine XR, 37.5mg daily for 1 week, then 75mg daily | Placebo | No difference between groups. | No difference between groups. | No difference between groups. Both groups had reduction in HF score (no p-value given). | Venlafaxine 51% reduction in patient-perceived hot flush score; Placebo 15% reduction; p<0.001. (single item on interference of HF with daily living) | NR | NR | NR | Mental health improved in tx vs. P on SF36 (p=0.005) | NR | NR | NR | NR | Possibly more sexual dysfunction in tx than P (p=0.11) | Vitality improved in tx vs. P on SF36 (p=0.005) | NR | 11/40 in tx; 8/40 in P | Difficulty sleeping decreased libido, nausea and anxiety in tx group | Greater dry mouth, sleeplessness, and decreased appetite in tx than P, but dizziness, tremors, anxiety, diarrhea, and rash less in tx than P.
| | | | | | 1. Natural or surgical menopause
| | | | | | 2. ≥ 14 hot flashes per week
| | | | | | Exclusion:
| | | | | | 1. Known adverse reactions to antidepressants
| | | | | | 2. Receiving estrogens, progestins, antidepressants, or chemotherapy
Limouzin-Lanothe, 1994 | 499 | Non-blind RCT | HH | 6 months | Enrolled by 101 physicians in France; all literate and “enjoyed a comfortable standard of living” | Inclusion: | Women's Health Questionnaire, Psychological General Well-Being Index, Sleep Problems Questionnaire; Sexual Behavior Questionnaire. | NR | NR | NR | NR | NR | Similar Education | 0 | NR | Veralipride 100mg/day first 20 days of each month (V) | Estraderm TTS 50 and chlormandinone 1st 12 days of each month | NR | NR | NR | 1 or no HF: | Measures of quality of life, sleep, sexual function, depression, anxiety, general psychological well being, somatic complaints, cognitive difficulties, social life, family life, professional life, and vitality significantly better with HRT than V, but both groups improved over 6 months | NR | HRT group improved more than Veralipride group (p<0.001) | HRT group improved more than Veralipride group (p<0.001) | HRT group improved more than Veralipride group (p<0.01) | HRT group improved more than Veralipride group (p<0.001) | NR | 7/250 in HRT group; 2/249 in V group | HRT group improved more than Veralipride group (p<0.01) | Clinical efficacy for measures of quality of life, sleep, sexual function, depression (general psychological well being) all significantly better with HRT but both groups improved over 6 months | Attractiveness, social life, and vitality all improved more in the HRT group than in Veralipride group | No follow-up data in 10/250 of HRT and 10/249 of V; Discontinued TX: 21 of HRT and 36 of V. | NR | HRT: 67 local skin reaction, 26 systemic reaction;
| | | | | | 1. Natural or surgical menopause with amenorrhea ≥ 3 months but ≤ 3 years | 10 symptoms on a 4-point scale | | | | | | | | | | | | | | HRT: 183/240 (81%) | | | | | | | | | | | | | | V: 23 systemic reactions
| | | | | | 2. ≥ 4 HF/day and nocturnal sweating | | | | | | | | | | | | | | | V: 94/239 (44%) (p<0.001);
| | | | | | Exclusion: | | | | | | | | | | | | | | | Efficacy judged to be “very good” by clinician:
| | | | | | 1. HRT since beginning of menopause | | | | | | | | | | | | | | | HRT: 128/225 (57%)
| | | | | | 2. Symptomatic TX within 1 month | | | | | | | | | | | | | | | V: 39/214 (18%) (p<0.001)
| | | | | | 3. “Estrogen-dependent pathologic characteristic”
Melis, 1988 | 40 | DB RCT | P | 30 days | Recruitment info NR; Italy | Inclusion: | 1. HF frequency; HF severity (0–3); and vasomotor score (frequency × severity) by diary; | NR | NR | NR | NR | NR | NR | 0/40 | NR | Veralipride 100mg/day (V) | Placebo | NR | NR | Frequency (0–3) × intensity (0–3) | # of women experiencing improvement: | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | LH levels opioids | 0 | NR | 0 in placebo group
| | | | | | 1. Postmenopausal women aged 48–56 years | 2. “Objective HF” by skin temp (for 6 hours for 8 women in each group); | | | | | | | | | | | | | V: 3.0-1.0=2 (66% red) | V: 17/20 (50%) | | | | | | | | | | | Veralipride group had increased PRL and LH | | | 3 mastodynia in Veralipride group
| | | | | | 2. Physiologic menopause ≥ 1 year | 3. Plasma LH, FSH, PRL, E2; | | | | | | | | | | | | | P: 3.1-2.3=0.8 (26% red) | P: 10/20 (50%)
| | | | | | 3. Experiencing hot flashes | | | | | | | | | | | | | | p<0.05 | p<0.05
| | | | | | Exclusion: | | | | | | | | | | | | | | (note: interpreted from figure)
| | | | | | 1. HRT within 30 days
Stearns, 2003 | 165 | DB RCT | P | 6 weeks | Menopausal women (recruited from 17 US sites using newspaper ads, women's groups and professional referral networks) | Inclusion: | Daily hot flash composite score (frequency × severity; severity is 1–4); | 50/165 | 25/165 | NR | 12/165 | 12/165 | NR | 6 weeks prior | NR | Paroxetine 12.5 | Placebo | Paroxetine 12.5 = 3.3 | NR | Paroxetine 12.5 = 62.2% | NR | No significant difference in sleep, depression, anxiety, sexual interest, or disability for the groups | NR | Adjusted mean difference from baseline in sleep disturbance VAS: | Depression (BDI-I) | NR | NR | NR | NR | Sexual Interest GCS | NR | Global climacteric score improved | 12.5mg: 7/51 | 12.5mg: 4/51; | Headaches, dizziness, nausea, dyspnea, insomnia, constipation, lethargy, somnolence - none significant difference than placebo.
| | | | | | 1. Women over 18 years | Greene Climacteric Scale 21; | | | | | | | | | Paroxetine 25 | | Paroxetine 25 = 3.2 | | Paroxetine 25 = 64.6% | | | | 12.5mg: -1.38, | 12.5mg: -0.73; | | | | | 12.5mg: -0.02 | | Disability (SDS): | 25mg: 14/58 | 25mg: 8/58;
| | | | | | 2. Menopausal | sleep disturbance Visual Analogue Scale; | | | | | | | | | | | Placebo = 1.8 | | Placebo = 37.8% | | | | 25mg: -1.6 | 25mg: -0.006; | | | | | 25mg: -0.02 | | 12.5mg: 0.83 | P: 5/56 | P: 2/56
| | | | | | a. Amenorrhea ≥ 12 months | Beck anxiety inventory II; | | | | | | | | | | | (p=0.01) | | (p<0.03) | | | | P: -1.0 (not significant) | P: -0.33 (not significant); | | | | | P: -0.07 (not significant) | | 25mg: 0.01
| | | | | | b. 6 months amenorrhea with increased FSH and E2, or | Sheehan Disability Scale; | | | | | | | | | | | | | | | | | | Anxiety (BAI-II) | | | | | | | P: 0.06 (not significant)
| | | | | | c. Surgical menopause | Clinical Global Impression global improvement item. | | | | | | | | | | | | | | | | | | 12.5mg: -0.73
| | | | | | 3. 2–3 hot flashes/day or ≥ 14/week | | | | | | | | | | | | | | | | | | | 25mg: -1.23
| | | | | | Exclusion: | | | | | | | | | | | | | | | | | | | P: -1.11 (not significant)
| | | | | | 1. Recent psychotropic medication use
| | | | | | 2. Major depression or “significant mood or anxiety symptoms”
| | | | | | 3. HRT within 6 weeks
| | | | | | 4. Active cancer, current chemo or XRT
| | | | | | 5. Active psychiatric disorder
| | | | | | 6. Intolerance to SSRIs
| | | | | | 7. Substance dependence
Tarim, 2002 | 30 | DB RCT | P | 5 weeks | Consecutive patients presenting to outpatient menopause clinic of U in Turkey | Inclusion: | HF weekly severity score (frequency × severity 1–4) | NR | P: 4/9 | NR | NR | NR | NR | NR | NR | Meclopomide 150mg (M 150) or 300mg (M 300) | Placebo | NR | NR | “Weekly severity score” (frequency × severity 1–4) | Decrease of more than 50% in composite score: | NR | NR | No sleep disturbances reported by any group | NR | NR | NR | NR | NR | NR | NR | NR | 1 in P and 1 in M due to somnolence | 1 in P and 1 in M due to somnolence | Somnolence: 1 in each group; No dizziness, nausea, sleep disturbance
| | | | | | 1. Aged 35–55 years | | | M 150: 1/10 | | | | | | | | | | | Mean reduction: | M150: 8/10 (80%)
| | | | | | 2. Post menopausal with amenorrhea of 1 year | | | M 300: 4/11 | | | | | | | | | | | M150: 69.8% | M300: 5/11 (45%)
| | | | | | 3. FSH ≥ 40 | | | | | | | | | | | | | | M300: 35.0% | P: 2/9 (22%)
| | | | | | 4. At least 14 hot flashes a week | | | | | | | | | | | | | | P: 24.4%; | no p-value given
| | | | | | Exclusion: | | | | | | | | | | | | | | no p-value given
| | | | | | 1. CAD
| | | | | | 2. Any psychiatric disorders
Wesel, 1984 | 43 | DB RCT | HH | 20 days | Women attending a OB-GYN hospital in France | Inclusion: | HF frequency; HF severity (1–4); HF duration (1–6); | 0 | 0 | NR | 0/43 | NR | NR | > 30 days discontinue | NR | Veralipride 100mg/day (V) | CEE 1.25mg | V: 54.1-15.6 = 38.5 (71% reduction) | NR | # × intensity (1–4) | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | 3 in CEE group | NR | V: 2 mastodynia, 2 sedation, 4 headache, 3 nausea, 1 asthenia, 1 pelvic pain, 1 venous disorder | 3 stopped V TX due to AE; 4 stopped CEE due to AE.
| | | | | | 1. Aged 40–60 years | | | | | | | | | | | | CEE: 65.2-14.0 = 51.2 (79% reduction) | | V: 73-17=56 (77% red.) | | | | | | | | | | | | | | | CEE: 4 sedation
| | | | | | 2. Spontaneous amenorrhea ≥ 6 months | | | | | | | | | | | | Not significant | | CEE: 108-18=90 (83% red.)
| | | | | | Exclusion: | | | | | | | | | | | | | | Not significant
| | | | | | 1. Genital or mammary cancer
| | | | | | 2. Oophorectomy
| | | | | | 3. HRT within 30 days
Zichella, 1986 | 75 (5 groups of 15) | RCT | HH | 20 days | Postmenopausal women | Inclusion: | HF frequency (0–3); HF severity (0–3); | 0 | 0 | NR | NR | NR | NR | 0 | NR | Veralipride 100mg qd (V) | Bromocriptine 3.75; Liposom 40mg Imqd; domperidone 10mg qd | NR | NR | HF score: V: 3.5 ± 0.3 to 1.2 ± 0.1; P: 3.0 ± 0.2 to 2.4 ± 0.1 (p<0.05) | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | 0 | 0 | V: mastodynia 10; galactorhea 2. | Also looked at Lipisom, BCT, DOM not abstracted
| | | | | Recruiting information NR | 1. Physiologic menopause 1–2 years ago | | | | | | | | | | | | | | | | | | | | | | | | | | | | | 0 with placebo
| | | | | Aged 45–55 | 2. Severe vasomotor symptoms.
| | | | | | Exclusion:
| | | | | | 1. Endocrinologically active drugs within 6 months

Key/Abbreviations

AE = Adverse Effect

BAI-II = Beck Anxiety Inventory II

BCT = Bromocriptine

BDI = Beck Depression Inventory

BMI = Body mass index

CAD = Coronary artery disease

CEE= Conjugated equine estrogens

DB = Double blind

DHEA = Dehydroepiandrosterone

DOM = Domperidone

E2 = Estradiol

GCS = Greene Climacteric Scale

HF = Hot flash

HH = Head to head

HRT = Hormone replacement therapy

NR = Not reported

P = Placebo

RCT = Randomized controlled trial

SDS = Sheehan Disability Scale

SERMs = Selective Estrogen Receptor Modifiers

SF-36 = Modified Health Survey Short Form 36

SSRI = Selective Serotonin Reuptake Inhibitor

tx = Treatment

VAS = Visual Analogue Scale

Evidence table 6-7. Key Question 3F other drugs

| | | | | | | | Specific Characteristics of Population | | | | | | | Treatment | | | Main Outcomes
Study/Year | N | Type of Trial | Comparison | Length of Trial | Population | Inclusion/exclusion criteria | Measures | Hysterectomy +/- UO (#/n) | Hysterectomy BSO (#/n) | BSO (#/n) | Breast Cancer (#/n) | Use of SERMS (#/n) | Recent discontinuation of HRT (#/n) | High or Low BMI (#/n) | Main Drug type; dose; Regimen | Other Drugs type; dose; regimen | Hot Flashes (corrected) | Hot Flashes | Vaginal Dryness | Sleep | Mood | Somatic | Uterine Bleeding | Sexual Dysfunction | QoL | Other Outcomes | Withdrawals | Withdrawals due to AEs | Withdrawals due to Adverse Effects | Adverse Effects Reported | Comments | Overall findings
Andersen 1986 | 40 | DB RCT with cross-over | P | Unclear. | Women experiencing hot flushes in the climacteric. | NR | Patients recorded the number of hot flashes experienced daily (run-in week and last week of each treatment period). | NR | NR | NR | NR | None | 9/40 had previously been treated with hormones. States no treatment for hot flushes for 6 months prior to enrollment. 2 patients on topical estrogen dropped out. | NR | Alpha-Methyldopa 375 mg tab nightly, increased by 1 tab every 2 weeks as needed to maximum dose of 1,125 mg nightly | Placebo | Prior to crossover: | No significant difference between alpha-methyldopa and placebo in median number of hot flashes. | NR | NR | NR | NR | NR | NR | No significant difference in feeling of well-being (tendency is to feel worse on M). | No significant change in blood pressure or body weight. | 16/40 (14 dropouts and 2 excluded because flushing not severe enough) | 8/40 (4 M, 4P) drowsiness, dry mouth, headache, skin rash | “Substantially more” side effects with M. drowsiness, dry mouth, vertigo, and depression. | Distribution of symptoms appears quite different for drop-outs than for those completing the study. | Measures questionable. The authors conclude that M is efficacious for hot flashes. However, there was no difference in the number of hot flashes and overall it appears that participants tended to feel worse when on M. What is the significance of a visual analog score of the degree to which you are troubled by hot flashes? This measure and 62.5% participant preference for M is what drives the author's conclusion. | Question-able benefit for M with significant side effects noted.
| | | | 1 week run-in. | Mean age 51 years (range 46–60). | | Visual analogue scales used to denote trouble caused by hot flashes and general well-being. | | | | | | | | Dose adjusted every 2 weeks if needed to maximum dose then maintained for 4 weeks. | | No difference in median number between M and P (p > 0.05). Improved number of hot flashes for both P (12/19, pNR) and M (14/17, pNR). | Patients on alpha-methyldopa felt less troubled by hot flashes (p<0.05). | | | | | | | | No abnormal hematological measures.
| | | | 2 week wash-out then cross-over. Each treatment period could last up to 8 weeks total or until “troublesome side effects”. | Duration of symptoms 0.5–16 years (mean 4 years). | | Interviewed about side effects and which treatment they preferred. | | | | | | | | | | Summary statistics:
| | | | | Norway | | Labs: creatinine, AST, ALT, GGT< WBC, Hgb, Direct Coombs', blood pressure, weight. | | | | | | | | | | M group felt less troubled by hot flashes than P (p<0.05).
| | | | | | | | | | | | | | | | | General well-being was slightly disfavors M (p NR).
Bergmans 1987 | 71 | DB RCT (meds were randomized) | P | 8 weeks (4 week open study followed) | Women reporting hot flashes and sweats. | Description of women included: | Body weight, blood pressure. | NR | Ovariectomized patients excluded. | Excluded | NR | NR | NR | NR | Bellergal Retard (BR) 1 tablet twice daily | Placebo | Decrease in mean number for both BR and P. No significant difference between BR and P (p≤0.001) at week 12. | Similar number of baseline hot flashes, mean 14.48/day for BR and 14.55/day for P. | NR | Insomnia was improved for both BR (p=0.002) and P (p=0.03). | Statistically significant decreases in nervousness and hyperirritability were noted for BR and P. No significant between group differences. | Statistically significant decrease in headache, paresthesia, and dizziness noted for BR. No significant difference between BR and P. | NR | No change in loss of libido with BR, but improved with P (p=0.039). Between group differences not significant. | NR | Overall efficacy assessed by participant and investigator at the end of the double blind and open study. BR was assessed as excellent or good in 51% of cases, placebo 21%, the difference was statistically significant in favor of BR. | 33/71 | 10/33 BR group | 19/33 in BR group complained of adverse reactions. | Complaints included dry mouth, dizziness, sleepiness, headache, and nausea. | Early in the study some benefit of BR over P noted but effect gone by the end of the 8 week trial. | Bellergal was not more effective than placebo.
| | | | | No mean age reported. | All reported hot flushes and sweats with ≥ 1 of several other somatic complaints. | Symptoms rated as absent, slight, moderate, or severe. | | | | | | | | BR = 0.6 mg ergotamine, | | Decrease in severity for both BR and P. No significant difference between BR and P at week 12. | The mean number of hot flushes decreased in both BR and P. The only significant difference between BR and P was noted at week 2 (p<=0.001). | | Statistically significant differences between BR and P for insomnia were only seen at weeks 2 and 4. (BR superior). | | | | | | | 5 dropped out for personal reasons prior to starting treatment, | 6/33 P group | 18/33 in P group complained of adverse reactions.
| | | | | Patients from 3 general teaching hospitals. | Exclusion: | Efficacy rated by participant and investigator as poor, fair, acceptable, good or excellent. | | | | | | | | 40 mg Phenobarbital, 0.2 mg levorotatory alkaloids | | Decrease in sweating for both BR and P. No significant difference between BR and P (p≤0.001) at week 12. | Hot flush severity decreased in both BR and P. The only significant difference between BR and P was noted at week 2 (p<=0.008). | | | | | | | | | 12 dropped out from BR and 16 from P.
| | | | | Netherlands. | ovariectomized patients, and several medical conditions | | | | | | | | | | | | Sweating decreased in both BR and P. The only significant difference between BR and P was noted at week 2 (p<=0.04).
Bolli 1975 | 12 | DB RCT with cross-over | P | 2 trials 4 weeks each; | Hypertensive women with menopausal flushing. | NR | Daily number of hot flushes, changes in the severity and duration of hot flushes (more, same, less), severity of concomitant perspiration. | NR | NR | NR | NR | NR | None had used HRT. | NR | C 0.0375 mg tab twice daily for first trial | Placebo | Prior to crossover: | Appears that data presented compares patients' Clonidine trials to their placebo trials. | NR | NR | NR | NR | NR | NR | NR | No change in blood pressure with C. | None | None | None | Nausea in 1 patient on C. | Data not reported clearly. Summary states significant difference between C and P at higher dose C (150 mcg), but discussions states results of this trial did not reach statistical significance. | No difference between clonidine and placebo.
| | | | 2 weeks C or P then cross-over (n=12); | Duration of flushing was 1–16 months (mean 4 months). | | Side effects. | | | | | | | | C 0.075 mg tab twice daily for second trial | | NR | No significant difference in mean # of hot flashes between P and C in trial one or two, although both showed significant decrease from baseline.
| | | | 2 weeks higher dose C or P then cross-over (n=8) | Mean age 51 years. | | | | | | | | | | | | Summary statistics:
| | | | | Dunedin Hypertension Clinic, New Zealand | | | | | | | | | | | | Results were the same for Trials 1 and 2.
| | | | | | | | | | | | | | | | | No significant difference in mean number between C and P.
| | | | | | | | | | | | | | | | | No significant difference between C and P in subjective measures.
Carranza-Lira 2001 | 75 (5 groups 15 each) | SB RCT | HH | 3 months | Healthy postmenopausal | NR | Number of hot flashes per day, intensity of hot flashes on visual scale 0–10, duration in minutes, insomnia and sweating (absent or present). | NR | NR | NR | NR | NR | None had used HRT or other treatment for their symptoms. | NR | C 0.10 mg tab every 12 hours | CEE 0.0625 mg tab daily (hysterectomized patients only) propranolol 20 mg tab every 12 hours veralipride 100 mg tab daily from Monday-Friday Placebo tab every 12 hours | | Hot flash frequency decreased in the CEE and C groups compared to the propranolol, veralipride and placebo groups. | NR | Insomnia presence was greater in the propranolol group when compared to CEE, clonidine and veralipride. Frequency of presentation of insomnia was greater in propranolol than in CEE and C. | NR | NR | NR | NR | NR | NR | 4/75 (1 CEE, 2 propranolol, 1 veralipride) | 2/75 (1 CEE and 1 veralipride for drug intolerance) | | NR | Method of randomization not disclosed. States patients with contraindication to CEE were randomly distributed to the other 4 four groups. No statement that the patients were blinded.
| | | | | (≥ 1–5 years) women with vasomotor symptoms and insomnia. | | | | | | | | | | | | | Hot flash intensity and duration in CEE users decreased in comparison to the other four groups. | | | | | | | | | | | | | Limited information given. Summary table is essentially uninterpretable.
| | | | | No hormones or other treatment for hot flushes, FSH and estradiol in the postmenopausal range. | | | | | | | | | | | | | Hot flash intensity was lower in C compared to propranolol and P.
| | | | | Mean age not reported. | | | | | | | | | | | | | The presence of sweating was lower in CEE and C compared to propranolol and P.
| | | | | Mexico
Clayden 1974 | 100 | DB RCT with cross-over | P | 9 weeks (1 week of no treatment to assess baseline then 4 weeks C or P then cross-over) | Women with menopausal flushing of sufficient severity to warrant treatment. | Inclusion: | Patient diary recording each attack of flushing. | NR | NR | NR | NR | NR | States all previous medication for flushing was stopped 2 weeks before entry to trial. | Mean weight 64.6 kg (44.4 to 86.9 kg) | C 0.025 mg tabs 1 twice daily, increased to maximum of 3 tabs twice daily depending on effect or presence of side effects. | Placebo | Prior to crossover: | Appears that data presented compares patients' Clonidine trials to their placebo trials, rather than doing the two trials separately. | NR | NR | NR | NR | NR | NR | NR | Blood pressure and pulse. No significant changes over the study period (p NR). | 14 excluded for several reasons (Table 1). 4/14 were for side effects | 3C,1P | | 56 participants reported side effects. 34 while on C, 36 while on P. | No stats provided prior to cross-over. | No significant difference between C and P prior to crossover. After cross-over, C was more effective than P in reducing number of hot flashes.
| | | | | Duration of flushing ranged from two weeks to 23 years. | 1. No other complicating illness | Nine visits throughout trial. At each visit, questions were asked about frequency, severity, and duration of attacks. 5 point scale (“much more” to “much less”). | | | | | | | | | | No difference in mean change from baseline number to week 4 between C and P (p=0.7)*. | Reduction in number of hot flashes was greater during clonidine period than placebo period (C first p<=0.05, P first p<=0.001). | | | | | | | | | | | | Effects nonspecific (Table V) and “well distributed” between C and P except dry mouth which was more frequent on C.
| | | | | 42 received C first | | Side effects question “Any problem with the tablets?” | | | | | | | | | | Summary statistics: | During first treatment period, more patients on C than P improved in scores of frequency, severity, and duration (p values listed by week). During the second treatment period, there was no difference between C and P.
| | | | | | | Blood pressure/pulse. | | | | | | | | | | Greater reduction in number while on C (C first p<=0.05, P first p<=0.001). | Greater placebo response noted in those with flushing for less than 1 year.
| | | | | | | | | | | | | | | | | Compared to their own P trial, the number of patients who improved on scores of frequency, severity, and duration was greater for C first only (p=0.1, p=0.05, P=0.01).
| | | | | | | | | | | | | | | | | P response greater in those with flushing for <1 year (p NR).
Edington 1980 | 93 | DB RCT cross-over (4 weeks C or P then cross) | P | 16 weeks (4 phases each 4 weeks, first 2 trials conducted by the same investigator) | Women with dilatation of blood vessels in all areas of the skin and profuse sweating. Mean age 47 years (range 27–71). | Inclusion: | Patient diary of the time, extent, severity and duration of flushing, and side effects. | NR | NR | 10/66 | NR | NR | NR | NR | C 0.05 mg twice daily | Placebo | Prior to crossover: | Mean number of flushing attacks (averaged over all 4 trials) was significantly lower with C therapy (p<0.05). | NR | NR | NR | NR | NR | NR | NR | Blood pressure and pulse. No significant changes over the study period (p NR). | 27/93 | 6/93 | 2/93 on P withdrew (1 headache, 1 double vision), 4/93 on clonidine withdrew (1 respiratory infection, 1 depression, 2 headaches, 1 nausea) | Headache 12C, 10P | Study done in 4 trials of 4 weeks each. Trial 3 was a single-blinded placebo only trial. “The findings were averaged” from the 4 trials. | Clonidine was more effective than placebo. However, statistical method is questionable.
| | | | | | 1. Dilatation of blood vessels in all areas of the skin and profuse sweating. | Blood pressure, pulse. | | | | | | | | | | NR | | | | | | | | | | 6 due to symptoms, 1 nonmedical, 8 lost to follow up, 12 patients did not keep proper diaries | | | Dry mouth 11C, 4P | I don't think this study can be used.
| | | | | | 2. ≥ 30 attacks per week | | | | | | | | | | | Summary statistics: | | | | | | | | | | | | | Insomnia 8C,4P
| | | | | | 3. Symptoms for ≥ 3 months but not > 12 months. | | | | | | | | | | | Mean number of flushing attacks (averaged over all 4 trials) was significantly lower with C therapy (p<0.05). | | | | | | | | | | | | | Fatigue 3C, 5P
| | | | | | Exclusion: | | | | | | | | | | | Subjective assessment of frequency, severity, and duration was noted as much less or less in (50–89%) of all participants after each crossover. | | | | | | | | | | | | | Nausea 2C, 3P
| | | | | | 1. Other interfering illness | | | | | | | | | | | | | | | | | | | | | | | | Other 30C, 28P
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | (p NR)
Gerdes 1982 | 38 (15/38 defaulted) | DB RCT | HH | 20 weeks | Menopausal women with symptoms. | Inclusion: | South African Personality Questionnaire, Leckie-Withers Test of Liability to Depressive Illness, Bem Sex Role Inventory, Items from Uken Motherliness Test, Mini-Biography Questionnaire, subjective assessment concerning pretreatment to post treatment change on 5 point scale. | NR | NR | NR | Excluded | NR | NR | NR | Opposed Estrogen group: | C group: | Reported in Sonnendecker 1980 | Reported in Sonnendecker 1980 | NR | NR | Significant decrease in MBQ depression score for CEE compared to C (p<0.05). A significant decrease in indirect and direct depression, MBQ depression and anxiety scores was seen in CEE but not C (p<0.05). | NR | NR | NR | NR | | 38 women entered the study but 15 defaulted (7 from estrogen and 8 from clonidine group) leaving only 23 remaining. | NR | NR | NR | 10 asymptomatic postmenopausal controls (not included in n) | Only estrogen/progesterone combination was associated with improvement in measures of depression and anxiety (p<0.05).
| There were also 10 asymptomatic controls | | | | No mean age noted. | 1. Elevated FSH (>18mIU/ml) and LH (> 15mIU/ml) | | | | | | | | | CEE 1.25 mg daily for 21 days + medrogestone 5mg daily from day 16 to 21, then 7 days off, + placebo C 2 tab twice daily for 28 days | placebo CEE daily 21 days + placebo medrogestone days 16–21, then 7 days off, + C 0.025 mg 2 tab twice daily for 28 days
| | | | | Climacteric Clinic Johannesburg Hospital | 2. Hot flushes
| | | | | | Exclusion:
| | | | | | 1. Several medical conditions
Guttuso 2003 | 59 (246 screened 187 were ineligible) | DB RCT | P | 12 weeks (followed by a 5 week open-label treatment phase) | Postmenopausal women with hot flashes. | Inclusion: | 4 patient clinic visits, bimonthly phone calls and patient diaries. | NR | NR | 8/30 G | NR | 1/30 G | States could not be on HRT, leuprolide, or tamoxifen for 2 months prior to study. | BMI NR only weight. | G 300 mg tab 3 times daily (900 mg daily). | Placebo | Statistically significant decrease between G and P in frequency at weeks 4 (p=0.03) and 12 (p=0.02) and composite score at weeks 4 (p=0.01) and 12 (p=0.01). | Statistically significant decrease between G and P in hot flash frequency at weeks 4 (p=0.03) and 12 (p=0.02) and composite score at weeks 4 (p=0.01) and 12 (p=0.01). | NR | Pittsburgh Sleep Quality Index improved with G at week 4 (p=0.01) but not at week 12 (p=0.09). | No significant difference between G and P in Profile of Mood States. | NR | Onset of menses in 3 P and 2 G. | NR | No significant difference between G and P in Short Form-36 Health Survey. | No significant difference between G and P in Patient Global Impression of Change Scale. Several lab studies done. Significant differences were seen in albumin, total protein, total bilirubin, blood urea nitrogen, and platelets. | 5 withdrawals from double-blind study, 4 withdrawals from open-label study | 4/30 in G (dizziness, rash, heart palpitations, and peripheral edema) | | Somnolence, dizziness, rash and peripheral edema were reported in G but not P. | A few patients were taking raloxifene or antidepressants during the study. | G was more effective than P throughout the study.
| | | | | Mean age 52.7 G, 53 P. | 1. Average ≥ 7 hot flashes/day accompanied by sweating | Serum FSH and estradiol, LH, CBC with differential, platelets, chemistry-14 panel, phosphate. Vitals signs, height, weight. | | | 6/29 P | | 5/29 P | | Mean weight in pounds 158.7 G and 152.8 P. | Participants allowed to decrease dose if side effects. | | Results not altered by adjusting for baseline group differences in duration of hot flashes and Total Mood Disturbance scores. | Results not altered by adjusting for baseline group differences in duration of hot flashes and Total Mood Disturbance scores. | | | | | | | | | | 1/29 in P (diarrhea) | | 15 (50%) in G and 8 (27.6%) in P reported at least one adverse event. | 81.5% of patients requested to continue G after completion of the open-label study.
| | | | | Randomization was stratified by surgical menopause status. | 2. Amenorrhea for > 12 months or 6–12 months with FSH>40 mIU/mL and estradiol<20 pg/mL or status post bilateral oophorectomy for 2 months. | Hot flash diary of frequency and severity (scale 1–7) symptoms noted at occurrence. Composite hot flash score, | | | | | | | | In the open label trial the dose of G could be increased to maximum of 2700 mg/day. | | | | | | | | | | | | | Two withdrawals for AE's from the open- label study (dizziness, peripheral edema).
| | | | | Recruited by advertisement. | Exclusion: | Pittsburgh Sleep Quality Index, Profile of Mood States, Short Form-36 Health Survey, Patient Global Impression of Change Scale. Adverse events.
| | | | | New York | multiple
Hammond 1984 | 10 | DB RCT with cross-over | P | 14 weeks (1 week baseline, 4 weeks study drug, 1 week baseline, 4 weeks alternate medication) | Menopausal women with vasomotor symptoms. | All women had ≥ 30 vasomotor flushes/week and serum FSH ≥ 40 mIU/ml. | Diary of number of vasomotor flushes and objective 5 hour study periods of continuous temperature monitoring and sampling for serum LH. | NR | NR | NR | NR | NR | States no HRT used for 6 months prior to study. | NR | Methyldopa 250 mg tab twice daily, increased after 1 week to 3 times daily | Placebo | Prior to crossover: | In the first study period (i.e. before crossover) there was no significant difference between M and P in mean decrease of hot flashes. | NR | NR | NR | NR | NR | NR | NR | Statistically significant decrease in the mean number of LH peaks per hour during M therapy (p<=0.05). | 1/10 | 1/10 | No side effects noted for P. | “Significant side effects occurred in 6/10 patients receiving methyldopa.” | Authors conclude that “because of significant side effects and minimal symptomatic improvement, M is not likely to be an acceptable therapy.” | No significant effect of M. Significant side effects.
| | | | | Mean age 45.6 years (range 36–54). | States women were “normotensive, in good health, and had no medical contraindication to M.” | | | | | | | | | | | Both M and P resulted in decrease in hot flashes (pNR). No significant difference in mean decrease in number between M and P. | In the second study period there was a significant decrease in vasomotor flushes for M but not P (p<=0.02). | | | | | | | | | | | 1 patient on M developed a lupus-like rash.
| | | | | 7 natural menopause, 3 surgical menopause (6 months to 6 years post menopause). | | | | | | | | | | | | Summary statistics: | Objective measures of hot flashes by skin temperature changes did not show any significant difference in either treatment phase. | | | | | | | | | | | Fatigue, weakness, dizziness and nausea were noted by 50% of patients.
| | | | | North Carolina | | | | | | | | | | | | Compared to baseline, significant decrease in number for M (p<=0.02). | | | | | | | | | | | | Bradycardia 2 patients, orthostatic hypotension 1 patient.
| | | | | | | | | | | | | | | | | No significant difference in objective measures of skin temperature.
Lindsay 1978 | 100 | DB RCT with cross-over | P | 13 weeks (6 weeks P or C then cross-over, 1 week free in between) | Menopausal women with symptoms. States all experienced “natural” menopause. | NR | No diaries. | NR | NR | NR | NR | NR | # NR, states all treatment of symptoms stopped at least 4 weeks before entry | NR | 0.025 mg tab, 2 tablets twice daily, increased to 2 tabs three times daily after 1 week if needed | Placebo | Prior to crossover: | Blatt Menopausal Index. Significant decrease in first 6 weeks for C (p<0.05) and P (p<0.05). | NR | NR | Kellner and Sheffield initial scores higher in women with menopausal symptoms for >1 year (p<0.01) compared to those with symptoms for < 1 year | NR | NR | NR | NR | NR | 62/100 | 2 | 2 withdrawals for nausea, dry mouth and insomnia on C | 2 reported nocturia on C, 1 reported nausea on P | 100 initially to be included. States only 41 completed treatment in the trial. Three additional withdrawals noted, one did not return after initial assessment, 2 withdrew because of side effects. Results are reported for the remaining 38. | No difference between clonidine and placebo.
| | | | | Mean duration of symptoms 1.6 years (1 month-5 years). | | Interviews at weeks 4, 7, and 12. | | | | | | | | | | Significant decrease in Blatt score for C (p<0.05) and P (p<0.05) and in flush score for C (p<0.005) and P (p<0.001). | No difference between C and P.
| | | | | Mean age 46.4 years (35–60) | | Blatt Menopausal Index (4 points scale). | | | | | | | | | | No significant difference between C and P on Blatt or flush score. | “Flushing attacks”.
| | | | | Patients selected from referrals on a random basis. Glasgow. | | Flushing attacks assessed separately (4 point scale). | | | | | | | | | | Summary statistics: | Significant decrease in first 6 weeks for C (p<0.005) and P (p<0.001)
| | | | | | | Kellner and Sheffield rating scale for psychological symptoms. | | | | | | | | | | After crossover, no significant improvement in scores for either C or P, no difference between C or P. | No difference between C and P.
Nagamani 1987 | 30 | DB RCT | P | 10 weeks (2 weeks to assess baseline, 8 weeks C or P) | Symptomatic women (6 spontaneous menopause, 24 surgical). | Exclusion: | Patient diary noting occurrence of hot flashes and side effects of treatment. | NR | NR | 24/30 | NR | NR | NR, states no treatment for symptoms for at least 30 days before inclusion | NR | C Transdermal 0.1 mg/day, patch changed weekly | Placebo | No significant difference between C and P in mean change at weeks 4 (p=0.28)* and 8 (p=0.25)*. | Mean number of hot flashes significantly decreased from baseline at each weekly assessment (p<0.001–0.03) for C and only at weeks 5 (p<0.05), 6 (p< 0.05), and 8 (p<0.04) for P. (Results for direct comparison of C and P NR, graphic display only.) | NR | NR | NR | NR | NR | NR | NR | LH levels measured in 2 participants without C and after 2 weeks of C. No change in LH pulsatile secretion noted with C. | 1/30 (excluded from analysis, dropped out after 2 weeks of treatment) | None | None | Skin reactions (erythema and/or itching) 4C, 3 P (no dryness of mouth or dizziness reported) | How useful are the results of limited subjective measures? | C was more effective than P in subjective measures but not for mean decrease in number of hot flashes.
| | | | | Mean age 41 (range 25–58) | 1. Previous treatment with oral C, | At visit, patients were questioned about frequency, severity (decrease or same), and duration (decrease or same) of hot flashes. | | | | | | | | | | Significant decrease in mean number for C (p=0.002) and P (p=0.04) at week 8. | Subjective comparison of frequency (decrease or same) (p<0.04), severity (p<0.04), and duration (p<0.03) of hot flushes significantly decreased in the clonidine compared to the P groups. | | | | | | | | No significant changes in blood pressure and pulse.
| | | | | Texas | 2. Other medical exclusions listed | Blood pressure, pulse, LH levels. | | | | | | | | | | Proportion of women reporting a decrease in subjective frequency (p<0.04), severity (p<0.04), and duration (p<0.03) was greater for C than P.
Nappi 1991 | 35 (5 groups of 7 each) | RCT | HH | 4 weeks | Menstruating women undergoing TAH-BSO for benign indications. | Not more explicitly specified. | Plasma LH and FSH. | None | 35/35 | 35/35 | NR | NR | NR | BMI 23.1 ± 1.5 | C 0.075 mg tab twice daily | Sodium Valproate 200 mg tab twice daily | Hot flash frequency and intensity were lower in the estradiol, clonidine, and Lisuride treated groups compared to P (p<0.01). | Hot flash frequency and intensity were lower in the estradiol, clonidine, and Lisuride treated groups compared to P (p<0.01). | NR | NR | NR | NR | NR | NR | NR | FSH, LH levels | NR | NR | NR | NR | All treatments started on the first day after surgery. | Estrogen, clonidine, and Lisuride decreased hot flash frequency and intensity compared to placebo.
| | | | | Mean age 43.5 years (range 30–50) | | Patient diaries of frequency (0, <5/day, >5–<10/day, >10/day scored 0–3) and intensity of hot flushes (0, mild, moderate, severe scored 0–3). | | | | | | | | | Lisuride 0.2 mg tab twice daily | | | | | | | | | | | | | | | Method of randomization not disclosed. No report of blinding. One small paragraph on hot flash results, more time spent discussing LH/FSH results.
| | | | | | | | | | | | | | | | Transdermal 17B estradiol 0.050 mg daily
| | | | | | | | | | | | | | | | placebo
Nesheim 1981 | 40 | DB RCT with cross-over | P | Not clearly stated but inferred; 1 week baseline; 30 day M or P then 14 day washout then cross-over | Women with menopausal hot flushes. | Exclusion: | Patient recorded number of hot flashes per day. | NR | NR | NR | NR | NR | Participants were not allowed to take estrogen for 4 weeks before the study. | NR | l-methyldopa 250 mg tab twice daily increased if needed to maximum of 2 tabs twice daily | Placebo | Prior to crossover: | Median number of hot flashes per week prior to medication was 58 (14–315). | NR | NR | NR | NR | NR | NR | NR | No significant change in blood pressure. | 12/40 (various reasons reported) | 2/40 (specific effects not stated) | | Tiredness 15 M, 3 P | Some results appeared to be combined across both treatment periods (i.e. patients compared to themselves).
| | | | | Mean age or age range NR. | 1. Use of antihypertensive, antidepressants, or sedating drugs | Patients were contacted weekly by phone and asked to use a VAS to record degree they were troubled by hot flashes. | | | | | | | | | | NR | 16 participants received M first, 12 P first. | | | | | | | | | 2 additional patients were unable to keep record of their hot flashes, only VAS data available | | | Dry mouth 10 M, 7P
| | | | | Patients referred by General Practitioners in Akershus County, Norway. | | Blood pressure. | | | | | | | | | | Summary statistics: | Median number of hot flashes for M first was 42 (14–140 and for P first was 70 (28–315). (Not reported if this was significantly different at baseline.) | | | | | | | | | | | | Slight edema 3 M
| | | | | | | | | | | | | | | | | Median reduction in number 38% P (pNS), 65% M (p<0.05). | Hot flash frequency was reduced by both M and P, favoring M in both the first phase (p=0.06) and the second phase (p =0.01) Combined results from both phases favors M (p=0.004). | | | | | | | | | | | | Diarrhea 1 M, 1P
| | | | | | | | | | | | | | | | | Between groups M superior to P (p=0.06 M first, p=0.01 P first). | Median VAS score prior to treatment 8.4 cm (2.9–10) | | | | | | | | | | | | Exanthem and Arthralgia 1 M
| | | | | | | | | | | | | | | | | 22 M, 15 P improved. Overall, greater reduction in number for M (p=0.004) | Improvement in score was greater with M than P (p=0.002) (patients compared to themselves). Median improvement 77% with M, 30% with P.
| | | | | | | | | | | | | | | | | Median improvement on VAS score 5 M, 2.4 P (p=0.002).
| | | | | | | | | | | | | | | | | Median improvement 77% M, 30% P.
Salmi 1979 | 40 | DB RCT cross-over (not true RCT, medication packs made in random order) | P each patient is her own control | 12 weeks, cross-over at 6 weeks | Women with menopausal symptoms. 10 still menstruating, 18 spontaneous menopause. | Inclusion: | Patient records and visits (3). | 2/37 | 7/37 | NR | 1 of the patients was excluded at the beginning because of cancer in a mammary node. | NR | NR | NR | 0.025 mg tab twice daily, increased every 2 weeks by 1 tab twice daily, if needed, to max 0.075 mg twice daily | No concurrent use of HRT, psychopharmaceutics or antihypertensive. | Prior to crossover: | Sweating and hot flushes (day and night). | NR | Insomnia. No statistical difference (p NR) between C and P. | Disturbances of depression and anxiety states. | NR | NR | NR | NR | No changes in blood pressure and pulse during the trial. | 3 were excluded from initial 40, unclear if this was prior to randomization. 1 for cancerous node, 1 for psychiatric treatment, 1 for interruption of medication. | none | None | No significant differences between C and P in side effect occurrence. (Various side effects listed Table 1) | Serum aspartate amniotransferase and cholesterol readings were done in all and there were no elevated values noted. | No difference between clonidine and placebo.
| | | | | Mean age 50.5 years (range 41–57). | 1. Hot flushes, sweating, menopausal symptoms | Frequency of sweating episodes/hot flushes (none, <5, >5, >10) | | | | | | | | | | No significant difference between C (14/20) and P (16/17) in number asymptomatic at 6 weeks (p=0.0975)*. | No statistical difference (p NR) between C and P. | | | No statistical difference (p NR) between C and P.
| | | | | Mean duration of symptoms 21.5 months (range 1–131 months). | | Incidence of insomnia and depression, occurrence of possible anxiety states (none, less than before the medication, the same as before, more than before) | | | | | | | | | | Summary statistics:
| | | | | Outpatients from Department of Ob/Gyn, University Central Hospital, Finland. | | Blood pressure, pulse, AST, cholesterol. | | | | | | | | | | No significant difference between C and P in alleviation of symptoms (p NR).
| | | | | | | Side effects.
Sonnendecker 1980 | 38 (15/38 defaulted) | DB RCT | HH | 20 weeks | Menopausal women with symptoms. | Inclusion: | Mammography, hot flushes in number per day, FSH, LH, 17B-estradiol, progesterone, prolactin. | NR | NR | NR | Excluded | NR | NR | NR | Opposed Estrogen group: | C group: | Mean change in number from pre- to post-trial follow up decreased significantly with CEE (p<0.05) but not C. | Number of hot flashes experienced daily was decreased significantly in the estrogen group (p<0.05) but not in the clonidine group. | NR | NR | NR | NR | NR | NR | NR | FSH, LH, and estradiol, progesterone and prolactin levels were assessed. Mammography was performed. | 38 women entered the study but 15 defaulted (7 from estrogen and 8 from clonidine group) leaving only 23 remaining. | NR | NR | NR | | Only estrogen/progesterone combination was effective for decreasing hot flashes.
| | | | | No mean age noted. | 1. Elevated FSH (>18mIU/ml) and LH (> 15mIU/ml) | | | | | | | | | CEE 1.25 mg daily for 21 days + medrogestone 5mg daily from day 16 to 21, then 7 days off, + placebo C 2 tab twice daily for 28 days | placebo CEE daily 21 days + placebo medrogestone days 16–21, then 7 days off, + C 0.025 mg 2 tab twice daily for 28 days | No significant difference in mean change between CEE and C
| | | | | Climacteric Clinic Johannesburg Hospital | 2. Hot flushes
| | | | | | Exclusion:
| | | | | | 1. Several medical conditions
Wren 1986 | 19 | DB RCT with cross-over | P | 10 weeks (2 weeks placebo, then 4 weeks C or P then cross-over) | Postmenopausal women with symptoms (all spontaneous menopause). | Inclusion: | Frequency, severity, and duration of vasovagal symptoms. Patient diaries of number of flushes/sweats, insomnia, anxiety, libido, headache, irritability, and depression. | Excluded | Excluded | NR | NR | NR | Excluded if previous use C, antihypertensive, HRT or sedative, tranquilizer, or hypnotic drugs | NR | C 0.025 mg tabs 2 twice daily | Placebo | Prior to crossover: | Crossover design, each patient is her own control. | No change with C or P | No change in insomnia or tiredness with C | No change in anxiety, panic, or irritability with C | NR | NR | NR | NR | No change in blood pressure or gonadotropin levels | 5/19 (not included in analysis, states withdrawal due to frustration with lack of benefit) | None | No adverse affects reported. | NR | No p values reported in this paper | No difference between clonidine and placebo.
| | | | | Mean age 50.6 (range 46–56) | 1. Spontaneous menopause | Exam and biochemical investigation every 2 weeks. | | | | | | | | | | NR | No significant difference in mean # of hot flashes. (p NR) | | | | | | | | | | | | | | Statistical method is question-able.
| | | | | Menopause clinic at the royal Hospital for Women, New South Wales | 2. Symptoms ≥ 3 months but not > 12 months. | | | | | | | | | | | Summary statistics:
| | | | | | Exclusion: | | | | | | | | | | | No significant difference in mean number between C and P (p NR).
| | | | | | 1. Hysterectomy | | | | | | | | | | | No data reported for severity and duration.
| | | | | | 2. Previous C or antihypertensive use

*p value not reported by the authors

AE = Adverse Effect

BMI = Body mass index

BR = Bellergal Retard

BSO = Bilateral Salpingo Oophorectomy

C = Clonidine

CEE = Conjugated Equine Estrogens

DB = Double-blind

ECOG = Eastern Cooperative Oncology Group Scale

G = Gabapentin

HH = Head to head

HRT = Hormone replacement therapy

M = Methyldopa

MBQ = Mini-Biography Questionnaire

NR = Not reported

P = Placebo

QoL = Quality of Life

RCT = Randomized Controlled Trial

SERMs = Selective Estrogen Receptor Modifiers

TAH = Total abdominal hysterectomy

UO = Unilateral Oophorectomy

VAS = Visual Analogue Scale

Evidence table 6-8. Key Question 3G-I complementary and alternative therapies

| | | | | | | | Specific Characteristics of Population | | | | | | | | Treatment | | Main Outcomes
Study/Year | N | Type of Trial | Comparison | Length of Trial | Population | Inclusion/Exclusion Criteria | Measures Used | Hysterectomy (#/n) | Bilateral Oophorectomy (#/n) | Premature Ovarian Failure (#/n) | Breast Cancer (#/n) | Use of SERMS (#/n) | Behavior or Lifestyle Factors (#/n) | Recent discontinuation of HRT (#/n) | High or Low BMI (#/n) | Main Drug type; dose; regimen | Other Drugs type; dose; regimen | Hot Flashes | Vaginal Dryness | Sleep | Mood | Cognitive | Somatic | Urinary | Uterine Bleeding | Sexual Dysfunction | Quality of Life | Other Outcomes | Withdrawals | Withdrawals due to AEs | Adverse Effects | NCCAM Category | Comments
Aiello, 2004 | 173 | RCT | HH | 12 months | Postmenopausal women recruited from the greater Seattle area (50–75 years of age) through mass mailings and media placements. | Inclusion: | Adherance to exercise via daily activity logs, food frequency questionnaire, information on menopause symptoms and their severity was collected at 0,3,6,9, and 12 months with a self-administered questionnaire, which was a modified version of a questionnaire used by the Women's Health Initiative, DEXA was conducted at baseline and 12 months for leanness | 13–18% | NR | NR | NR | NR | NR | 35–38% had taken in the remote past | Average was 30.5 and 30.6 in each group | 45 minutes of moderate-intensity exercise, 5 days/week for 12 months | Control was invitation to attend 45 minute weekly stretching session for 12 months | No change in frequency over the year | NR | No change in either group over the year | No change in depressive feelings in either group over the year (only 13% had a baseline) | No change in either group over the year; when analyzed by time since menopause those within 5 years of menopause had a significant decrease in memory problems in the exercise group compared to the controls (OR at 6 mo=0.2; 95% CI, 0.08–0.6). This was sustained at 9 and 12 months. | NR | NR | NR | NR | NR | When analyzing the subset of moderate/severe menopausal symptoms (n=11 exercisers, 10 controls), a significant decrease in hot flashes was seen over the year in the control group (p=0.02 but not in the exercisers) | 6/87 in the exercise group; 2/86 controls | None | None | Mind-body | Only RCT looking at exercise
| | | | | Average age 60.7 and 60.6 SD (6.6 and 6.7years). Approximately 60% had some menopausal symptoms. | 1. Sedentary at baseline (<60 min/week of moderate-to vigorous exercise)
| | | | | | 2. BMI>25.0 or over 24.0 with body fat>33%
| | | | | | Exclusion:
| | | | | | 1. Taking HRT
| | | | | | 2. Smoker
Albertazzi, 1998 &1999 | 104 | RCT | P | 12 weeks | Mean age 53, range of 48–61. | Inclusion: | Daily diary; Kupperman Index | NR | NR | NR | NR | Allowed | NR | Had to be off at least 6 weeks | Mean was 25.9 for both groups with range from 18–36 | Casein 60 grams daily for 12 weeks | Soy powder (Supro Brand Protein Technologies, St. Louis, MO) 60 grams/day; this contained 76 mg of isoflavones (aglycone units) | Hot flash reduction was seen in both group (43.6 % reduction in soy group compared with 31.3% reduction in placebo group). Soy group had greater reduction than casein group at 12 weeks (p<0.01) | Vaginal maturation indices did not increase in the soy group, but did significantly increase in the casein group | NR | NR | NR | NR | NR | NR | NR | NR | Kupperman index values as a whole did ‘not change’ | 25/51; 11 in the soy group and 14 in the casein group | 14 patients, 7 in each group dropped due to gastrointestinal side effects; lack of efficacy caused 3 patients in the casein group and 1 person in the soy group to withdraw | Gastrointestinal - constipation 48% | Biologically based therapies
| | | | | Women postmenopausal requesting treatment for severe hot flushes. | 1. ≥ 6 months since the last menstrual period or ≥ 6 weeks since bilateral oophorectomy was performed
| | | | | | 2. Seven moderate to severe hot flushes, including night sweats/24 hours during at least the last 2 weeks of the 4 week prestudy period
| | | | | | 3. FSH>50 and estradiol <35
| | | | | | Exclusion:
| | | | | | 1. HRT or any other drug for the treatment of climacteric symptoms, such as Vitamin E, clonidine, veralipride.
Anarte, 1998 | 73 | RCT | HH | 6 months | 45–55 year old postmenopausal women with less than 3 years evolution, no previous treatment; all attending a Menopause Unit in Southern Spain | None reported other than population definition except that patients in whom hormonal treatment was contraindicated were excluded | Kupperman Index, plus the emotional alternation, anxiety and depression scales of the Granada Gynecological Questionnair of Salvatierra et al. | NR | NR | NR | Those with contraindication to HRT excluded | NR | NR | No previous | NR | Transdermal estrogen with cyclical progesterone | HRT plus Psychological counseling (Education, counseling and behavioral element) | In both groups there was significant improvement in vasomotor symptoms (p<0.0001 | NR | Insomnia significantly improved in the combined group (HRT + counseling) p=0.0001 from baseline and 0.0022 between groups. Insomnia was not significantly improved in HRT group. | Combined treatment group has significant benefit in nervousness (p=0.0001), anxiety, depression, emotional alteration, melancholia (p=0.0001) over HRT only group, however, both groups had significant improvement in these parameters from baseline. HRT only nervousness (p=0.0001) and anxiety (p=0.0002); combined group both had p = 0.0001. | NR | NR | NR | NR | NR | NR | Weakness and fatigue improved in combined group over HRT alone group (p=0.0001); same with palpitations. Neither group had improvement in joint and muscle pain or headache symptoms. | NR | NR | NR | Mind-body
Atkinson, 2004 | 205 | DB RCT | P | 1 year | Women recruited from a breast clinic in Cambridge, UK | Exclusion: | 28 day menopausal symptom diary at baseline and 12 months; severity and frequency of 21 symptoms associated with menopause | NR | NR | NR | Excluded | NR | NR | NR | Measured but not reported | Promensil 1/day; 26 mg biochanin, 16 mg formononetin, 1 mg genistein, 0.5mg diadzein derived from red clover | Placebo | Interaction between treatment group and menopausal status for changes in menopausal symptom score and number of hot flashes was not statistically significant p<0.05 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | 16/102 withdrew from Promensil group and 12 /103 from placebo withdrew | None reported; most withdrew to go on HRT | None | Biologically based therapies
| | | | | | 1. History of breast cancer, major breast surgery
| | | | | | 2. Use of HRT
Baber, 1999 | 51 | DB RCT | P | 7 months | Unpaid female volunteers | Inclusion: | Greene Climacteric Scale | Excluded | NR | NR | NR | NR | Vegetarian > 10g legumes/ day excluded | None for 3 months | Weight reported in kg with mean 67–71 kg +/−-11.0–12.8 | Promensil (Novogen Ltd, Sydney); Promensil is a standardized isoflavone supplement prepared from red clover extract in 500mg tablet form containing 40 mg/tablet; contains genistein, daidzein, biochanin, and formononetin | Placebo | Greene score and flush frequency decreased in both placebo and active groups during the 3 months of treatment (p=0.003); no difference between groups | NR | NR | NR | NR | NR | NR | NR | NR | NR | Significantly different (p=<0.001) in urinary isoflavones between baseline and 3 months in the supplemented group; not the case in the placebo group | 8/51 withdrew | 7 withdrew for personal reasons; 1 withdrew for medical reasons not related to the study | NR | Biologically based therapies | After urine isoflavone analysis was performed, it became apparent that many subjects in the placebo group displayed high urinary isoflavone excretion
| | | | | | 1. Aged 45–65
| | | | | | 2. > 3 hot flushes/day
| | | | | | Exclusion:
| | | | | | 1. Intercurrent medical problems
| | | | | | 2. HRT or antibiotics in previous 3 months
| | | | | | 3. FSH<30
| | | | | | 4. Menstruation in previous 6 months
| | | | | | 5. Hysterectomy
| | | | | | 6. Vegetarian (>10g legumes per day)
Baird, 1995 | 97 | RCT | Control Usual care | 4 weeks | Volunteers recruited through newspaper ads, flyers, and radio | Inclusion: | Health habits and history questionnaire, Luteinizing hormone, follicle stimulating hormone, vaginal cytology, urinary phytoestrogen | NR | NR | NR | NR | NR | NR | None for 6 months | NR | 1/3 of calories to come from soy flour | Control was usual care diet | NR | No change in vaginal maturation index | NR | NR | NR | NR | NR | NR | NR | NR | No change in FSH, LH, | 6/97 withdrew, 3 were found ineligible after screening, 2 from other family emergencies and 1 could not tolerate soy foods | None | None | Biologically based therapies
| | | | | | 1. Age less than 65
| | | | | | 2. No menses for ≥ 2 years
| | | | | | 3. No use of estrogen or antibiotics ≥ 6 months
| | | | | | 4. No use of prescription drugs known to effect outcomes, such as corticosteroids.
Balk, 2002 | 27 | RCT | P | 6 months | Postmenopausal women were recruited from clinics and private gynecology, family practice, and internal medicine offices in Pittsburgh. Advertisements were placed in newspapers, on radio, and on the web site for Magee-Women's Research Institute home page. | Inclusion: | Endometrial biopsy | NR | NR | NR | NR | Excluded | NR | Over 1 year to be eligible | Mean was average | 100 mg soy/cereal/day | N/A | No difference | No difference | Soy had more insomnia | No difference (depression) | N/A | N/A | No difference | N/A | No difference (decreased libido) | N/A | Headache, palpitation, night sweats, no difference | 2/13 from placebo and 6/14 from the soy group | Yes | Flatulence, poor taste - no improvement | Biologically based therapies
| | | | | | 1. Over 40 years, postmenopausal, no vaginal bleeding for 1 year or >30 years old with BSO or POF | Menopausal Symptoms Questionnaire by Brzeginski, et al | | | | | | | | | | | | | | | | | | | | | | | Number not stated
| | | | | | 2. Omnivore
| | | | | | 3. Intact uterus
| | | | | | Exclusion:
| | | | | | 1. HRT in past year
| | | | | | 2. Use of SERMs
Bellipanni, 2001 | 79 | RCT | P | 6 months | No relevant pathologies, taking no drugs, hormones or herba preparation and conducting a normal lifestyle with typical Mediterranean diet rich of carbohydrates and fresh vegetables | Inclusion: | Questionnaire in which life habits, physiological data, data concerning previous pathologies, treatment-related side-effects, treatment-induced alterations, effects on perimenopausal symptoms (neurovegetative, sleep, psychological) werer recorded at time 0 and at 3 and 6 months. Questions concerned duration and character of their menstrual cycle and/or psychosomatic, peri- and menopause related symptoms such as irritability, morning mood and depreession, insomnia, night sweatings, headache, stypsis, amnesia, hot flushes, palpitations, and body weight increase. | NR | NR | NR | NR | NR | All non-smokers and no alcohol abuse | NR | NR | 3 mg melatonin/day | Placebo | No significant difference between groups | NR | No significant difference between groups | After analysis of all answers, the evaluation of different typical perimenopause or menopause-related symptoms or alternations did not disclose a clear-cut difference between the two groups, with the notable exception of a very significant improvement of mood and complete disappearance of morning depression in the melatonin-treated women. | NR | NR | NR | Only episodical improvement of regularity and duration of menstrua cycles were reported. Six menopausal women (at 1 and 2 years after total cessation of the menses) reported a re-acquisition of normal (bleeding and duration) menstrual cycles | NR | NR | Information on LH, thyroid and FSH results | NR | NR | NR | Biologically based | Poor study
| | | | | | 1. Age 42–62
Blatt, 1953 | 748 | DB RCT | 5 arms with controls and placebo | 3 years | Climacteric women | NR | Menopausal index, a validated scale that represents a numerical conversion of the severity of the 11 most common menopausal symptoms. | NR | NR | NR | NR | NR | NR | NR | NR | Vitamin E 50–100mg tid (n=82) vs. ethinyl estradiol 0.05mg (n=107) vs. conjugated equine estrogen 1.25mg (n=173) vs. phenobarbital 15mg tid (n=88). | Placebo (n=298) | All results reported by menopausal index of which several questions pertain to vasomotor symptoms. No p values are given in paper due to date of publication. However, 66.5% of both estrogen groups had an excellent response to treatment (as compared to 13.4% of Vitamin E, 23.6% of phenobarbital and 15.6% of placebo patient) | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | Biologically based
Boblitz, 2003 (Abstract Only) | 179 | RCT | P | 6 weeks | Women with menopausal symptoms | NR | Kupperman Menopause Index; CGI scores for anxiety, impaired drive, depressive mood and nervousness/irritability | NR | NR | NR | NR | NR | NR | NR | NR | Remifemen Plus; 20 mg black cohosh, 250 mcg of hypericin | Placebo | NR | NR | NR | In all Greene Climacteric Index items referring to psychological symptoms, Remifemin Plus was superior to placebo (p<0.001) | NR | NR | NR | NR | NR | NR | A decrease in Kupperman Index total score demonstrated significant superiority of the active to placebo (p<0.001) | NR | 6 withdrew in each group due to adverse events, none serious | NR | Biologically based
Brzezinski, 1997 | 145 | RCT | Control Israeli diet (usual care) | 12 weeks | Women who were peri and postmenopausal (43–65 years) with climacteric complaints from the outpatient menopause clinic at Hadassah Medical Center, Jerusalem, Israel | Inclusion: | Menopause symptoms questionnaire (MSQ); evaluates hot flashes, night sweats, palpitations, headache, depression, vaginal dryness, urinary discomfort, insomnia, and decreased libido on a four point scale. Serum phytoestrogen concentrations | Included | Included | NR | NR | NR | NR | Could not be taken at the time of study | 26.24 ± 0.48 for PE group and 25.82 ± 0.87 in control group | Phytoestrogen rich diet, approximately 1/4 of their calories (PE group) | Regular Israeli diet; told to avoid soy products and flax seed | Significantly reduced in PE group over controls (p=0.004) | Significantly reduced in PE group over control (p=0.005) | NR | NR | NR | NR | NR | NR | NR | Total score of menopausal symptomatology (MSQ score) was reduced greatly in both groups during the study groups, but the difference between the groups was not significant | Average of 100-fold increase in the phytoestrogen serum levels of the PE group; no change in the control group | 31/145 | 4/95 in the PE group due to intolerance of diet; 2/95 in soy group and 7/50 in control group withdrew due to unbearable menopausal symptoms; other dropouts were due to personal reasons | NR | Biologically based therapies | Interesting as came from food, tofu, soy milk, and flax seed largely
| | | | | | 1. Natural or surgical menopause (≥ 3 months of amenorrhea)
| | | | | | 2. FSH>30, LH>20, and low plasma estradiol level (<200)
| | | | | | 3. ≥ 1 of the following symptoms: hot flashes, night sweats, insomnia, depression, vaginal dryness, or dyspareunia
| | | | | | Exclusion:
| | | | | | 1. Evidence of acute medical illness
| | | | | | 2. Use of gonadal hormones or any medication known to influence menopausal symptoms or endocrine variabels
| | | | | | 3. Known or suspected allergic reaction to specific food items.
Burke, 2003 | 241 | DB RCT | HH | 24 months | Women aged 45–55 were recruited from the community and seen at Wake Forest University. | Inclusion: | Self report in symptom diaries. | 56/241 | NR | NR | Excluded | NR | NR | 180/241 | 0/241 | 25g of soy with 42mg a day of isoflavones or 25g of soy with 58mg a day of isoflavones | 25g of soy, alcohol washed to remove isoflavones (Control) | Rapid reduction in all groups, including control. No difference between groups. | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | Biologically based therapies | 170/241 used OC
| | | | | White: 88% | 1. Perimenopausal (only 1 period in preceding 3 months) | | | | | | | | | | | | Significant reduction for all groups from baseline (p<0.0001) but no difference between groups (p=0.10).
| | | | | Married: 79% | 2. At least 1 vasomotor symptom a day
| | | | | High school diploma: 96% | 3. No use of HRT for 3 months prior to study entry
| | | | | ≥$30,000 annual income: 79% | Exclusion:
| | | | | | 1. Acute myocardial infarction or stroke within 6 months
| | | | | | 2. History of breast or endometrial cancer
| | | | | | 3. History of invasive cancer within 5 years
| | | | | | 4. Active thromboembolic disease
| | | | | | 5. Previous osteoporosis fractures being treated with hormones
| | | | | | 6. Low bone density
| | | | | | 7. Previous exposure to diethylstilbestrol
| | | | | | 8. An endometrial biopsy showing hyperplasia
Bygdeman, 1996 | 40 | RCT | HH | 3 months | Postmenopausal women complaining of vaginal dryness (aged 43–76, mean 58.28 years) | Exclusion: | Self diary and vaginal dryness index (Bachmann) | NR | 2/40 | NR | NR | NR | NR | NR | NR | Replens: 1 vaginal application three times/week for 3 months | Dienoestrol vaginal cream (0.01%) 0.5mg daily for 2 weeks then three times a week for 3 months | NR | Both groups resulted in a significant increase in the vaginal dryness index with compared to baseline values | NR | NR | NR | NR | NR | NR | NR | NR | NR | 1/40 | NR | NR | Biologically based
| | | | | | 1. Hormonal-dependent tumors
| | | | | | 2. Known or suspected other serious diseases, abnormal genital bleeding, past history of active thromboembolic disorder, vaginal infection
| | | | | | 3. HRT in the last 3 months
| | | | | | 4. Vaginal use of any douche or lubricant
Cagnacci, 2003 | 80 | RCT, open | HH | 3 months | Women (age 47–53) in perimenopause referred to the Menopause Center were enrolled; mean age was 50.2, 51.5 and 51.8 | Exclusion: | State Trait Anxiety Inventory, Self-Evaluations Depression Scale, Greene's Climacteric Scale | NR | NR | NR | NR | NR | NR | NR | Mean 26.0, 26.9 and 26.7 | Kava-Kava (KK) 100m/day (15 women) vs. Kava-Kava 200mg/day (19 women) | Control was 1000mg Calcium/day (34 women) | Both KK groups had significant decline in Greene's score from baseline, but not significantly different from control group. | NR | NR | Anxiety; significant decrease compared to control in both KK groups (p<0.009); Depression scores were significantly decreased from baseline in KK groups, however, not significant from controls | NR | NR | NR | NR | NR | NR | NR | 12/80; 6 in the control group, and 5 in the 100mg KK group and 1 in the 200mg KK group | 2 for nausea and gastric pain | nausea and gastric pain | Biologically based
| | | | | | 1. Organic or neurological pathologies
| | | | | | 2. Used hormones, neuroactive or psychotropic drugs in the 3 months preceeding
Carranza-Lira, 2001 | 30 | DB RCT | P | 1 month | Postmenopausal women who attended the Climacteric Clinic of the hospital studied | Inclusion: | Modified Kupperman Index | NR | NR | NR | NR | NR | NR | Never received | No difference between groups (average BMI is 28) | Phytoestrogen cream 4mg/day aloe vera; wild yam root extract; almond oil; cartamo oil; jojoba oil; tocopheryl acetate; chamomile extract; sheepshkin root extract oil of ass herb; siberian ginseng extract; to alternating forearms/day | Cold cream control | A significant decrease in Kupperman Index Score was found in both groups at the end of treatment (p<0.001), no other significant differences between groups | NR | NR | NR | NR | NR | NR | NR | NR | NR | A significant decrease in KI was found in both groups at the end of the treatment (p<0.001) in both groups from baseline | NR | NR | NR | Biologically based therapies
| | | | | | 1. No current or previous exposure to HRT
| | | | | | 2. FSH >30 and estradiol <30
Chen, 2003 | 52 | RCT | HH | 16 weeks | Non-hysterectomized postmenopausal women, aged 45–65 with climacteric complaints were recruited from outpatients attending this Taiwan Hospital | Inclusion: | Greene Climacteric Scale | Excluded | Excluded | Excluded | Excluded | NR | NR | None within 6 months | 52–56 kg | JWSYS (Sun Ten Pharmaceutical Co., Taipei, Taiwan); 4 grams tid; includes angelica Radix, Atractylodis rhizoma, Paeoniae Radix; Bupleuri Radix; Hoelen; Glycyrrhizae Radix; Moutan Bark; Gardeniae Fructus; Zingiberis Rhizoma, Menthae Herba | Premelle 0.625/2.5 (Wyeth Medica, Newbridge, Co. Kildare, Ireland); one tablet q d | JWSYS had significant reduction (p<0.01) in vasomotor symptoms on Greene scale and Premelle did not. | NR | NR | Both groups had significant improvement in anxiety and depression (p<0.01) | NR | Both groups had significant improvement from baseline (p<0.01) | NR | See withdrawals | Premelle group had significant improvement (p<0.01), but JWSYS group did not | NR | Both JWSYS and Premelle induced a significant reduction of prevalence and severity of menopausal symptoms. (p<0.01) | 13/37 JWSYS; 11/25 HRT | 3/37 from Chinese herb group due to vaginal bleeding and abdomenal disturbances; 5/25 from HRT group due to vaginal bleeding and breast tenderness | See withdrawals | Biologically based therapies | No true control; high drop out rate
| | | | | | 1. Last menstruation ≥ 6 months previously
| | | | | | 2. No HRT for ≥ 6 months
| | | | | | Exclusion:
| | | | | | 1. Severe metabolic, endocrine, or GI disease, concomitant heart disease, uncontrolled hypertension (>160/95), diabetes, endometriosis, undiagnosed vaginal bleeding and psychiatric illness
| | | | | | 2. Surgically induced menopause
| | | | | | 3. Previous or current estrogen-dependent tumors, other current malignant or life-threatening disease,
| | | | | | 4. Previous or concomitant serious or chronic medical conditions.
| | | | | | 5. Taking tranquilizers or antidepressants
Chenoy, 1994 | 56 | DB RCT | P | 6 months | 56 women were recruited from the general gynecology clinic of North Staffordshire Hospital Center, London; from general practitioners' surgeries, and by self referral of volunteers. | Inclusion: | Self reported symptom diary | Excluded | NR | NR | NR | NR | NR | None for 2 months prior | NR | Six months of treatment with either four 500mg evening primrose oil with 10mg natural Vitamin E | Placebo was 500mg liquid paraffin; four capsules twice daily | All women given placebo showed a significant positive difference between control cycle and last cycle (p<0.05). Women given gamolenic acid, however, did not show a significant improvement between the control cycle and last available treatment cycle except for a reduction in the maximum number of night time flushes (p-0.014). | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | 11/28 from placebo and 10/28 from gamolenic acid group | 2/11 from placebo due to nausea; however main reason stated was lack of clinical response | Lack of clinical response | Biologically based therapies | Significant response to placebo but not to gamolenic acid
| | | | | | 1. Menopausal women who had hot flushes at least three times/day
| | | | | | 2. Elevated FSH and LH or had amenorrhea for at least 6 months, or both.
| | | | | | Exclusion:
| | | | | | 1. Received estrogen replacement or essential fatty acid supplements in the previous 2 months.
| | | | | | 2. Taking any form of HRT or other drug for menopausal symptoms during the study, or systemic steroids, non-steroidal anti-inflammatory agents, anticonvulsants, clonidine, and phenothiazides.
Chiechi, 2003 | 187 | RCT | Usual care | 6 months | Healthy postmenopausal asymptomatic woman aged 39–60, living in Southern Italy; mean age was 52.7 years | Inclusion: | Karyopycnotic index and maturation value of the vagina, FSH, estradiol, urinary daidzein, vaginal smears | Included | NR | NR | NR | NR | NR | NR | 27.06–28.9 mean | Women were given soy increased diet, adding a soy food every day, and two meals twice/week based on phytoestrogen rich food; isoflavone intake of 20–30mg/day | Usual care; and HRT | These women were asymptomatic | Statistically significant improvement from baseline in vaginal indices in both the HRT (p<0.01) and soy groups (p=0.03), most in the HRT group; not seen in control group | NR | NR | NR | NR | NR | NR | NR | NR | NR | 22 out of control group; 44 out of diet group; 31 out of HRT group | NR | NR | Biologically based therapies | Too high of drop out rate to be reliable
| | | | | | 1. Spontaneous menopause of ≥ 6 months
| | | | | | 2. FSH>30, or bilateral oophorectomy
| | | | | | Exclusion:
| | | | | | 1. Age >60
| | | | | | 2. Heavy drinkers
| | | | | | 3. Treatment with HRT, cholesterol-lowering, antiosteoporotic or other interfering drugs (i.e. tibolone)
| | | | | | 4. Diabetes or history of cancer
| | | | | | 5. In vegetarian or macrobiotic diet
| | | | | | 6. Presence of menopausal symptoms requiring therapy
Cleary, 1994 | 30 | RCT | P | 15 weeks | Women age 50–60 years with menopausal symptoms recruited through local and national newspapers | Inclusion: | 1. Weekly 1–10 scale Symptom questionnaire during study | NR | NR | NR | Excluded | NR | NR | At least 18 months | NR | The spine and pelvis of each subject was treated by a low-force osteopathic technique developed by Fox, and the cranium by cranial techniques following mechanical principles weekly for 10 weeks, followed by a 5 week observation period. | Placebo: low-force technique delivered to a joint adjacent to a restricted joint, where it will have no effect; force is so low in both groups that they are unaware they have received treatment weekly for ten weeks followed by five week observation period | Reduction in study group of hot flashes (p=0.016) at ten weeks and (p=0.007) at 15 weeks; Reduction in study group of night sweats (p=0.021) at ten weeks and (p=0.016) at 15 weeks | NR | Reduction in insomnia vs control group (p=0.098) at ten weeks and (p=0.018) at 15 weeks | Reduction in depression in study group compared to controls (p = 0.042) at ten weeks and (p=0.290) at 15 weeks; Reduction in irritability is study group compared to controls (p = 0.184) at ten weeks and (p=0.271) at 15 weeks | NR | NR | Reduction in urinary frequency in study group over controls (p=0.021) at ten weeks and (p=0.168) at 15 weeks | NR | NR | Average symptom score decreased in the study group compared to the control group over the study (p=0.005) | Of the 11 hormones studied there was a significant difference in testosterone levels (decreased in study group) (p=0.028); Reduction in pain was greater in the study group: (p=0.04) for neck pain, and (p=0.06) for back pain | NR | NR | NR | Manual Medicine
| | | | | | 1. < 4 periods in the previous 12 months | 2. Pre-, Week 5, and Week 15 blood levels of estradiol, FSH, LH, thyroxine, testosterone, sex hormone binding globulin, prolactin, cortisol, IGF/1, TSH, and GH
| | | | | | 2. Abnormal FSH/LH analysis
| | | | | | Exclusion:
| | | | | | 1. Current or past HRT in last 18 months
| | | | | | 2. Any debilitating medical condition
| | | | | | 3. Any facial or spinal surgery
| | | | | | 4. Taking medication likely to affect their hormonal or sympathetic systems, such as thyroxine, or beta-blockers
| | | | | | 5. Any past or present patient of the researcher
Cohen, 2003 | 18 | RCT | HH | 12 weeks | Women were recruited by flyers and by advertisements in local newspapers in a New England ; 11/17 women had ceased having menstrual cycles within the past 2 years and the remaining 6 women had not had a period in 3–4 months; Mean age was 47.3 years (43–53) | Inclusion: | 4 scale daily symptom diary | NR | NR | NR | NR | NR | NR | Excluded at least 3 months prior | NR | 9 week acupuncture treatment protocol consisting of 1/week for 3 weeks then once every other week for a total of 6 treatments followed by 3 nontreatment weeks (20–30 minutes/ treatment) (EA group) | UB15, 23, 32; GV 20, H7; pericardium 6; SP6, 9; L3 for experimental group; comparison is general tonic (shen mein) L4;K7 and ear points (7) | EA group showed a decrease in mean monthly hot flush severity (30%) for site-specific acupuncture from baseline to month 2 (p=0.05), baseline to month 3 (p=0.005) and baseline to posttreatment month 4 (p-0.019). The comparison acupuncture treatment group had no change in severity from baseline over the treatment phase. | NR | Sleep disturbances in the EA group declined over the study and reached a statistically significant difference (0.05) from baseline in posttreatment month. This also accured in the comparison group. | Mood changes decreased in both groups between baseline and posttreatment month of the study; EA group p=0.05; comparison acupuncture group (0.056) | NR | NR | NR | NR | NR | NR | NR | 1/18 | Withdrew prior to randomization | None | Alternative Health Systems
| | | | | | 1. Ability of self-identification of menopausal hot flushes
| | | | | | 2. Ceased previous treatment of menopausal symptoms with hormones, other medications, herbs, or acupuncture at least 3 months prior to enrollment in the study to allow for a sufficient cleansing period
| | | | | | Exclusion:
| | | | | | 1. Women with hormonal supplementation, other pharmacologic therapies, herbal remedies, or acupuncture (including acupressure).
Crisafulli, 2004 | 90 | RCT | P, HH | 1 year | Healthy, ambulatory women, referred by the Department of Internal Medicine and the Department of OB/GYN at University of Messina, Italy, age 47–57 | Inclusion: | Self-reported diary of the number of hot flushes, 14 days before each assessment; only number used, not severity | Not allowed | Not allowed | NR | NR | NR | Not allowed if smoked > 10 cigarettes/day | None for 12 months | Average for all groups was 23–24 | 1mg/day estradiol combined with noresthisterone; genistein (n=30) at 54mg/day | Placebo | Estrogen group, flush score decreased by 53% (p<0.001) compared to placebo at 3 months. This was maintained at 6 and 12 months. Genistein group decreased by 22% (p<0.01) after 3 months; 29% at 6 months (p<0.001) and 24% at 12 months (p<0.01) compared to placebo. The difference between the estrogen group and the genistein group was significant at all measurements (p<0.05) | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | 7 | None | None | Biologically based therapies | Funding source not reported; important study due to length.
| | | | | | 1. No surgical menopause patients
| | | | | | 2. No period for 12 months, FSH>50 and estradiol level <100.
| | | | | | Exclusion:
| | | | | | 1. Clinical or lab abnormalities suggesting cardiovascular, hepatic, renal disorders, coagulopathy
| | | | | | 2. Use of oral or transdermal estrogen, progestin, androgen or other steroids in the preceeding year
| | | | | | 3. Smoking >10 cigarettes/day
Dalais, 1998 | 52 | DB RCT | HH | 7 months | 52 postmenopausal women were recruited | Inclusion: | Hot flush diary | NR | NR | NR | NR | NR | Non smokers; non vegetarians | None for 3 months prior | NR | 45 grams of soy (high phytoestrogen), linseed (high phytoestrogen), or wheat diet; dosage of isoflavones (daidzein, genistein) was 52.64 ± 8.68 mg/day | Wheat diet | In women consuming linseed and wheat, a significant decrease in hot flush rate was observed following 12 weeks of ingestion (41% decrease, p<0.009; 51% decrease, p<0.001 respectively) compared to baseline. No significant decrease in hot flush rate was detected during soy ingestion. | Women ingesting soy showed signicant increase in vaginal cytology maturation index (p-0.03); none for other two groups | NR | NR | NR | NR | NR | NR | NR | NR | Urinary excretion of daidzein, genistein, enterodiol and enterolactone increased significantly (10–30 fold) during soy and linseed ingestion, respectively (p<0.01). No such changes in wheat group | 8/52 | Personal reasons | NR | Biologically based therapies
| | | | | | 1. Age 45–65
| | | | | | 2. FSH > 40
| | | | | | 3. > 14 hot flashes/week
| | | | | | 4. 12 months of amenorrhea
| | | | | | 5. No antibiotic or hormone replacement therapy use for the preceding 3 months
| | | | | | 6. Non-smoker and non-vegetarian
Davis, 2001 | 55 | DB RCT | P | 12 weeks | Women, age 45–70 years were recruited through the Jean Hailes Foundation Newsletter, newspapers, radio station interviews and the medical unit of the Jean Hailes Foundaion | Inclusion: | Daily diary of the frequency of hot flushes and night sweats for four weeks before treatment and for the entire 12 weeks of the study period. The Menopause Specific Quality of Life Questionnaire (MENQOL) and urinary phytoestrogen excretion | NR | NR | NR | NR | NR | NR | 44.4% of placebo group had previously used HRT, and 53.6% of CMH has previously used HRT | Body mass index was 26.1 (24.3, 27.9) in placebo group; and 25.7 (23.9, 27.5) in CMH group | Both placebo and CMH produced by Ningbo Daekang Herbs Co Ltd (Ningbo, China) | Placebo was cornstarch with a bitter taste enhancer | Frequency of vasomotor symptoms were reduced in both CMH and placebo groups. Difference between groups was not significant (p =0.09) A progressive decline in the frequency of vasomotor symptoms with treatment duration was seen in both groups | NR | NR | NR | NR | NR | NR | NR | NR | A reduction in score was seen in all four domains of the MENQOL scores. 'This was significant only for the physical, vasomotor, and sexual domains in the CMH group, and the physical domain in the placebo group. The difference between the two treatment groups was not significant for any of the four domains | Women with more than four years of ammenorrhea had a significantly greater response to placebo than to CMH; significant greater reduction in score was seen with CMH compared with placebo in the vasomotor domain of the MENQOL for age <55, BMI <25, and previous nonusers of natural therapies (p<0.05) | 14/42 in Chinese herbal group; 9/36 in placebo group. | Most withdrew in the first week after randomization due to the taste of both products | In CMH group, two became asymptomatic before study began and withdrew, and on started HRT; 7 withdrew due to taste intolerance, 2 were lost to follow-up, and 2 withdrew due to other illness; in placebo group, one withdrew before the study commenced due to lack of symptoms, 2 withdrew due to no benefit, one withdrew due to other illness, one was lost to follow-up and 3 withdrew due to taste intolerance | Biologically based therapies (specifically comments in article that this is not assessing TCM) | Herbs in CMH = rehmannia glutinosa, Cornus officinalis, Dioscorea opposita, Alisma orientalis, Paeonia suffruticosa, Poria cocos, Citrus reticulata, Lycium chinensis, Albizzia julibrissin, Zizyphus jujuba, Eclipta prostarata, Ligustrum lucidum
| | | | | | 1. Non-Asian women who had lived in Australia for at least ten years
| | | | | | 2. Postmenopausal (>12 months amenorrhea and FSH >25)
| | | | | | 3. Reported at least 14 hot flushes or night sweats/week
| | | | | | Exclusion:
| | | | | | 1. Use of HRT, Chinese medicinal herbs (CMH), or other natural therapies during the eight weeks before baseline
| | | | | | 2. Preexisting gastrointestinal, renal, or liver disease, diabetes mellitus requiring treatment, uncontrolled hypertension, undiagnosed vaginal bleeding, systemic glucocorticosteroid use
| | | | | | 3. Undergoing cancer therapy
| | | | | | 4. Women who had consumed a high phytoestrogen diet for the four weeks before baseline
Duffy, 2003 | 36 | DB RCT | P | 12 weeks | 36 postmenopausal women aged 50–65 were recruited by circular email at King's College London from a database of those who had previously participated in a study on bone mineral density at Guy's Hospital. | Inclusion: | Hospital Anxiety & Depression Scale; Greene Climmacteric Scale; Stanford Sleepiness Scale; Epworth Sleepiness Scale; paced Auditory Serial Addition test; plus short-term memory test from the Weschler Memory Scale; plus samples from the Cambridge neuropsychological Test Automated Battery ‘list all the animals they could think of in 1 minute’ | 13–22% | Included | NR | NR | NR | All nonsmokers; caffeine and alcohol assessed, plus diet; alcohol intake significantly less in soy group (p<0.05); high IQ in both groups (118 and 115) | None in past 12 months | NR | Soya isoflavone supplement used was Solgen 40 (Solbar Plant Extracts, Ashdod, Israel). Each capsule contained 30 mg total isoflavone equivalents. Dose was two capsules/day for 12 weeks | Identical looking placebo capsules; told to avoid Soya foods and food products containing Soya for the duration of the study, and for the two weeks prior | No significant effects of treatment on any of the menopausal symptoms assessed by the Greene Climacteric Scale | NR | No difference | No difference | Significant improvement in memory in Solgen group (delayed recall of pictures (p<0.03); immediate story recall (p<0.06); corrected for practice effect; also learning the reversal of the simple discrimination rule (p=0.05) | No difference | NR | NR | NR | NR | Improved time to learn complex tasks greater in Solgen group than placebo (p<0.05 and <0.003) | 3/36 | None | None | Biologically based therapies
| | | | | | 1. No menstruation for the previous 12 months
| | | | | | Exclusion:
| | | | | | 1. Had used HRT in previous 12 months
| | | | | | 2. Use of antibiotics in the previous 3 months
| | | | | | 3. Current illness or use of psychoactive medication.
| | | | | | Three subjects were excluded during the course of the treatment, two because they started treatment with amitryptiline and one because she started HRT
Faure, 2002 | 75 | DB RCT | P | 4 months | Postmenopausal women requesting treatment for hot flushes. | Inclusion: | Self report by diary. | NR | NR | NR | NR | NR | NR | At least 6 weeks | NR | 70mg/day of Genisten and Diadzin (Phytosoya) 325mg four/day = 70mg of G/D | Placebo | The Intention-to-treat analysis indicated treatment effect on the change in frequency of hot flashes for the intervention group (p=0.01). | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | 6 soy group | NR | NR | Biologically based therapies
| | | | | | 1. ≥ 6 months out from last menses | | | | | | | | | | | | | | | | | | | | | | | 14 placebo
| | | | | | 2. FSH >40
| | | | | | 3. ≥ 7 moderate to severe hot flashes per 24 hours
| | | | | | 4. ≥ 6 weeks since last HRT use
Freedman, 1992 | 33 | RCT | HH | 4 weeks | 33 women were recruited from newspaper advertisements; mean age in years was 50.7 ± 8.6 in paced respiration group; 53.1 ± 6.0 in muscle relaxation group; and 53.9 ± in alpha wave feedback group | Inclusion: | Ambulatory monitoring of sternal skin-conductance level and abdominal and thoracic ventilation; in addition thoracic and abdominal ventilation were recorded on two additional channels of the Medilog using inductance plethysmography (Respitrace); serum epi | Included | Included | NR | NR | NR | NR | None for 1 year | NR (mean weight with variation recorded in pounds) | 8 1-hour biweekly treatment sessions of paced respiration training | 8 1-hour treatment sessions of alpha-EEG biofeedback, or Patients were taught muscle relaxation by a research assistant using previously published methods | Hot flash frequency declined significantly (p<0.02) for the paced-respiration group but not for the muscle relaxation (p>0.2) or alpha wave feedback group (p>0.5). | NR | NR | NR | NR | NR | NR | NR | NR | NR | Analysis of vafriance on respiration rate showed a significant (p<0.02) Group x Pretreatment/Posttreatment interaction effect. Simple effects tests showed a significant pretreatment/posttreatment increase in tidal volume for the paced respiration group (p<0.03) but not for the muscle relaxation group (p>0.8) or alpha wave feedback (p>0.5) | NR | NR | NR | Mind-body interventions
| | | | | | 1. Amenorrheic ≥ 1 year
| | | | | | 2. ≥ 5 hot flashes/day
Freedman, 1995 | 24 | RCT | HH | 4 weeks | Women recruited from newspaper advertisement; age was 52.5 years ± 1.6 for paced respiration group; 52.7 ± 1.6 years for alpha feedback group | Inclusion: | Ambulatory monitoring of sternal skin-conductance level and abdominal and thoracic ventilation; in addition thoracic and abdominal ventilation were recorded on two additional channels of the Medilog using inductance plethysmography (Respitrace); serum epinephrine and norepinephrine | Included | Included | NR | NR | NR | NR | None for 1 year | NR (mean weight with variation recorded in pounds) | 8 1-hour biweekly treatment sessions of paced respiration training | 8 1-hour treatment sessions of alpha-EEG biofeedback | Hot flash frequency declined significantly (p<0.001) for the paced-respiration group but not for the alpha wave feedback group. | NR | NR | NR | NR | NR | NR | NR | NR | NR | The 24-hour patern of skin-conductance level of significantly altered for the paced respiration group (p<0.001); no significant change in any of the biochemical measures | NR | NR | NR | Mind-body interventions
| | | | | | 1. Amenorrheic ≥ 1 year
| | | | | | 2. ≥ 5 hot flashes/day
Germaine, 1984 | 26 | RCT | HH | 6 months | Menopausal women, 44–61 years (Mean=50.3 years); 12 premenopausal women, all reporting regular menstrual periods from 22–45 served as controls | Inclusion: | Heat stress test (HST); this is 2 circulating water pads maintained at 42° C to the subjects torso whild supine on a bed in a 23° C room. Subjects were instructed to signal the earliest perception of a hot flash by pushing a hand-held button; following the HST 1 the 14 menopausal women were randomly assigned to receive 6 weekly sessions of progressive musle relaxation or alpha EEG biofeedback; HSTs were then administered 1 week later and then final test at the end of training. | NR | NR | NR | NR | NR | NR | NR | NR | Progressive muscle relaxation (PMR) | Alpha EEG biofeedback | Increase in heart rate during the heating period, whereas premenopausal women declined in heart rate. Significant reduction in PMR group compared to controls during third HST (Significant test p<0.0003, and Group X Test p<0.002) were found. Also time was significantly longer (p<0.01) for onset of hot flush in the PMR group compared to control group. This change was significant between HST 2 and HST 3 for the PMR group but not the control group (p<0.01). | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | Mind-body interventions | Novel way of confirming the presence of hot flushes
| | | | | | 1. ≥ 2 hot flashes/day
| | | | | | 2. No HRT
| | | | | | 3. No periods
Han, 2002 | 82 | DB RCT | P | 5 months | Women, age 45–55 years | Inclusion: | Kupperman Index; height, weight, blood pressure, lipid, and hormone levels, transvaginal sonography | Excluded | NR | NR | Excluded if within past 5 years | NR | All exercised less than three times/week; 30% smokers in placebo group; 20% smokers in isoflavone group; | None allowed for 12 months | NR | Soy isoflavone 83.3 mg/day; soy protein 50.3 mg and isoflavone 33.3mg. Genistein, daizein, and glycitein in aglycone form 23.3.mg, 6.2mg, and 3.8 mg, respectively. | Placebo was 83.3 mg composed of purified soy protein 50.3mg without isoflavones and glucose 33.3mg | Isoflavone group declined more than placebo group (p<0.01) | NR | Insomnia score decreased in isoflavone group more than placebo group (p<0.01) | Isoflavone group improved score over placebo in melancholia, nervousness (p<0.01) | NR | NR | NR | NR | NR | NR | All measures of Kupperman scale (vasomotor, paresthesia, insomnia, nervousness, melancholia, vertigo, weakness, arthralgia and myalgia, headache, palpitation, formication) showed individual statistical improvement in isoflavone group over placebo (p<0.01) | 1 out of 41 in each group; 1 for ‘poor response’ and 1 for ‘nausea’ | NR | NR | Botanically based | Soy isoflavone obtained from eugenbio Co. Ltda, Seoul, South Korea
| | | | | | 1. Intact uterus
| | | | | | 2. FSH > 25
| | | | | | 3. Estradiol < 20
| | | | | | 4. Presence of hot flashes
| | | | | | 5. ‘in menopause’ at least 12 months
| | | | | | Exclusion:
| | | | | | 1. Using lipid-lowering drugs, antidiabetic medications, soybean-derived products, or herbal supplements
| | | | | | 2. History of uncontrolled hypertension, stroke or TIA
| | | | | | 3. Cancer diagnosed less than 5 years ago
| | | | | | 4. Previous myocardial infarction
Hartley, 2003 | 34 | DB RCT | P | 1 week | Postmenopausal women aged 53–65 were recruited from those responding to articles in national and local press | Inclusion: | National Adult Reading Test-Revised version; Hospital Anxiety and Depression Scale, Greene Climacteric ScaleStanford Sleepiness Scale, Epworth Sleepiness Scale, Immediate and delayed paragraph recall from the Weschler Memory Scale-Revised, and several other brain function measures | Included | Included | NR | NR | NR | Smokers included | None for 12 months prior to study | Mean 66kg | Ginkyo One-A-Day 120mg tablet/day containing 25% Ginkgo flavonoids and 6% terpenoids | Placebo | No significant effect of treatment on any of the menopausal symptoms assessed by the Greene Scale, however all improved from baseline (p<0.001) | NR | No effect | No difference between groups | Not significant between groups | NR | NR | NR | One parameter of Greene's scale that did not improve over time | NR | NR | 3 | One in the placebo group because of brief menstrual period and two in the Ginkgo group because testing was too demanding | NR | Biologically based
| | | | | | 1. No period for 12 months and healthy.
| | | | | | Exclusion:
| | | | | | 1. Use of HRT within the previous 12 months
| | | | | | 2. Smoking more than 20 cigarettes/day
| | | | | | 3. Current illness or use of psychoactive medication, including soya supplements, Ginkgo or ginseng (herbs were allowed)
Hirata, 1997 | 71 | DB RCT | P | 24 weeks | Women (mean age 52.4 ± 6 years) were solicited through radio, television, and newspaper and magazine information; age range was from 44.7–69.3 years in the placebo group and from 44.5 to 59.6 years in the dong quai group. | Inclusion: | Kupperman Index; symptom diary; serum estradiol, estrone, and sex hormone-binding globulin levels; vaginal cells, endometrial ultrasounography | Excluded | NR | NR | Excluded | NR | Smokers excluded; more than 2 alcohol drinks/day excluded; 57% were regular exercisers | No HRT allowed for previous 3 months | Excluded for weight >30% or < 15% of ideal weight | 4.5 grams/day of dong quai from root material | Maltodextrin placebo | 29.4% of the placebo group and 33.3% of the dong quai group reported good or excellent control of their vasomotor symptoms | 40% of subjects complained of moderate to severe vaginal dryness at baseline; 12 weeks later, about 30% still had this symptom | NR | NR | NR | NR | NR | NR | NR | NR | Both groups has significant decrease in Kupperman scale from baseline at 6, 12, and 24 months (p<0.0001); No significant changes were seen in serum estradiol level, estrone level, SHBG level, blood pressure, or weight were seen during the study | 6/36 in the placebo group; 4/35 in dong quai group | Placebo: 2 dropped due to lack of efficacy; 2 developed ‘minor side effects’; 1 lost interest; 1 developed ‘other health problems’; dong quai; 2 due to lack of efficacy; 1 due to minor side effects and 1 due to other health problems | Side effects: burping, gas, and headache in both groups, with no statistically significant difference between groups | Botanically based | Dong quai was extracted from the crushed root of Angelica sinensis by East Earth Herbs, Inc (Eugene, OR). Potency of the study drug material was standardized to 0.5mg/kg of ferulic acid. Oil of orange was added to all study drug material to disguise the aroma of the dong quai.
| | | | | | 1. FSH > 30
| | | | | | 2. ‘troublesome’ hot flushes >14/week
| | | | | | 3. ‘post menopausal’ for ≥ 6 months
| | | | | | 4. No HRT for 3 months
| | | | | | Exclusion:
| | | | | | 1. Weight >30% or < 15% of ideal weight
| | | | | | 2. Previous hysterectomy, serious illness
| | | | | | 3. Use of herbal therapy during the previous 3 months
| | | | | | 4. Gastrointestinal disorders that resulted in chronic diarrhea or malabsorption
| | | | | | 5. History of breast cancer, pelvic irradiation,
| | | | | | 6. Tobacco use, or consumption of > 2 alcoholic drinks per day
| | | | | | 7. Active liver disease
| | | | | | 8. Chronic use of antibiotics
| | | | | | 9. Use of vaginal creams or corticosteroids
Hochanadel, 1999 | 11 | DB RCT | P | 12 weeks | Naturally postmenopausal women over age 45 | NR | Somatic symptoms, mood and verbal learning performance of naturally post-menopausal women were measured | Excluded | NR | NR | NR | NR | NR | NR | NR | 100 mg/day of encapsulated soy isoflavone | Placebo | No improvement | No improvement | NR | No significant difference between groups | No significant differences between groups | No significant differences between groups | No improvement | NR | No improvement | NR | None of the statistical comparisons between the active and placebo conditions yielded findings in support of the hypothesis that soy isoflavones may be useful fo the treatment of these post-menopausal cognitive or somatic changes | NR | NR | NR | Botanically based | Poster. Don't have actual paper
Hudson, 1998 | 13 | DB RCT | P | 3 months | Women recruited from a one sentence article in The Oregonian (local newspaper) | Inclusion: | Self-reported symptom diary (frequency and severity) | NR | Excluded | NR | NR | NR | NR | No HRT for 3 months previously | NR | Botanical formula that contained 500mg combined dry herb: burdock root (2 part), licorice root (2 part), motherwort (1 part), Dong Quai root (2 part) and Mexican wild yam root (1 part) 2 capsules tid | Rice bran placebo with similar smell and appearance also 2 tid. | 100% improvement in severity symptom score in verum group (n=7) and 67% improvement in placebo group (n=6). 71% in verum group had improvement in number of symptoms and 17% had improvement in number of symptoms in placebo group. One sided Z-test showed p<0.03, but two-sided Z test did not reveal this to be statistically significant | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | None | None | NR | Botanically based | Size of study was too small
| | | | | | 1. Hhot flashes and one additional menopause symptom
| | | | | | 2. No HRT for the previous 3 months
| | | | | | 3. Natural physiologic menopause with no menses for > 3 months
| | | | | | 4. No serious acute or chronic disease
| | | | | | 5. No cariovascular disease and normotensive
Hunter, 1999 | 86 | RCT | P | 5 years | All women were over 50 years who had been randomized to two 90 minute education groups or no intervention at age 45; | Inclusion: | 1. Sociodemographic and health information survey | NR | NR | NR | NR | NR | Smokers & exercisers | 29% taking HRT | NR | Education | N/A | HRT users reported fewer hot flashes (p<0.04). | No difference | No difference | No difference in depression or anxiety | Significant difference in knowledge of menopause (p<0.01) | Control group more likely than intervention group to believe aches & pains (p<0.01) & skin problems (p<0.05) are due to menopause, no difference as a category | NR | No difference | Improved sexual function in intervention group (p<0.06) | HRT users in comparison to non-users reported that menopause had a greater impact on their lives (p<0.04). | Women in intervention group maintained better knowledge & did not attribute so many things to menopause. | NR | N/A | N/A | Mind-body interventions
| | | | | | 1. Premenopausal at age 45, from the age/sex registers of five general practices in south London | 2. Knowledge about menopause questionnaire | | | | | | | | | | | | | | | | | | | Controls had lost interest in sex more (p<0.02) | | Women in prepared group took more exercise (p<0.01) and had lower prevalence of HRT (p<0.01)
| | | | | | Detailed exclusion/inclusion criteria outlined in Maturitas 1998:29:215–24 | 3. Menopause Representation Questionnaire (MRQ)
| | | | | | | 4. Women's Health Questionnaire (WHQ)
Hyde, 1983 (Abstract Only) | 30 | RCT | HH | NR | Menopausal women | NR | Menopausal symptoms checklist for frequency, intensity and duration of menopausal symptoms; Galvanic skin responses | NR | NR | NR | NR | NR | NR | NR | NR | 12 contingent Galvanic Skin Response feedback conditioning sessions and progressive relaxation training | 12 non-contingent feedback sessions and were told simply to relax | Both groups improved; No significant difference between groups was observed | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | Mind-body interventions
Irvin, 1996 | 45 | RCT | HH, P | 10 weeks | Postmenopausal women from the greater Boston area recruited through media sources of public service announcements and newspaper advertisements, and through posted notices at appropriate medical sites, age 44–66 | Inclusioin: | Spielberger State-trait Anxiety Inventory; Profile of Mood States; daily hot flash diary | NR | NR | NR | NR | NR | NR | NR | NR | Relaxation group (RR); reading group (R) which served as the placebo intervention group, or the charting group which was the control group | Reading group was instructed to read leisure material; relaxation group instructed in diaphragmatic breathing and breath awareness; both 20 minutes/day | All three groups had a change in flash frequency, but these did not reach statistical significance. The RR group did have a significant decrease (p<0.046) in intensity of hot flashes from baseline. | NR | NR | On the POMS the RR group demonstrated a significant decrease in tension-anxiety (p<0.044) and depression-dejection (p<0.013) | The reading group showed significant decrease in confusion-bewilderment (p<0.013) on the POMS | NR | NR | NR | NR | NR | NR | 12/45 | 4 left because they found charting to be too intrusive in their lives, 3 dropped out due to snow; 2 because they started their menses again, 2 lack of interest, and 1 who went on estrogen treatment | See withdrawals | Mind-body interventions | Inclusion:
| | | | | | 1.General good health | | | | | | | | | | | | | | | | | | | | | | | | | | | 1. Postmenopausal women symptomatic, having ≥ 3 flushes/day
| | | | | | 2. ≥ 6 months without a menstrual period | | | | | | | | | | | | | | | | | | | | | | | | | | | 2. ≥ 6 months of amenorrhea or bilateral oophorectomy, FSH >40
| | | | | | 3. Experiencing ≥ 5 hot flashes per 24 hours | | | | | | | | | | | | | | | | | | | | | | | | | | | Exclusion:
| | | | | | 4. Willingness to monitor flashes and abide by the protocol | | | | | | | | | | | | | | | | | | | | | | | | | | | 1. HRT within the previous 6 weeks
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | 2. Allergy to foodstuffs known to contain isoflavones
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | 3. Current history of active bowel, liver or gall bladder disease
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | 4. Diabetes requiring drug therapy
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | 5. Malignancy (excluding skin cancers)
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | 6. Contraindications to HRT use, vegetarians and/or regular soy product users,
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | 7. Receiving medications that result in liver enzyme induction
Jeri, 2002 | 30 | DB RCT | P | 16 weeks | Nonvegetarian Peruvian women who had been postmenopausal for more than 1 year; median age was 52 ± 0.7 years for treatment group and 51 ± 0.8 years for control group | Inclusion: | Self reported diary of frequency and severity of hot flushes | NR | NR | NR | NR | NR | NR | Excluded | NR | Promensil (40 mg standardized isoflavones (genistein, daidzein, formononetin and biochanin))/day | Placebo | Reduction in both frequency and severity of hot flushes was reported by women in the treatment group; 14 Promensil women had a 48% reduction from baseline in frequency of hot flashes (p<0.001), controls had a 10.5% reduction. P value not given between groups or for control group; Regarding severity index, 47% reduction in Promensil group from baseline (p<0.001) and no change in placebo form baseline. | NR | NR | NR | NR | NR | NR | NR | NR | NR | Significant reduction in FSH in Promensil group from baseline (59.27 to 48.60) P<0.001) | 1/15 Promensil group | NR | NR | Biologically based
| | | | | | 1. < 60 with FSH>30, having ≥ 5 hot flushes/ day averaged for more than 1 week
| | | | | | 2. Not using HRT, antidepressants, or other medication or soy or other estrogen-active plan products
Knight, 1999 | 37 | DB RCT | HH, P | 12 weeks | Women, age 40–65, were recruited through the University Department of OB/GYN at St. George Hospital, Sydney, Australia | Inclusion: | Greene Menopause Scale;self-reported diary of hot flushes | NR | Included | NR | Excluded | NR | NR | None within 6 weeks | NR | Placebo vs. 40mg of Promensil vs. 160mg of Promensil | Promensil is a standardized isoflavone supplement prepared from red clover extract, in tablet form; each tablet contains 40 mg of total isoflavones; genistein (4.0), daidzein (3.5mg) and their methylated precursors biochanin (24.5mgg) and formononetin (8.0mg) | Flushing frequency decreased in all groups over the 12 week trial period. There was not difference in flushing frequency between the active and placebo groups. (average 29–34% reduction) | NR | NR | NR | NR | NR | NR | NR | NR | NR | None of the biological parameters of estrogen activity measured, including FSH, SHBG and climacteric symptom scores, showed any change with time, compared to placebo. (average 26% -160mg group to 46% - placebo group reduction in Greene Score over the twelve weeks) | 2/37 | Intervention by their general practitioner | NR | Biologically based
| | | | | | 1. Postmenopausal women symptomatic, having ≥ 3 flushes/day
| | | | | | 2. ≥ 6 months of amenorrhea or bilateral oophorectomy, FSH >40
| | | | | | Exclusion:
| | | | | | 1. HRT within the previous 6 weeks
| | | | | | 2. Allergy to foodstuffs known to contain isoflavones
| | | | | | 3. Current history of active bowel, liver or gall bladder disease
| | | | | | 4. Diabetes requiring drug therapy
| | | | | | 5. Malignancy (excluding skin cancers)
| | | | | | 6. Contraindications to HRT use, vegetarians and/or regular soy product users,
| | | | | | 7. Receiving medications that result in liver enzyme induction
Knight, 2001 | 24 | DB RCT | P | 12 weeks | 24 subjects were recruited through the University Departments of Obstetrics and Gynecology , Sydney Australia | Inclusion: | Daily flush diary; Green Menopause Scale | Included | Included | NR | Excluded | NR | NR | None within 6 weeks | Mean of 66.1–70.2 kg | Isoflavone powder, TakeCare, 60g/day; isoflavones 134.4mg/day; (aglycone formulations 77.4mg/day) | Casein based powdered drink | Flushing frequency decreased in both groups, but there was not difference in flushing frequency between the active and placebo groups; no difference in Greene Menopause Symptom Scores | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | 4/24 | 3/12 in the isoflavone group..could not tolerate taste | None | Biologically based
| | | | | | 1. Postmenopausal women, having ≥ 3 hot flushes/day; amenorrhea for 6 months, FSH >40 or bilateral oophorectomy
| | | | | | 2. Aged 40–65
| | | | | | Exclusion:
| | | | | | 1. HRT within the previous 6 weeks
| | | | | | 2. Current history of active bowel, liver or gall-bladder disease; diabetes requiring drug therapy; malignancy; contraindications to HRT use
| | | | | | 3. Vegetarians and regular soy-product users.
Komesaroff, 2001 | 50 | DB RCT | P | 3 months | Healthy menopausal women 45–60 years, currently experiencing symptoms of the menopause, recruited from the Baker Institute Menopause Clinic, and from the local community by advertisements placed in local newspapers and discussion in the electronic media. Mean age was 53.3 ± 1.1 years | Inclusion: | Symptom diary self reported including number of episodes of flushing and scores for specific symptoms. Symptom scores were combined to produce values for ‘total’, flushing', and total non-flushing' scores. This approach made possible analysis of specific scores relating to mood, breast symptoms, libido and energy levels. | 3/50 | NR | NR | NR | NR | NR | None within 6 weeks | Mean of 27.3 ± 0.8 | Wild yam preparation (Biogest) supplied in 100gram tubs. Participants were asked to apply one teaspoonful twice daily to the arms, legs or abdomen (manuractures claim that each 1 gram of bioGest contains Dioscorea villosa extract 100mg, Linum usitatissmum oil 2 grams, Perlargonium graveolens oil 100mg, Salvia officinalis oil 100mg and alpha tocopheryl acetate 10mg in a vegetable cream base). | Placebo | No significant difference between the yam cream and placebo in any of the three cases | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | 19/25 in the Biogest group attributed to unrelieved symptoms and unspecified personal circumstances. 8/25 in the placebo group for same reasons | No adverse effects | NR | Biologically based
| | | | | | 1. No HRT for ≥ 6 weeks
| | | | | | 2. Last period > 12 months before, FSH>30 or estradiol <130
| | | | | | Exclusion:
| | | | | | 1. Significant cardiac, renal or hepatic disease, psychiatric disease, inflammatory conditions or active thyroid disease, diabetes, or a history of breast cancer
Kotsopoulos, 2003 | 94 | DB RCT | P | 3 months | Women were recruited from a larger trial. | Inclusion: | Validated questionnaire of menopause-associated symptoms (measure not stated by name). | NR | NR | NR | NR | NR | 0/94 | 0/94 | 0/94 | 118mg Isoflavones | Placebo | No change between groups. | No change between groups. Intervention group had a significant improvement (p=0.01). | NR | No change within groups for psychological outcomes | NR | No change between groups | No change within groups. | NR | No change between groups, both intervention and placebo groups improved (p=0.009 and p=0.015, respectively). | NR | Both intervention and placebo groups had a significant improvement in facial hair (p=0.04 and p=0.014, respectively) and dry skin (p=0.0027 and p=0.011, respectively). | 19/94 | Gastrointestinal side effects | None serious | Biologically based
| | | | | Average age: 59–60 years | 1. Aged 50–75 years | | | | | | | | | | | | | | | | | | | | | | | 10 in treatment group | All were due to AEs (19) | Treatment group: 7 - intolerable; 1 - weight gain; 1 - menopausal symptoms; 1 - unrelated
| | | | | | 2. Non smokers | | | | | | | | | | | | | | | | | | | | | | | 9 in placebo group | | Placebo group: 6 - intolerable; 2 - constipation; 1 - allergies
| | | | | | 3. Non vegetarians
| | | | | | 4. ≥ 12 months amenorrheic
| | | | | | 5. FSH >20
| | | | | | Exclusion:
| | | | | | 1. On HRT in previous 12 months
| | | | | | 2. On phytoestrogens or soy based proteins
| | | | | | 3. On antibiotics in previous 3 months
Kritz-Silverstein, 2003 | 56 | DB RCT | P | 6 months | Women were recruited through mass mailings based on voter registration lists, newspaper ads, and presentations at local organizations. | Inclusion: | Beck Depression Inventory (BDI) | NR | NR | Yes | NR | NR | 2/56 drink soy beverages every day | Yes | NR | 110mg/day of Isoflavones | Placebo | NR | NR | NR | NR | Women in the treatment group showed improvement on four of five tests compared to controls (p=0.03) | NR | NR | NR | NR | NR | NR | NR | NR | NR | Biologically based therapies | Outcome was significant improved performance on category fluency
| | | | | Average age: 61 years | 1. Postmenopausal women aged 55–74 years | The Mini-mental Status Examination (MMSE) | | | exact number not stated | | | | exact number not stated
| | | | | Average age at menopause: 49 years | | Trials A & B of the Halstead-Reitan Neuropsychological Test Battery
| | | | | | | Category Fluency
| | | | | | | Logical Memory and Recall
Leonetti, World Congress on Fertility, 1998 (Abstract Only) | 90 | RCT | P | 1 year | 5 years of menopause, surgical or natural | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | 20mg/day of natural progesterone cream | Placebo | 83% of natural progesterone cream patients had improvement or resolution of vasomotor symptoms compared with 14% of placebo group (p<0.001) | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | Biologically based
Lewis, 2002 (Abstract Only) | 99 | DB RCT | HH, P | 16 weeks | Postmenopausal women | NR | Menopause Specific Quality of Life (MENQOL), plus daily diary of frequency and severity of hot flashes | NR | NR | NR | NR | NR | NR | NR | NR | Flaxseed muffin vs. soy flour muffin | Wheat flour muffin | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | ANOVA on 4 domains showed no significant time by dietary group interaction in quality of life: vasomotor, psychosocial, sexual, physical or in combined score, hot flash frequency of hot flash severity. No MENQOL domains or hot flash symptoms showed significant group differences: however, all groups showed improvement with time | 7/33 from flax, 3/33 from soy;3/33 from wheat | NR | NR | Biologically based therapies
Lindh-Astrand, 2004 | 75 | RCT | HH | 12 weeks | 75 postmenopausal sedentary women with vasomotor symptoms, 48–63 years of age, recruited by advertisement in the local papers and at the gynecological outpatient clinic of a hospital in Sweden; mean age of exercise group was 54 years with BMI of 24.6; estrogen treated women had mean age of 50.9 years and BMI of 25.6 | Inclusion: | Number of flushes during the last day and night in a log-book which was filled in at bedtime for two weeks before and during the 12 week treatment. Also measured the severity of flushes (0–10); also completed questionnaires on aspects of quality of life at baseline, 4,8,12, and 24 weeks, Kupperman Index, VAS to general summary of the total climacteric symptom intensity and distress, MOOD Scale, SCL-90 | 4 | None | NR | NR | NR | NR | None previous | See population | 3 times weekly exercise (15 women); also compared to 8 wait listed women and 4 women being observed in a parallel study on hot flushes in women with breast cancer | Oral estrogen (15 women); 45 other women randomized to three additional arms (2mg/day) | The severity of flushes decreased significnatly p=0.041 in the 5 exercising women, who continued the complete follup-up time of 36 weeks (exercising the entire time period). In the estrogen group the mean number of flushes decreased (p<0.001) after 12 weeks and remained at this level; in the waiting list group of 12 untreated women the number of flushes did not change during a period of 8 weeks. | NR | NR | NR | NR | NR | NR | NR | NR | Kupperman's Index and Mood Scale only changed significantly in the estrogen group (p<0.01), although SCL-90 improved in both exercise and estrogen group (p<0.01) | SCL-90, Kupperman's and VAS all changed significantly p<0.01) at 36 weeks, and mood scale only in the estrogen group | 5/15 in the first 12 weeks, 5/15 additional in the second 12 weeks in the exercise group; 6/15 in the first 12 weeks from the estrogen group; 0/15 in the second 12 weeks | 1 from estrogen group | Vaginal bleeding | Mind-body interventions
| | | | | | 1. Spontaneous menopause ≥ 6 months previously
| | | | | | Exclusion:
| | | | | | 1. Severe endocrine, metabolic or thrombo-embolic disease, uncontrolled hypertension, or daily use of sedatives, anxiolytic or antidepressant medication
| | | | | | 2. Exercising regularly more than 1 hour/week
Makkonen, 1993 | 30 | DB RCT | P | 6 months | Women, mean age of 52.3 ± 2.7 years for guar gum group; mean age of 53.6 ± 4.0 in placebo group | Exclusion: | Kupperman Index, weight, height, blood presuure, serum estrone, estradiol, testoserone, androstenedione, FSH, LH, SHBG, TSH, total cholesterol, HDL cholesterol, triglycerides and fasting blood glucose | NR | NR | NR | NR | NR | 3 were smokers in guar gum group; none in placebo | At least 3 months off | Weight recorded in kilograms | Guar gum (Guarem, Orion Pharmaceutica, Espoo, Finland) 5 grams 3 times daily for 6 months | Placebo was wheat flour granules | Both groups improved significantly on the Kupperman scale (p<0.001) at 3 and 6 months from baseline. No difference between groups | NR | NR | NR | NR | NR | NR | NR | NR | NR | See note under hot flashes regarding Kupperman Index scores | 3 withdrawals from the placebo group, one due to depression and exhaustion, and two due to travelling. No withdrawals from the guar gum group | NA | NA | Biologically based therapies
| | | | | | 1. Uncontrolled hypertension, diabetes mellitus, liver disease or thromboembolic disease
| | | | | | 2. Hormone therapy taken during previous three months
Murkies, 1995 | 58 | DB RCT | HH | 14 weeks | Women were recruited from interested patients in a general practice in Melbourne, Australia and newspaper advertisements | Inclusion: | Diet diary; flush diary to record daily number of flushes; subjective four point scale of ‘general menopause symptoms’ (flushes, sweats, palpitations, headache, sleep disturbance, depression, tiredness, irritability/nervousenss, frequency/urge to urinate, vagninitis, loss of libido, dyspareunia; vaginal smears | NR | NR | NR | NR | NR | Non smokers | None for 3 months | 26.5 ± 0.76 for soy group; | 45 grams of ‘soy flour’ | 45 grams of refined wheat flour | At 6-weeks there was a significant decrease in hot flashes and general symptom score from baseline in the soy treated group (p<0.05). At 12-weeks there was a significant decrease in hot flashes and general symptom group in both groups (p<0.05) and no significant difference between the 2 flour groups. | Vaginal maturation score did not change within or between flour groups | NR | NR | NR | NR | Urinary daidzein excretion increased signifiantly over 12 weeks in the majority of women in the soy group with signicant difference between groups (p<0.001) | NR | NR | NR | No change in lipid panels between groups | 5/28 withdrew from soy group; 6/30 withdrew from wheat group | NR | NR | Biologically based therapies | Soy Products of Australia donated debittered soy and unbleached refined wheat flour
| | | | | | 1. ≥ 12 months of amenorrhea, and FSH>25, | | | | | | | | | 25.6 ± 0.68 for wheat group
| | | | | | 2. Hot flushes > 14/week
| | | | | | 3. Non-smokers
| | | | | | 4. Stopped antibiotics or hormonal replacement ≥ 3 months prior
Nachtigall, 1994 | 30 | RCT | HH | 12 weeks | Post menopausal women | Inclusion: | Pap smear done every 4 weeks with specific criteria for atrophy; Vaginal fluid pH; Vaginal health index | NR | NR | NR | NR | NR | NR | Not allowed | NR | Replens (a nonhormonal bioadhesive local vaginal mosturizer) 3 times/week for 12 weeks | 2 grams of Premarin Vaginal cream daily for 12 weeks | NR | Vaginal moisture showed significant improvement in both groups at 12 weeks (p<0.005) | NR | NR | NR | NR | NR | NR | NR | NR | Vaginal elasticity improved in both groups (p <0.02) from baseline; vaginal pH and vaginal fluid volume improved from baseline (p<0.05) | None | None | None | Biologically based
| | | | | | 1. > 1 year past their last menstrual period
| | | | | | 2. Not on any other HRT
| | | | | | 3. Cancer free
| | | | | | 4. Experiencing vaginal discomfort or dyspareunia.
Nassef, The 10th World Congress on the Menopause. 2002 (Abstract Only) | 37 | RCT | P | 3 months | Postmenopausal Egyptian females | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | Cimicifuga rhizome 40mg/day | Placebo | No difference (p>0.05) between groups | NR | NR | NR | NR | NR | No difference in dysuria or stress urinary incontinence between groups (p>0.05) | NR | NR | NR | Bone aches were significantly improved in phytoestrogen group (p<0.001); no significant difference between groups in vaginal cytology, bone mineral density, or endometrial thickness (p>0.05) | NR | NR | NR | Biologically based
Penotti, 2003 | 62 | DB RCT | P | 6 months | Women patients attending the outpatient Menopause Clinic at the University of Mulan | Inclusion: | Daily diary for hot flash recording | NR | NR | NR | NR | NR | NR | NR | 23.2 both groups | 36mg Soy Isoflavones a day | N/A | No change between groups, both groups had a 40% reduction in hot flashes | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | 6 in soy group | 1 from soy group due to diarrhea | Diarrhea | Biologically based
| | | | | | 1. High FSH and low BE2 | | | | | | | | | | | | | | | | | | | | | | | 7 in placebo group | Persistent hot flashes in the rest
| | | | | | 2. LDL < 160
| | | | | | 3. ≥ 7 hot flashes/day
| | | | | | 4. Post menopausal for ≥ 6 months
| | | | | | 5. Aged 45–60 years
| | | | | | 6. T score > -2.5
| | | | | | Exclusion:
| | | | | | 1. Osteoporosis
Rachev, 2001 | 64 | DB RCT | P | 60 days | Women age 40–60 from the ‘maternity ward’ of the University Hospital in Sofia, Bulgaria; mean age was 51.5 in LF group and 49.5 in placebo group. | Inclusion: | Hamilton Anxiety Scale (HAMA) and the Climacteric Index | NR | NR | NR | NR | NR | NR | NR | Weight was expressed in kilograms, mean of 71.3 for LF group and 79.0 for P group | Liposom Forte (phospholipid liposomes) 28mg/2ml as a single intramuscular injection every other day for a period of 60 days | Placebo injection every other day for 60 days | Significant decline in the climacteric index in LF and P groups from baseline (p<0.001); however more significant decline in LF group (p=0.0013) than P group (NOTE: did include questions of asthenia (p=0.05), dizziness (p=0.024) and restlessness (p=0.019) | NR | NR | Decrease in the total HAMA score in both groups was noted (p<0.001); however significantly greater decline in the LF group than the P group (p<0.001); specifically anxious mood (p=0.006), tension (p=0.024) and fear (p=0.009) were significant between groups as well. | NR | NR | NR | NR | NR | See climacteric index scores under hot flashes | NR | 6/64 | Allergy = 1 | NR | Biologically based therapies | Not sure that they did a good job of confirming symptoms were related to menopause
| | | | | | 1.Evident anxious-depressive symptoms associated with physiological menopause lasting for at least one year | | | | | | | | | | | | | | | | | | | | | | | | anxiety = 1;
| | | | | | 2. No treatment with phospholipids ≥ 4 weeks prior | | | | | | | | | | | | | | | | | | | | | | | | asthenia = 1;
| | | | | | 3. No antidepressant or anxiolytic therapy during the study | | | | | | | | | | | | | | | | | | | | | | | | drowsiness = 2;
| | | | | | Exclusion: | | | | | | | | | | | | | | | | | | | | | | | | hypertension = 1;
| | | | | | 1. Sensory organ deficiency not properly corrected by artificial aids | | | | | | | | | | | | | | | | | | | | | | | | petechia = 1;
| | | | | | 2. Signs or symptoms of foci of cerebral lesions, | | | | | | | | | | | | | | | | | | | | | | | | increased sweating = 1;
| | | | | | 3. Signs or symptoms of other neurological and/or psychiatric diseases requiring treatment with neuroleptic drugs and/or other antidepressants | | | | | | | | | | | | | | | | | | | | | | | | paroxysmal tachycardia = 1;
| | | | | | 4. Liver or kidney impairment, severe cardiovascular diseases, past or ongoing neoplastic diseases, other sever ongoing internal or surgical pathologies | | | | | | | | | | | | | | | | | | | | | | | | weight increase = 1
| | | | | | 5. Proven hypersensitivity to phospholipid
Rankin, 1989 | 40 | RCT | No treatment | 2 weeks | Women, age 40–60 who stated they were experiencing menopausal symptoms; referred to the study by other health professionals and recruited from church groups and various women's organizations. Mean age was 49.3 years, range from 40–58 | Inclusion: | Neugarten-Kraines Menopausal Index Scale, Sound Wave Audiotapes | 41% | NR | NR | NR | NR | NR | 5 (2/sound, 3/control) had taken HRT for 1–12 years | NR | 20 minute long low frequency sound wave audiotape developed by Halpern (1978); 3 times/week for 2 weeks | No treatment | The sound wave group has significant improvement over no treatment in decreased frequency of symptoms (p=0.01), somatic symptoms were decreased (p=0.03) and psychological symptoms were decreased (p=0.029). | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | 6/20 in sound group; 7/20 in the control group | 4 completed the protocol late, others did not follow instructions, or did not have time. | None | Mind-body | Poor study
| | | | | | 1. Understand and write English
Rao, 2003 | 30 | RCT | P | 2 months | Women with menopausal symptoms | NR | Menopause-specific Quality of Life | NR | NR | NR | NR | NR | NR | NR | NR | Biogest cream (wild yam) | Placebo | Significant effects were noted with symptoms of hot flushes, night sweats, and emotional symptoms with dramatic reductions in these symptoms occurring in the BioGest group when compared with placebo. | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | Biologically based | Abstract only available
Russo, 2003 | 50 | DB RCT | P | 3 months | Women who were referred to a clinic in Rome, Italy. | Inclusion: | Self report questionnaire. | NR | NR | NR | Excluded | NR | Smokers excluded | ≥ 6 months discontinuation | Obesity excluded | 32mg/day of Soy (Fitormil)- Specific formulation described in paper | Placebo | 11/25 in soy group and 6/25 in placebo group described improvement in symptoms (p<0.05) | No significant reductions for either group. | No significant reductions for either group. | No significant reductions for either group on anxiety. | NR | NR | NR | NR | NR | NR | NR | 3 | 1 due to spotting after 15 days | Spotting | Biologically based | Cross over study, only using data from first 3 months before cross over.
| | | | | Average age: 53 years | 1. Aged 48–54 years
| | | | | Average age at onset of menopause: 51 years | 2. Recent menopause (1–2 years LMP)
| | | | | | 3. Symptomatic
| | | | | | 4. Caucasian
| | | | | | 5. Negative PAP test
| | | | | | Exclusion:
| | | | | | 1. Currently on HRT or off <6 months
| | | | | | 2. Arterial hypertension or cardiovascular pathologies
| | | | | | 3. Endocrinological pathologies
| | | | | | 4. Nicotinism
| | | | | | 5. Obesity
| | | | | | 6. Alcohol or drug abuse
Salmaggi, 1993 | 80 | DB RCT | P | 30 days | Age 45–59 (mean age is 51) women patients consecutively referred to an Ob/Gyn department in Italy | Inclusion: | HAM-D-21 (Hamilton Depression Rating Scale) and the RDI (Rome Depression Inventory); MMPI (Minnesota Multiphasic Personality Inventory); CGI-I (Clinical Global Impression Improvement Scale) | Included | Included | NR | NR | NR | NR | Not included if on estrogen | NR | 1600mg SAMe per day divided into 4 doses | Placebo | NR | NR | NR | HAM-D-21 decreased significantly (p<0.01) at both day 10 and 30 compared to placebo; also found in RDI (p<0.01), CGI-I (p<0.01) and depression and psychoasthenia scale of MMPI (p<0.01) compared to placebo. | NR | Questions 11–16 on the HAM-D-21 pertaining to somatic symptoms improved significantly from placebo at both day 10 and 30 (p<0.01) | NR | NR | NR | NR | NR | 10/40 from each group due to poor compliance | NR | NR | Biologically based
| | | | | | 1. Major depression within 6 to 36 months following surgical or natural menopause
| | | | | | 2. Free of antidepressants for ≥ 1 week
| | | | | | Exclusion:
| | | | | | 1. Considered at risk for suicide
| | | | | | 2. On estrogen therapy
| | | | | | 3. Major medical illness or bipolar illness
Sammartino, 2003 | 70 | RCT | HH | 12 cycles of 28 days | Women attending Menopause Clinic. | Inclusion: | Kupperman scale - Baseline and 6, 12 months | 0 | 0 | 0 | 0 | NR | NR | Excluded | Excluded if >30 | 36mg/day of Genistein | Calcium supplements | Significant decline in Kupperman Score for Genistein group (p<0.05). | NR | NR | NR | NR | NR | NR | NR | NR | NR | All women in Genistein group had decreased climacteric symptoms (but not specified by symptom). | 3 in Genistein | None | None | Biologically based
| | | | | Average Age: 51 years | 1. At least 12 months after spontaneous menopause | | | | | | | | | | | | | | | | | | | | | | | 4 in Calcium
| | | | | Average time since menopause: 17 months | 2. FSH > 40
| | | | | Average BMI: 24–26 | 3. Estradiol < 20
| | | | | | 4. At least 7 hot flashes of moderate to severe severity in 24 hours during last 2 weeks
| | | | | | Exclusion:
| | | | | | 1. Neoplastic, metabolic and infectious diseases
| | | | | | 2. Concomitant use of any drug
| | | | | | 3. BMI < 30
| | | | | | 4. Past or concomitant use of HRT or other drug used for treatment of climacteric symptoms
| | | | | | 5. Endometrial thickness of >5mm or endometrial abnormalities
Sandberg, 2002 | 30 | RCT | HH | 14 weeks, Follow-up at 6 months | Women age 48–60, natural menopause of at least 6 months were recruited through advertisements in the local press and at gynecological outpatient clinics. | Inclusioin: | Visual Analog Scale (VAS) | Unclear | Not included | Not included | NR | NR | Similar rates of smoking & exercise | NR how recent, not taken during study | 26.7 vs. 25.6 | Electro acupuncture (EA) | Extremely superficial needle insertion | Both groups showed improvement in VAS at 3 and 6 months | NR | NR | Significant improvement in mood at 12 weeks in EA group compared to baseline | NR | NR | NR | NR | NR | NR | NR | 4/15 Superficial needle insertion | Hot flashes | Hot flashes | Alternative health care systems
| | | | | | 1. FSH and estradiol levels confirms postmenopausal state | SCL-90 | | | | | | | | | | | | | | Both groups improved in SCL-90 | | | | | | | | 4/15 EA
| | | | | | 2. Natural menopause of ≥ 6 months
| | | | | | 3. Aged 48–60 years
| | | | | | Exclusion:
| | | | | | 1. Severe metabolic, thromboemboic, endocrine or malignant disease, uncontrolled hypertension
| | | | | | 2. Use of medication that could interfere with vasomotor symptoms
Scambia, 2000 | 39 | DB RCT | P | 12 weeks | Women who were outpatients at Italian hospital (mean age was 54 ± 7.1 years) | Inclusion: | Vasomotor symptoms were evaluted usina a special score card and the Greene climacteric scale. Special score card was filled out daily to evaluate the number and severity of hot flushes and brought it to each visit | NR | 1/50 | 1/50 | NR | NR | NR | NR | BMI = 26.2 ± 1.7 | Standardized soy extract containing 12% isoflavones and 35% saponins in a tablet which was 200mg SOYSELECT 2/day which would correspond to 50mg/day of isoflavones. After 6 weeks of treatment Premarin was also given to each participant at a dose of 0.625 for 4 weeks | Placebo tablet containing lactose | In the first 6-weeks of treatment, participants who were taking the standardized soy extract had a significant reduction (p<0.01) in the mean number of hot flushes/week as compared with placebo. Once the Premarin was started both groups had a decrease in hot flushes and there was no significant difference between groups. | After 6 weeks of treatment, the group that was taking the standardized soy extreact had a significant reduction (p<0.001) in the mean point values 19 and 20 of Greene scale (hot flushes and night sweats) compared with placebo. | NR | NR | NR | NR | NR | NR | NR | NR | NR | 20 were analyzed in soy extract group suggesting no withdrawals | Nausea in 1 placebo member | NR | Biologically based
| | | | | | 1. Spontaneous amenorrhea ≥ 12 months
| | | | | | 2. Surgical or early menopause
| | | | | | 3. Normal endometrial thickness by ultrasound, negative mammography, and metabolic and biochemical index within normal range
Simkin-Silverman, 2003 | 535 | RCT | Lifestyle vs. assessment only | 5 years | Women were recruited from the WHLP clinical trials and were seen at the Health Studies Clinic at the University of Pittsburg. | Inclusion: | Weight, BMI and body fat were measured. | NR | NR | NR | NR | NR | NR | NR | 58/535 High BMI | Behavioral, dietary and physical activity intervention | N/A | NR | NR | NR | No signs of increased stress or depressive symptoms in intervention group | NR | NR | NR | NR | NR | NR | Women lost significantly more weight in the intervention group (p<0.001), remained more active (p<0.001) and consumed fewer calories (p<0.01) than the control group. | 14/260 Intervention | NR | NR | Mind-body | 5 year program showed that intense exercise encouragement (cognitive restructuring program) and low fat diet showed decrease of weight and waste circumference
| | | | | | 1. Aged 44–50 years | Paffenbarger Activity Questionnaire | | | | | | | | | | | | | | | | | | | | | | 12/275 Control
| | | | | | 2. Premenopausal by self report | The Block Food Frequency Questionnaire
| | | | | | 3. Not taking HRT
| | | | | | 4. BMI was 20–34
| | | | | | Exclusion:
| | | | | | 1. Women taking lipid-lowering medication, antihypertensive medication, insulin, thyroid medication, or psychotropic medications
St. Germain, 2001 | 69 | RCT | Placebo | 24 weeks | Telephone interviews of age 42–62 year old women; | Inclusion: | 5 day Menopausal Index (modified from the Blatt instrument, 1953) at baseline, week 12 and week 24 | 11 with intact ovaries | Excluded | NR | NR | NR | Non smoking | None for 12 months prior to study | 20–31 | SPI+ (Supro 675 HG; Protein Technologies International, St. Louis, MO = 80.4 mg/day aglycone components which are the unconjugated parent forms of isoflavones) | SPI- (Supro 675 IF; Protein Technologies International) = 4.4 mg/day aglycone components; Group 3 consumed whey protein (control) produced by ProMod; Ross Laboratories, Columbus, Ohio | No treatment effect on the change in frequency of hot flushes; time of study from baseline did have a significant effect on hot flush frequency in all groups (p.0.003) | No significant difference among the three groups at any time point | NR | No significant difference among the three groups at any time point | NR | NR | No significant difference among the three groups at any time point | NR | No significant difference among the three groups at any time point | NR | NR | 1/69 | None | NR | Biologically based therapies
| | | | | | 1. ≥ 10 hot flushes and/or night sweats/week, within 12 months of their last menstrual cycle
| | | | | | 2. Free from chronic diseases (cardiovascular disease or osteoporosis) or chronic medication use
| | | | | | 3. Not taking HRT or ERT at the time of the study or 12 months previously
| | | | | | 4. 1 or both ovaries remaining
| | | | | | 5. BMI 20–31
| | | | | | 6. FSH>30.
Teoman, 2004 | 81 | RCT | Control Usual care | 6 weeks | Volunteer postmenopausal women (average age 51.0 ± 3.9 years) | Inclusion: | 6 minute walking test, vertical jump test, static back extension test, sit up test, side bending test, sit and reach test, balance test, quality of life using the Nottingham Health Profile | NR | Excluded | NR | NR | NR | NR | Must be on for 12 months | 27.0 ± in exercise group and 25.4 ± 4.0 in control group | 6 weeks aerobic exercise programme | Non-exercise control group | NR | NR | NR | NR | NR | NR | NR | NR | NR | At the end of the 6 weeks, there was a statistically significant change in the exercise group according to NHP, indicating an improvement in the quality of life (<0.05). Only the increase in social isolation parameter was not statistically significant. | NR | NR | NR | NR | Exercise | Turkey
| | | | | | 1. Natural menopause | | | | | | | | | | | | | | | | | | | | | | | | | | Mind/body
| | | | | | 2. Taking HRT ≥ 1 year (0.625 mg estrogen and 2.5 mg medroxyprogesterone/day)
| | | | | | 3. Aged 45–65 years old
| | | | | | 4. No health problems that may prevent from doing exercise
| | | | | | 5. No high cardiac risk
Thompson, 2002 (Abstract only) | 53 | DB RCT | P | 16 weeks | Women with breast cancer with menopausal symptoms | NR | Measure Yourself Medical Outcome Profile (MYMOP), Hospital Anxiety and Depression score, European Organization for Research and Treatment in Cancer Quality of Life Score, Menopausal Symptom Scale | NR | NR | NR | Included | NR | NR | NR | NR | Homeopathic intervention | Placebo | Both groups showed significant improvement over the study period by an average of 80%. No statistically significant difference betweeen groups | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | 8/43 | NR | NR | Biologically based therapies | Abstract only; included as only homeopathic RCT that could be found.
Tice, 2003 | 252 | DB RCT | HH | 12 weeks | Women were recruited from 3 academic clinical research sites in Oakland, CA; Minneapolis, MN, and Iowa City, Iowa from the general population through newspaper and radio advertising, flyers posted in clinics and at health fairs, and directed mailings | Inclusion: | Greene Climacteric Scale; used the psychological (anxiety and depression), somatic, vasomotor, and sexual desire; hot flash diary cards | NR | Allowed | NR | NR | NR | Excluded if drank >2 alcoholic beverages/ day | None for 3 months prior | 26.3 ± 5.1 in Promensil group; 25.6 ± 4.2 in Rimostil group; 26.5 ± 5.4 in placebo group | Promensil contains an average of 41.0 mg of total isoflavones/tablet (red clover containing a higher proportion of biochanin A and genistein); Rimostil contains average of 28.6 mg of total isoflavones and a higher proportion of formononetin and daidzein. Participants took two tablets daily. | Placebo that had less than 0.04 mg total isoflavone | Decrease in hot flush count was significant for all three groups (p<0.001), however, the hot flash reductions in the phytoestrogen groups were not statistically different from placebo at 12 weeks (p>0.20). | NR | NR | NR | NR | NR | NR | NR | NR | NR | Greene Symptom Scales; over the 12-week treatment period, there were significant improvements from baseline in all three groups, but there was no statistically significant differences between groups on any of the Greene scales | 6/252 withdrew 2 from each of the 3 arms; 84 participants were in Promensil group; 83 participants were in Rimostil group; 85 participants were in placebo group | 1 from the Rimostil group | There was no statistically significant association of either of the dietary supplements with adverse events | Biologically based
| | | | | | 1. Age 45–60 years old
| | | | | | 2. Experiencing ≥ 35 hot flashes/week
| | | | | | 3. FSH > 30
| | | | | | 4. ≥ 2 consecutive months of amenorrhea prior to enrollment with ≥ 6 months of amenorrhea in the year prior to entry, or documented bilateral oophorectomy.
| | | | | | Exclusion:
| | | | | | 1. Vegetarians
| | | | | | 2. Consumed soy products more than once/week
| | | | | | 3. Took medications affecting isoflavone absorption (antibiotics, antacids) or hormonal preparations during the three months prior to enrollment
| | | | | | 4. Significant gastrointestinal disease
| | | | | | 5. > 2 alcoholic beverages/day
| | | | | | 6. Allergic to red clover
| | | | | | 7. Regular users of dietary supplements containing isoflavones
| | | | | | 8. Consumed less than 80% of the expected study tablets during the 2-week placebo run-in period
Unfer, 2004 | 376 | DB RCT | P | 5 years | Healthy voluntary postmenopausal women; mean age was 49 ± 4.3 years in soy group; 50 ± 3.9 years in placebo group | Inclusion: | Endometrial biopsies at the beginning of the study, after 30 months, and at the end of the study | Excluded | Excluded | NR | NR | NR | NR | None for 8 weeks | 67 kg ± 10.2 kg in soy group; 65.8 ± 10.7 kg in control group | Soy tablets (3/day) equaled 150mg/day of isoflavones; isoflavones were 40–45% genistein, 40–45% diadzein, and 10–20% glycitein | Placebo | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | No cases of endometrial hyperplasia or malignancy were detected at 30 months; at 5 years, 6 cases of endometrial hyperplasia were detected in Group A (soy), none in Group B (p<.05) (control) | 7 withdrew at 30 months; and 50 more withdrew by 5 years | NR | NR | Biologically based | Significant for length of study..5 years
| | | | | | 1. Intact uterus
| | | | | | 2. Absence of menses for ≥ 12 months
| | | | | | 3. FSH >30
| | | | | | 4. Body weight range within 20% of normal
| | | | | | Exclusion:
| | | | | | 1 Use of medication containing estrogens, progestins, or androgens within 8 weeks of the beginning of the study
| | | | | | 2. Presence of endometrial hyperplasia
Upmalis, 2000 | 177 | DB RCT | P | 12 weeks | Postmenopausal women age ≥ 50 years | Inclusion: | Daily symptom dairy cards for recording the number and severity of hot flushes and night sweats | Excluded | Excluded | NR | Excluded | NR | NR | Discontinue ≥ 60 days prior | See inclusion criteria | Soy isoflavone extract tablet. The extract was standardized for total content of genistin and daidzin (approximately 50% each). The dose contained in two tablets taken once daily was approximately 50mg in total of genistin and daidzin | Placebo | There was a significant (p<0.05) change from baseline in both the number and the severity of hot flushes in both treatment groups. Analysis showed a statistically significant reduction (p=0.01) in average hot flush severity over the 12 weeks in the soy isoflavone extract tablet group compared with the placebo group. Marginally significant (p=0.078) reduction in the number of hot flushes in the soy isoflavone extract tablet group compared with the placebo group; No statistically significant difference between the two groups at 12 weeks (p>0.05) in frequency of night sweats | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | 31/90 those randomized to soy group withdrew; 24/87 withdrew from placebo group | Failure to meet inclusion/exclusion criteria; protocol violations; voluntary discontinuation; | NR | Biologically based therapies | Odd study design in that randomization occurred prior to screening for inclusion/exclusion criteria
| | | | | | 1. Overall good health
| | | | | | 2. Body weight within +/− 35% range for body mass index
| | | | | | 3. FSH >40
| | | | | | 4. Estradiol levels of 25 pg/mL or less
| | | | | | 5. Average of ≥ 5 vasomotor symptoms/day
| | | | | | 6. No menses for at least 6 months
| | | | | | 7. Discontinued HRT use at least 60 days before study entry
| | | | | | Exclusion:
| | | | | | 1. History of breast cancer, hyperplasia, endometrial carcinoma, or cervical neoplasia
| | | | | | 2. Positive pregnancy test
| | | | | | 3.Undiagnosed abnormal vaginal bleeding
| | | | | | 4. Bilateral oophorectomy or hysterectomy
| | | | | | 5. Thromboembolic disorders
| | | | | | 6. History of cardiovascular disease
| | | | | | 7. Liver disease
| | | | | | 8. History of chronic alcoholism
| | | | | | 9. Medication hypersensitivity, or allergy to dietary supplement ingredients
| | | | | | 10. Uncontrolled addiction or severe depression
| | | | | | 11. Acute systemic infection
| | | | | | 12. Abnormal laboratory values
Valente, 10 world congress on the menopause, 2000 (Abstract Only) | 100 | RCT | HH | NR | Menopausal women | NR | Neurovegetative symptoms, vaginal dryness, endometrial pattern, lipids, bone density | NR | NR | NR | NR | NR | NR | NR | NR | 50 women treated with phytoestrogens (25 with oral and 25 with patch, 75mg/day) | 50 with HRT, patch (Estradiol 2.5mg and Levonorgestrel 1mg) | “Phytoestrogen therapy cannot be considered as valid as HRT” | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | Biologically based
van de Weijer, 2002 | 30 | DBRCT | P | 12 weeks | Symptomatic postmenopausal women, age 49–65 | Inclusion: | Greene Climacteric Scale; self-reported diary | NR | NR | NR | Excluded | NR | NR | None for 12 weeks prior to study | BMI was 24.8 ± 3.0 for placebo group and 26.4 ± 5.4 for Promensil group | Red clover (Promensil) 80 mg/day | Identical placebo | No difference in the hot flush count between the 2 groups at baseline 1. At week 12 there had been a significant decline in hot flushes in the isoflavone users (p=0.0154) | NR | NR | NR | NR | NR | NR | NR | NR | Greene scores differences did not reach significance | Isoflavone urinary excretion increased significantly for women in the active treatment group (p=0.027). (p=0.0005) from baseline of 4 week washout period | 3/16 red clover group; 3/14 control group | Zero | N/A | Biologically based therapies | Red clover was manufactured from three varieties of red clover using a standardized extraction and blending process to obtain a proprietary ratio of daidzein, genistein, biochanin and formononectin.
| | | | | | 1. ≥ 5 hot flushes/day | Urinary isoflavone levels | | | | | | | | | | | | | | | | | | | | | | | Withdrawals were due to lack of efficacy
| | | | | | 2. ≥ 12 months amenorrhea
| | | | | | Exclusion:
| | | | | | 1. HRT or antibiotics within 12 weeks of study entry
| | | | | | 2. Undiagnosed vaginal bleeding, active liver or renal disease
| | | | | | 3. History of allergy for foodstuffs
| | | | | | 4. Previous history of malignancy, cardiovascular disease or thromboembolism
Washburn, 1999 | 51 | DB RCT | HH | 6 weeks then cross-over | Perimenopausal women aged 45–55 years; women were recruited through advertisements in a local newspaper | Inclusion: | Self reported symptom diary of hot flashes and night sweats; both frequency and severity; A health related quality of life questionnaire was administered at baseline and at the end of each 6 week intervention period. Using the health related quality of life questionnaire data, an overall symptoms core was calculated by using the Likert scale information for the following content specific areas: estrogenic symptoms, general health, sleep disturbances, and gastrointestinal symptoms. Specifically, the estrogen symptom score was calculated to provide a continuous estimate of the intensity/frequency of symptoms known to be estrogen-dependent (vasomotor symptoms, vaginal dryness, sleep disturbances, breast tenderness, mood swings and difficulties in concentration) | NR | NR | NR | NR | NR | NR | ≥ 6 months discontinuation | Mean weight was 163.4lbs | Group 1: 20 grams complex carbohydrated supplement containing no phytoestrogen; | All supplements were provided by Protein Technologies International, St. Louis, Missouri. All identical appearing packets | No significant differences were observed in the number of hot flushes or night sweats/week; however, severity of hot flashes was lower in the soy groups vs. the carbohydrate group (p<0.001) | NR separately | No significant difference between groups | NR | NR | NR | NR | NR | NR | General health score was not significantly different between groups | Estrogenic symptom score' was significantly different from the comparison group (p<0.05) | 9/51 | 5 had personal reasons; 1 did not want to use aspartame, 1 remembered she was allergic to soy and 1 had a recurrence of acne rosacea | NR | Biologically based
| | | | | | 1. Presence of menopausal symptoms (≥ one hot flush or night sweat daily) | | | | | | | | | | Group 2: 20 grams of soy protein supplement containing 34 mg phytoestrogen/day;
| | | | | | 2. Not currently using HRT (or any HRT in the past 6 months) | | | | | | | | | | Group 3: 20 grams soy protein supplement containing 34 mg phytoestrogens split into two equal doses consumed twice daily.
| | | | | | 3. Missing ≥ 3 menstrual periods in the last 12 months and having last menstrual period not > 12 months before participating in the study
Wiklund, 1999 | 384 | DB RCT | P | 16 weeks | Women were recruited through advertisements in newspapers. Women seeking medical assistance due to climacteric symptoms were asked to participate in the trial as well. | Inclusion: | Women's Health Questionnaire; Psychological General Well-being Index; Visual Analog Scales (VAS); self-reported diary | NR | NR | NR | Excluded | NR | NR | None for 2 months | Reported in kg, with mean 71.1 (11.6) for ginseng group (n=193) and 69.9 (11.5) for placebo group (n=191) | Standardized ginseng extract (Ginsana, containing 100mg of the standardized ginseng extract G115; Pharmaton SA, Lugano, Switzerland); 2 capsules/day | Placebo | Both treatments improved vasomotor symptoms compared with baseline (p<0.05), with no indication that the ginseng was superior to placebo; No statistically significant difference between treatments was observed in vasomotor symptoms even though a considerable decrease in these symptoms was noted for both treatments | NR | NR | Statistically significant differences (p<0.05) were detected for depression, well-being and health subscales of the PGWB in favor of the ginseng extract compared to placebo | NR | NR | NR | NR | NR | With regard to the primary endpoint (total score of the PGWB index) only a tendency for slightly better overall symptomatic relief (p<0.1) was seen in subjects taking the ginseng extract. | NR | 3/193 ginseng group; 2/191 placebo group | 1/193 in the ginseng group due to nausea and lack of efficacy | See withdrawals | Biologically based
| | | | | | 1. Healthy postmenopausal women, aged 45–64
| | | | | | 2. No HRT for the previous 2 months
| | | | | | 3. No bleeding during the previous 6 months
| | | | | | 4. 6 episodes of hot flushes during at least 3 of the past 7 days.
| | | | | | Exclusion:
| | | | | | 1. Previous or concomitant serious or chronic medical conditions
| | | | | | 2. Uncontrolled hypertension (>160/95)
| | | | | | 3. Psychiatric illness
| | | | | | 4. Unable to understand and complete the QoL questionnaires
| | | | | | 5. Taking tranquilizers
Williamson, 2002 | 80 | RCT | HH | 19 weeks | Women age 45–60 with no period for 3 months. | Exclusion: | Women's Health Questionnaire; VAS for severity of flushes and night sweats, MYMOP, a validated, self-completed measure of quality of life | NR | NR | NR | NR | NR | NR | Required | NR | Reflexology weekly for 6 weeks then monthly for 3 months | N/A | No change between groups | NR | No change between groups | Anxiety Depression no change between groups | No change between groups on memory/ concentration | No change between groups | NR | NR | NR | NR | Feelings of attractiveness no change. | 5/38 control | No reasons stated | None reported | Energy Therapy
| | | | | Recruited by means of notices placed in primary care surgeries. | 1. Current HRT use or psychoactive medications | | | | | | | | | | | | | | | | | | | | | | p>0.2 for time-group interaction. | 6/42 reflexology
| | | | | | 2. Severe pathology of feet | | | | | | | | | | | | | | | | | | | | | | p<0.001 - strong time effect evidence
| | | | | | 3. Previous reflexology treatment
| | | | | | 4. Current CAM treatment for menopausal symptoms or
| | | | | | 5. History of severe psychological illness
Woo, 2003 | 136 | RCT | HH | 3 months | 50–65 year old women with no periods for the past 12 months; contacted as part of a territorywide survey and random sampling of housing estates, and participants who are registered with the Family Medicine clinic of the Chinese University of Hong Kong | Inclusion: | Menopausal symptoms questionnaire; MMSE, plus four neuropsychological tests covering measurement of memory (Hong Kong List-Learning test, attention (Trail Making test), motor speed (Finger Tapping Test), and word-finding ability (Boston Naming Test), quality of life (SF36), Food Frequency Questionnaire; lipid profile; urinary deoxypyridinoline; dietary phytoestrogen intake and urinary phytoestrogen; estradiol; FSH and LH | 24% | 18% | NR | Excluded | NR | 100% non smokers | Not allowed | 24 | Pueraria lobata (PL) | HRT; Premelle (Wyeth) containing conjugated equine estrogen (o.625 mg) for first 14 days followed by 14 days of combination of estrogen plus progesterone (5mg) | No significant change in menopausal symptoms between baseline and 3 months in any of the groups | NR | NR | NR | 1. No change in any group except MMSE increased for both HRT & PL | NR | NR | NR | NR | SF-36, no differences in any groups | NR | 5/48 HRT | HRT = abdominal pain, distension, and acne or too busy; PL group = urticaria and being too busy; control group = being too busy | Abdominal pain, distention, acne, too busy, urticania | Biologically based | p values not clear in article regarding cognitive changes, probably <0.05
| | | | | | 1. No period for 12 months | | | | | | | | | | Isoflavone 100mg/day; plus a control group where women were given no treatment | | | | | | 2. Delayed recall improved in HRT vs. control | | | | | | | 2/47 PL
| | | | | | Exclusion: | | | | | | | | | | | | | | | | 3. Attention span better in HRT & PL | | | | | | | 2/41 control
| | | | | | 1. Hypertension, ischemic heart disease, stroke, dementia, diabetes, thyrotoxicosis, breast lump/malignancy, or abnormal Pap smear | | | | | | | | | | | | | | | | 4. Performance in flexible thinking best in PL group
| | | | | | 2. Taking lipid lowering drugs or HRT
Wuttke, 2003 | 62 | DB RCT | HH, P | 12 weeks | NR | Inclusion: | Menopausal rating scale | NR | NR | NR | NR | NR | NR | NR | Excluded if >30 | Cimicifung racemosa (CR BNO 1055) brand name Klimadynon/Menofem, correlating to 40mg herbal drug/day; and placebo | Conjugated estrogen 0.6mg/day | MRS items 1–3 (#1 related to hot flashes) were significantly reduced by the CE compared to placebo (p=0.0461). CR BNO 1055 showed a marked difference to placebo, without reaching the level of significance. | NR | NR | NR | NR | Factor 3 (questions 7–10 on the MRS scale) which relate to urinary and sexual symptoms did show significant improvement with the black cohosh vs placebo (p=0.0218); CE approached significance (p=0.0503) | NR | NR | NR | MRS score (items 1–10) demonstrates an obvious placebo effect over the 12-week treatment period, which was outmatched by CR BNO 1055 and CE. These effects approached significance, p=0.0506 and p=0.0513 respectively). | NR | NR | NR | NR | Biologically based | This study is often quoted as the one study that shows black cohosh as effected as conjugated estrogen for menopausal symptoms. Clearly this is a misquote as the data did not show statistically significance between any on the 1–10 MRS scale, and only conjugated estrogen was significant in MRS 1–3
| | | | | | 1. Postmenopausal women, 40–60 years of age
| | | | | | 2. BMI < 30
| | | | | | 3. Last menstrual bleeding at least 6 months ago
| | | | | | 4. FSH>25
| | | | | | 5. ≥ 3 hot flushes/day
| | | | | | 6. Menopause rating scale (MRS) items 1–6, sum of scores >1.7 at visits 1 and 2; MRS item 1 (hot flushes) >0.3 at visits 1 and 2.
Wyon, 1995 | 24 | RCT | P | 3 months | “Ordinary” women patients who attended the outpatient clinic because of vasomotor symptoms and were primarily interested in HRT | Inclusion: | Daily symptom dairy; Psychological General Well-Being Index; Sleep Dysfunction Test; modified Kupperman Index | Excluded | Excluded | Excluded | NR | NR | NR | Not allowed | NR | Acupuncture to VB 15, 23, 32; GV20; H7; P6; LIV3; SPG, Each treatment given twice a week for 2 weeks and once week for 6 weeks for 30 minutes each. | Superficial needle insertion | No significant differences were found between groups on any measure, before, during, or 3 months after treatment; Number of hot flushes/day decreased significantly in both groups from before to the first as well as the second treatment period (p=0.013 and 0.0033 in the EA group, p = 0.005 and 0.0093 in the SNI group) | NR | NR | PGWB index did not change significantly in any group during treatment | NR | NR | NR | NR | NR | NR | Visual analog scale decreased significantly in the EA group but not the SNI group (p=0.008); Kupperman Index decreased significantly in both groups (p<0.05) and persisted for 3 months after treatment | 3/24 due to noncompliance with log books | None | None | Alternative Health Systems
| | | | | Median age was 54 with a range from 47–62 | 1. Healthy women with vasomotor symptoms
| | | | | | 2. Natural menopause at least 1 year previously
| | | | | | Exclusion:
| | | | | | 1. Severe metabolic, thromboembolic, or endocrine disease
| | | | | | 2. Uncontrolled hypertension (>95mg Hg diastolic)
Wyon, 2004 | 45 | RCT | HH, P | 12 weeks with 6 month followup | Local newspaper and gynecological clinic in Sweden | Inclusion: | Kupperman Index; visual analog scale; self-reported daily symptom diary of frequency and severity of menopausal symptoms | 4/45 | Excluded | NR | NR | NR | Excluded if exercised > 1 hour/week; 20–31% smokers | NR | 19.5–36.6; average 25.6 – 26.4 | Electro acupuncture (EA) 14 treatments over 10 weeks sites BL 15, 23, 32, HT 7, SP 6, 9 LR 3, PC 6, GV 20 | Conjugated estrogen 0.625mg/day vs. superficial needle insertion (SNI) (sham acupuncture) at Baseline, Week 15, 23, and 32 | Hot flushes decreased in all 3 groups over the 12 weeks (p<0.001); these results persisted at the 6 month followup. | NR | NR | NR | NR | NR | NR | NR | NR | NR | All 3 groups had significant improvement in Kupperman Index and visual analog scale (p<0.001); these results persisted at the 6 month followup | 4/15 in electroacupuncture group; 3/15 in superficial needle insertion group; 6/15 in estrogen group | None | None | Alternative Systems
| | | | | | 1. Healthy women with vasomotor symptoms
| | | | | | 2. Age 48–63 years
| | | | | | 3. Natural menopause ≥ six months prior (4 had hysterectomy, however, none had bilateral oophorectomy)
| | | | | | Exclusion:
| | | | | | 1. Severe metabolic, thrombo-embolic, or endocrine disorders
| | | | | | 2. Severe hypertension (>95mg Hg diastolic)
| | | | | | 3. Use of sedatives, anxiolytics, or antidepressants, or narcotics.
| | | | | | 4. Exercised > 1 hour/week
Yoles, 2002 (Abstract Only) | 102 | RCT | P | 6 months | NR | NR | Detailed questionnaire regarding patients 15 variables of patients menopausal complaints | NR | NR | NR | NR | NR | NR | NR | NR | Tofu based concentrated phytoestrogen | Placebo | Hot flushes decreased in 76% of the patients treated by phytoestrogen vs 19% of placebo group (p<0.001) | NR | Sleep disturbance improved in 69% taking phystoestrogen vs 16% placebo (p<0.001) | Nervousness improved in 56% taking phytoestrogen vs 14% placebo (p<0.001) | NR | NR | NR | NR | NR | NR | 77% decrease in PE group vs 17% in placebo group (p<0.001); no change in endometrial thickness | NR | NR | NR | Biologically based | Done in Israel

Key/Abbreviations

AE = Adverse effects

BDI = Beck Depression Inventory

BMI = Body mass index

BSO = Bilateral Salpingo Oophorectomy

CAM = Complimentary and Alternative Medicine

CE = Conjugated estrogen

CGI = Clinical Global Impression Improvement Scale

CMH = Chinese medicinal herbs

DB = Double blind

EA = Electro acupuncture

ERT = Estrogen replacement therapy

G/D = Genisten and Diadzin combination therapy

GI = Gastrointestinal

HAMA = Hamilton Anxiety Scale

HAM-D-21 = Hamilton Depression Rating Scale

HH = Head to head

HRT = Hormone replacement therapy

HST = Heat stress test

KK = KavaKava

LF = Liposom Forte (phospholipid liposomes)

LMP = Last menstrual period

MENQOL = Menopause Specific Quality of Life Questionnaire

MMPI = Minnesota Multiphasic Personality Inventory

MMSE = Mini-mental Status Examination

MRQ = Menopause Representation Questionnaire

MRS = Menopause rating scale

MSQ = Menopause symptoms questionnaire

MYMOP = Measure Yourself Medical Outcome Profile

NA = Not applicable

NHP = Nottingham Health Profile

NR = Not reported

OC = Oral Contraceptives

P = Placebo

PE = Phytoestrogen

PGWB-I = Psychological General Well-being Index

PL = Pueraria lobata

PMR = Progressive muscle relaxation

POF = Premature ovarian failure

POMS = Profile of Mood States

QoL = Quality of life

R = Reading

RCT = Randomized controlled trial

RDI = Rome Depression Inventory

RR = Relaxation

SAMe = S-adenosyl-L-methionine

SD = Standard deviation

SERMs = Selective Estrogen Receptor Modifiers

SNI = Superficial needle insertion

TCM = Traditional chinese medicine

TIA = Transient ischemic attack

VAS = Visual Analogue Scale

WHLP = Women's Healthy Lifestyle Project

WHQ = Women's Health Questionnaire

Evidence table 6-9. Key Question 4C therapies in women with breast cancer

| | | | | | | | Specific Characteristics of Population | | | | | | | | Treatment | | Main Outcomes
Study/Year | N | Type of Trial | Comparison | Length of Trial | Population | Inclusion/Exclusion Criteria | Measures Used | Hysterectomy (#/n) | Bilateral Oophorectomy (#/n) | Premature Ovarian Failure (#/n) | Breast Cancer (#/n) | Use of SERMS (#/n) | Behavior or Lifestyle Factors (#/n) | Recent discontinuation of HRT (#/n) | High or Low BMI (#/n) | Main Drug type; dose; regimen | Other Drugs type; dose; regimen | Hot Flashes | Vaginal Dryness | Sleep | Mood | Cognitive | Somatic | Urinary | Uterine Bleeding | Sexual Dysfunction | Quality of Life | Other Outcomes | Withdrawals | Withdrawals due to AEs | Adverse Effects | Comments
Barton, 1998 | 125 | RCT cross-over | P | 9 weeks | Women over age 18 with a history of breast cancer. | Inclusion: | Documentation of hot flashes number and severity using a diary questionnaire (cites Bergman, Loprinzi studies). | NR | NR | NR | 100% | 54% | Vitamin use in Table 1 | NR | NR | Vitamin E succinate 800 IU daily for 4 weeks followed by placebo | Placebo for 4 weeks followed by vitamin E | At the end of 4 weeks, HF frequency decreased 25% in vitamin E group as compared to 22% in the P (p=0.90). HF score decreased 28% with vitamin E and 20% with P (p=-0.68). Both groups had statistically significant within group decreases by Wilcoxon's sign rank. | NR | NR | NR | NR | NR | NR | NR | NR | NR | 102 women responded to question about preference at the conclusion of the study: | 4 prior to initiation of drug. | None | No significant differences in reporting of: | 125 women randomized; 5 in the placebo group withdrew before starting their medication.
| | | | | | 1. Hot flashes for ≥ 1 month with a frequency of ≥ 14 times per week. | | | | | | | | | | | | At the end of 9 weeks, vitamin E/P group had decrease in HF frequency and HF score that was greater than the P/vitamin E group, P<0.05, no data given | | | | | | | | | | 32% preferred vitamin E; 29% preferred placebo; 38% did not have a preference. | | | 1. headaches16/120 in vitamin E; 17/120 in P (p=0.85) | RCT cross-over tiral, but stratified by age (18–49 vs 50 and older), current tamoxifen use, duration of hot flashes (>/< 9 mo), average frequency of flushes and current MVI use.
| | | | | | 2. Life expectancy ≥ 6 months. | | | | | | | | | | | | | | | | | | | | | | | | | 2. nausea 11/120 in vitamin E; 11/120 in P (p=0.99)
| | | | | | 3. ECOG performance status of 0 or 1. | | | | | | | | | | | | | | | | | | | | | | | | | 3. fatigue 20/120 in vitamin E; 25/120 in P (p=0.31)
| | | | | | 4. Tamoxifen allowed | | | | | | | | | | | | | | | | | | | | | | | | | 4. other: 18/120 in vitamin E; 13/120 in P (p=0.43).
| | | | | | Exclusion:
| | | | | | 1. Current or planned therapy with corticosteroids, progestational agents, estrogens, androgens, chemotherapy, any other agen used for treating hot flashes, or more than 60 IU of vit E daily.
| | | | | | 2. Pregnant or lactating women.
| | | | | | 3. Women with a history of bleeding tendencies, immune deficiencies or thrombophlebitis.
Barton, 2002 (abstract) | 80 | Open trial | HH | 4 weeks | NR | NR | Hot flash diary: frequency and score (daily frequency × score) | NR | NR | NR | 100% | NR | NR | NR | NR | Venlafaxine, nefazodone, citalopram, mirtazapine | | Venlafaxine decreased HF score to 47% of baseline (n=47) | NR | NR | NR | NR | NR | NR | NR | NR | NR | “these antidepressants appear to ameliorate other menopausal related symptoms such as difficulty sleeping, anger and depression.” | NR | NR | NR | Pilot of 4 anti-depressant medications (venlafaxine, nefazadone, citalopram, mirtazapine)
| | | | | | | | | | | | | | | | | | Nefazadone decreased HF score to 37% of baseline (n=6)
| | | | | | | | | | | | | | | | | | Citalopram decreased HF score to 40% of baseline (n=14)
| | | | | | | | | | | | | | | | | | Mirtazapine decraesed HF score to 38% of baseline
Bertelli, 1999 (abstract) | 71 | Open label Randomized | HH | 6 weeks | NR | 71 post-menopausal breast cancer survivors with at least 7 HF/week. | HF frequency and score | NR | NR | NR | 100% | NR | NR | NR | NR | Depot IM medroxyprogesterone acetate (MPA) 500 mg IM on days 1, 14, and 28 vs oral megestrol acetate (MA) 40 mg/day for 6 weeks. | MPA vs MA | HF frequency was reduced by 87% and HF score was reduced by 89% as compared to baseline, with no significant diffferences between groups. | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | “less side effects were reported with MPA than MA”
| | | | | | | | | | | | | | | | | | Response (>50% reduction in HF) observed in 28/37 (75%) off MPA and 22/34 (64%) of MA groups, p=0.7 | | | | | | | | | | | | | 2 MPA vs 7 MA pts had vaginal bleeding.
| | | | | | | | | | | | | | | | | | Follow-up 6 months after randomization: | | | | | | | | | | | | | 0 MPA vs 6 MA stopped treatment early for toxicity.
| | | | | | | | | | | | | | | | | | 25/28 (89%) of MPA vs 10/22 (42%) MA maintained response (p<0.001).
Carpenter, 2002 | 15 | RCT cross-over | P | 72 hours ecah arm followed by 2 days observation period and 10 day wash-out | Postmenopausal women ≥18 years (some postmenopausal at early age due to chemotherapy) | Inclusion: | 1. HF monitor - ambulatory sternal skin conductance monitoring | NR | NR | NR | 100% | NR | NR | NR | Mean 28.8 (SD 5.7) | 6 magnetic devices attached to participants skin over accupuncture/accupressure sites used to balance energy and treat HF. | Placebo was identical in size, shape and weight (but blinding was not possible due to the distinctive magnetic properties of the treatment devices). | HF frequency decreased from 9.55 ± 6.7 to 8.27 ± 6.56 in the magnet group and from 10.45 ± 5.89 to 6.64 ± 5.82 in the P group (p=0.02). | NR | NR | NR | NR | NR | NR | NR | NR | Overal quality of life was not significantly different between groups. | NR | Only 11 participants (of 15) completed both arms of the study. | Reasons for 4 not completing the 2nd arm of the study. | Several problems were reported in both placebo and magnet arms in first week (27%) | Data not presented prior to cross-over. No wash out period reporte between arms of cross-over.
| | | | | | 1. Women ≥ 18 years | 2. HF diary (number of HF, date/time, severity 0–10, degree of bothered 0–10) | | | | | | | | | Accupressure sites located by 2 licensed accupuncturists. Study nurses affixed devices and covered with gauze and tegaderm magnetic device (hard plastic outer layer with 4 separate magnets of alternating polarity (+,-,+,-). Magna Bloc. | | HF severity showed no significant difference between groups. | | | | | | | | | | | | Perspiration (unable to keep device attached to skin) = 1 | 1 - Perspiration
| | | | | | 2. 1st time diagnosis of breast cancer | 3. HF related daily interference scale (HFRDIS) - 10 item scale measures degree to which HF interferes with 9 daily activities and overall quality of life | | | | | | | | | | | HF botherersome decreased from 4.18 ± 2.41 to 4.07 ± 2.68 for the magent group and from 4.4 ± 2.34 to 3.21 ± 2.85 in the P group (p=0.02) | | | | | | | | | | | | Lack of interest = 2 | 1 - Redness
| | | | | | 3. No other type of cancer | | | | | | | | | | | | HF interference scale was reduced in both groups, but no signficicant differences were found between groups. | | | | | | | | | | | | Itching from tape = 1 | 1 - Itching
| | | | | | 4. Currently free of cancer or competing treatment | | | | | | | | | | | | | | | | | | | | | | | | | By end of 2nd week 6 reported itching.
| | | | | | 5. > 12 months of amenorrhea | | | | | | | | | | | | | | | | | | | | | | | | | Willingness to continue with placebo was 8.2 vs. treatment at 9.3
| | | | | | 6. Expereincing HF
| | | | | | 7. Able to speak, write, and read English
| | | | | | Exclusion:
| | | | | | 1. Contraindication to magnets (i.e. implanted devices)
| | | | | | 2. Concurrent use of magnets for other symptoms
| | | | | | 3. Concurrent use of other HF treatments
Ganz, 2000 | 76 | RCT | Usual Care | 4 months | Mean age: 54.5 years | Inclusion: | 1. Menopausal Symptom Scale Score adapted from the Breast Cancer Prevention Trial Symptom Checklist | NR | NR | NR | 100% | 40 (56%) on Tamoxifen | NR | Excluded if any ERT use within last 3 months. | NR | NP counselling, tailored therapy and support. | Usual Care (UC) | NR | NR | NR | NR | NR | NR | NR | NR | Intervention group had significantly higher change score in CARES sexual functioning scale both unadjusted and adjusted (unadjusted mean change score 0.11 UC vs 0.46 Int, p=0.03) | No differenece in the mean change score for the RAND vitality scale between UC and INT groups (UC 2.3 vs INT 0.8, p=0.72). Same results after adjustment, and after adjustment using clonidine as a covariate. | Change in overall menopause symptom scale was significantly greater in the intervention group (reduced symptoms) as compared to the usual care group (true both for unadjusted scores and score adjusted for age, tamoxifen use, prior chemotherapy, race, partner status ad RAND score): unadjusted mean change score: 0.09 UC vs 0.57 INT, p<0.0001 | 4 people dropped out, all from the intervention group: 2 had family member's illness, 2 developed metastatic disease and became inelligible | None | NR | 1. Groups were random, but not equivalent at baseline: intervention group had lower urinary symptom scores and higher RAND vitality scores (p=0.05 for both).
| | | | | Disease-free, female breast cancer patients between 8 months and 5 years after diagnosis of stage I or II disease | 1. Perimenopausal or postmenopausal (defined by ammenorrhea > 6 months) | 2.Vitality Scale from the RAND 36 Item Health Survey 1.0 (also known as the Medical Outcomes Study SF-36) | | | | | | | | | 1. Assessment: symptom diary, in-depth interview focused on symptoms and influencing factors, and a standardized psychosocial evaluation. | | | | | | | | | | | | | | | | 2. Also, cannot distinguish interventions, as participants could choose from a menu and change within the course of the 4 months.
| | | | | | 2. All chemotherapy or radiation therapy completed ≥ 4 months prior to enrollment, but could be taking tamoxifen | 3. Sexual Summary scale from the Cancer Rehabilitation Evaluation System (CARES) | | | | | | | | | 2. Symptom Management: With help of nurse, patient chose 1 of 3 symptoms to focus on, developed an individualized plan of care that included education, counseling and specific pharmologic and/or behavioral interventions (for HF: pharmacologic = bellergal, clonidine patch, or megestrol; behavioral = slow abdominal breathing; for vaginal dryness: moisturizer or lubricant; for SUI: behavior = Kegel's; pharm = replens, phyenylpropanolamine; for psychosocial problems = referral for counseling or group support | | | | | | | | | | | | | | | | 3. There was contamination of the usual care group: up to 31% started some kind of therapy for symptoms.
| | | | | | 3. Presence of ≥ 1 target symptom that was moderate to severe in intensity | | | | | | | | | | 3. Follow-up: telephone call 2 weeks after intervention, visits at 2 months and 4 months. Patients had ability to change or alter treatment until symptom relief achieved.
| | | | | | 4. Willing to accept behavioral or pharmacologic treatment for ≥ 1 target symptom
| | | | | | Exclusion:
| | | | | | 1. History of other cancers except non-melanoma skin cancer
| | | | | | 2. Serious medical conditions that might influence the assessment of helath related quality of life
| | | | | | 3. An abnormal Pap smear showing dysplasia or more severe changes
| | | | | | 4. curent symptoms of majoy psychiatric illness that were not being treated or were not being controlled with medication.
| | | | | | 5. Inability to read and write English
| | | | | | 6. Active alcohol or substance abuse
| | | | | | 7. Use of ERT within the past 3 months
| | | | | | 8. Major cognitive impairment or inability to provide informed consent
Goldberg, 1994 | 116 | DBRCTX | P | 9 weeks (1week of P to assess baseline 4 weeks C or P then X) | Adult women on tamoxifen for breast cancer with hot flashes. | Inclusion: | Self administered questionnaires of number of hot flashes, severity (mild, mod, severe, or very severe graded 1–4), and drug toxicities. | NR | NR | NR | 116/116 | 116/116 | NR | NR | NR | Clonidine transdermal 0.1 mg/day, patch changed weekly | Patients were on tamoxifen for treatment of breast cancer. | No baseline differences in severity, frequency or hot flash score between C and P groups. | NR | NR | NR | NR | NR | NR | NR | NR | NR | Patient preferences for treatment option noted at the end of the study. 2-to-1 advantage for clonidine was significantly different than 50:50 odds (x2 p=0.02). | 6/116 omitted from analyses (1 ineligible, 1 didn't understand study, 4 failed to submit data) | C was associated with significant increase in dry mouth (p<0.001), constipation (p<0.02), itchiness under the patch (p<0.01) and drowsiness (p<0.05) compared to the week before treatment. | 21/116 omitted from efficacy analyses due lack of data or patch came off Despite unequal losses, baseline characteristics of hot flashes were similar (table 2). | Does not appear to be limited to menopausal women
| | | | | Median age 54 years (30–76). | 1. Hot flashes present >1 month and ≥ 7 per week | Composite score of mean frequency times mean severity. | | | | | | | multiple drug exclusions including hormonal therapies | | | | Statistically significant decrease in median frequency (p<0.04), severity (p<0.03), and hot-flash score (p<0.04) between C and P after first treatment period. (These findings remained significant after crossover.)
| | | | | Stratified by age, duration of tamoxifen use, duration of hot-flash symtpoms, and average frequency /severity of hot flashes. | 2. Life expectancy of ≥ 6 months | Contacted by nurses every 2–3 weeks to assess compliance, toxicities, and answer questions.
| | | | | | 3. ECOG performance status of 0 or 1.
| | | | | | Exclusion:
| | | | | | 1. Many listed
Hernandez Munoz, 2003 | 136 | RCT | HH | 12 months | Women > 35 years attending a breast cancer clinic in Venezuela | Inclusion: | HF diary (number and intensity) | 10% (with retention of the adnexae). | NR | NR | 100% | 100% on tamoxifen | NR | NR | NR | 1 tab bid ofCR BNO 1055 (C racemosa). Each tablet contained 20 mg of the herbal supplement. | All on tamoxifen; appears that control group did not have placebo | At the end of 6 months there was no significant difference in the control group for either moderate or severe HF (5–9% decline, p=0.71 compared to baseline). Results for intervention group are only reported in post-treatment, no comparison to pre treatment rates of symptoms | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | Of 150 that entered the study, 14 decided not to participate in the rest of the study. | NR | 11 “minor” adverse events occurred: 7 in the usual care group and 4 in the intervetnion group." No serious events reported. No list of what the events were. | No placebo in control group
| | | | | | 1. Women > 35 years who were premenstrual | | | | | | | | | | | | | | | | | | | | | | | | | | The control group was allowed to start other therapies for HF after 6 months.
| | | | | | 2. Diagnosis of ER+ breast cancer treated with tamoxifen
| | | | | | 3. Hot flush symptoms
Jacobson, 2001 | 85 | RCT, stratified by tamoxifen use | P | 60 days | Women over age 18 previously treated for breast cancer, who reported experiencing daily hot flases | Inclusion: | 1. Menopausal symptom index | NR | NR | NR | 100% | 59/85 on tamoxifen at baseline | NR | NR | NR | Black cohosh, 1 tablet bid with meals | Women permitted to use other nonhormonal medication while in study, but asked not to initiate new therapy for HF. | 1. mean HF number at end of study (no significant difference by ANOVA): | NR | Included in menopausal symptom scale, both goups improved, not significantly different from each other | Irritability and nervousness and depression included in menopausal symptom scale, both goups improved, not significantly difference from each other | NR | 1. Headaches and palpitations included in menopausal symptom scale, both goups improved, not significantly difference from each other | NR | NR | NR | NR | Safety outcomes were changes in mean levels of FSH and LH: both tamoxifen groups had lower FSH than the non-tamoxifen groups but not statistically significant, and no signficant change; no significant changes in LH levels | 9 participants declined further participation after baseline assessments. | 4 | Lack of change in LH and FSH levels reported. | Randomization procedure described.
| | | | | | 1. Completion of primary therapy including chemo and radiation ≥ 2 months prior. | 2. Changes in LH and FSH from start to end of study | | | | | | | | | | | tam+tx:27.9 | | | | | 2. Excessive sweating improved in both groups but the treatment group reported more improvement that placebo group (p=0.04, wilcoxon test) | | | | | | 16 (includes the 9) failed to complete the HF diary at the end of the study. | | 3 serious AE's occurred: hysterectomy (tam+tx), breast cancer recurrence (tam+tx), appendectomy (tam+placebo)
| | | | | | Exclusion: | 3. Visual analog scale of overall health and well-being. | | | | | | | | | | | tam+placebo: 31.6 | | | | | | | | | | | reasons for drop outs: | | 10 minor AE's occurred: constipation (tam+tx), swolllen finger (tam+placebo), arrhythmia (tx alone), weight gain (tam+tx), endometrial hyperplasia(tam+tx), diliation and currettage(tam+tx), cramping (tx alone), indigestion(tam+tx), vaginal bleeding(tam+tx), and rash on abdomen (tam+placebo).
| | | | | | 1. HRT for HF | 4. HF diary | | | | | | | | | | | tx alone: 26.7 | | | | | | | | | | | 1. Adverse effect 3 tx; 1 placebo
| | | | | | 2. Pregnancy | | | | | | | | | | | | placebo alone: 29.8 | | | | | | | | | | | 2. Forgot pills while traveling 1 tx; 1 placebo
| | | | | | 3. Major psychiatric illness | | | | | | | | | | | | 2. mean HF intensity (no significant difference by ANOVA): | | | | | | | | | | | 3. unknown 5 tx, 5 placebo
| | | | | | 4. Known recurrent or metastatic breast cancer | | | | | | | | | | | | tam+tx: 1.94
| | | | | | | | | | | | | | | | | | tam+placebo:2.06
| | | | | | | | | | | | | | | | | | tx alone: 1.97
| | | | | | | | | | | | | | | | | | placebo alone: 1.74
Kimmick, 2001 (abstract) | 62 | DBRCT | P | 6 weeks | Data from 47 women | Inclusion: | HR frequency and score (frequency × severity) | NR | NR | NR | 100% | 100% on tamoxifen | NR | NR | NR | Sertraline 50 mg qAM | Placebo | At 6 weeks: | NR | NR | NR (in process analyzed according to abstract) | NR | NR | NR | NR | NR | NR (in process analyzed according to abstract) | NR | NR | NR | NR
| | Cross-over | | | mean age 53.9 (range 36.6–77.1) | 1. Women on tamoxifen experiencing ≥ 1 HF/day | | | | | | | | | | | | 36% of women on sertraline (N=25) vs 27% of women on placebo (N=22)reported a decrease in the frequency of HF by 50% (p=0.7)
| | | | | 89% post-menopausal | | | | | | | | | | | | | At 13 weeks:
| | | | | 85.5% Caucasian | | | | | | | | | | | | | Women were asked which tablet/period worked best for their HF: 28% had no preference; 49% preferred sertraline; 11% preferred placebo.
Loprinzi, 1994 | 97 | DBRCT | P | 4 weeks each period, no wash out period between | 97 women with history of breast cancer, 66 men with prostate cancer who had undergone androgen-deprivation therapy. | Inclusion: | HF frequency | NR | NR | NR | 100% | 78/97 women (80%) were using tamoxifen | NR | NR | NR | Megestrol acetate 20 mg twice daily. | Placebo | After 4 weeks (results for women only): | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | Of 100 women enrolled in the trial, 2 were ineligible and 1 withdrew before starting any medication. Approximately 82% of women provided usable data for the analysis of efficacy. | NR | Assessed weekly for vaginal symptoms (dryness, irritation or discharge), change in appetite, fluid retnetion.vaginal bleeding reported as a side effect by 15(31%) women, who got megestrol first and had bleeding while on placebo. No suggestion that megestrol acetate was related to other vaginal symptoms, fluid retention or apetite change. | Stratified by duration of HF (< or > 9 months), type of orchiectomy, duration of androgen ablation (men), age and tamoxifen use (women).
| | | | | | 1. Breast or prostate cancer with either surgical or medical orchiectomy | | | | | | | | | | | | HF frequency was 26% of baseline in megestrol group vs 73% in placebo group, p<0.001.
| | | | | | 2. Bothersome hot flashes | | | | | | | | | | | | Median HF score was 17% of baseline in megestrol acetate group vs 73% of baseline in placebo group, p<0.001.
| | | | | | | | | | | | | | | | | | Reduction of 50% in HF frequency: 71% of megestrol group vs 24% of placebo group, p<0.001. Baseline frequency of HF was 6.1 HF/day (range 0.9–21.4) for women.
Loprinzi, 1997 | 52 | DBRCT | P | 4 weeks each period with 1 week washout between | NR | Inclusion: | Vaginal atrophy index: summed score of vaginal elasticity, secretions, mucosal integrity and moisture collected from pelvic exam. | NR | NR | NR | 100% | NR | NR | NR | NR | Replens daily for 5 days in 1st week, then 3×/week for next 3 weeks. | Placebo consisting of hydroxymethyl-cellulose, glycerin-delta lactone, hydrogenated palm oil glyceride and water. | NR | Vaginal dryness scores improved in both groups (decreased by 64% in Replens group and 62% in placebo group after 4 wks, p=0.3). | NR | NR | NR | NR | NR | NR | Dyspareunia scores decreased in both groups after 4 weeks: decreased 60% in Replens group and 41% in placebo group, p=0.05. | NR | Vaginal itching: not present at baseline in the majority of women and no significant impact of either Replens or placebo on this symptom. | Of 52 patients entering trial, 1 patient canceled before receving any therapy and 6 patients did not answer any of the weekly questionnaires. | 7 of the 45 patients terminated their participation before the end of full 9-week period. Anecdotal evidence suggests that patients did not like “feeling wet” and that amount of agent and/or discomfort with applicator contirubted to their decision to quit the study. | NR | Patients stratified by 1) age, 2) whether they were receiving current chemo or hormonal therapy and 3) pt perception of vaginal symptoms (mild, moderate, severe).
| | Cross-over | | | | 1. Women > 18 years with a history of breast cancer and significant vaginal complaints defined as persistent vaginal dryness and/or itching | Questionnaire grading symptoms of vaginal dryness, itching and discomfort during intercourse. | | | | | | | | | During washout period, placebo was given 3×/week. | | | No further substantive changes in vaginal dryness in either study arm. | | | | | | | During cross-over period, there were no further substantial changes in either arm for dyspareunia scores compared with the end of the first 4-week period. | | Participants asked which lubricant worked best: of 36 responding, 41% chose Replens, 24% chose placebo and 35% had no preference (p=0.68).
| | | | | | 2. Symptoms present for > 2 months.
| | | | | | Exclusion:
| | | | | | 1. Evidence of active vaginal infection
| | | | | | 2. Current antineoplastic therapy with estrogen
| | | | | | 3. Pregnancy or lactation
| | | | | | 4. Previous use of Replens
| | | | | | 5. Planned use of any vaginal preparation during study period
| | | | | | 6. Use of any vaginal product during prior 1 week.
Loprinzi, 2000 | 229 (191 with data) | RCT | P | 4 weeks | Breast cancer or perceived high risk of breast cancer | Inclusion: | Daily hot flash score (frequency × severity 1–4); hot flash frequency; Beck depression inventory; uniscale QOL instrument | NR | NR | NR | NR | NR | NR | NR | NR | Venlafaxine 37.5mg (V 37.5) | Placebo | See table 1. (Reduction in score and frequency for all arms compared to placebo) | NR | NR | BDI reduction: | NR | NR | NR | NR | All improved; NS between arms. | Tx: +3; | | 8 prior to study; | NR | Dry mouth, decreased appetite, nausea, and constipation more in tx. No difference in tiredness, dizziness, nervousness, mood changes, sweating, sleepiness or sleep trouble.
| | | | | | 1. > 14 bothersome hotflashes per week for ≥ 1 month (but no menopause criteria needed) | | | | | | | | | | Venlafaxine 75mg (V 75) | | | | | P = 1.6; | | | | | See figure 5. | P:-3; p=0.02 | | P - 6; V 37.5 - 7; V 75 - 12; V 150 - 5
| | | | | | 2. Age 18 or over | | | | | | | | | | Venlafaxine 150mg (V 150) | | | | | V 37.5 = 2.4;
| | | | | | 3. Breast cancer or perceived increased risk of breast cancer | | | | | | | | | | | | | | | V 75 = 4.8;
| | | | | | 4. Performance status of 0–1 on ECOG | | | | | | | | | | | | | | | V 150 = 3.2. NS
| | | | | | 5. Tamoxifen and raloxifene o.k. if started 4 weeks prior to study and continued for 5 weeks
| | | | | | 6. Not on chemo, estrogens, androgens, progestins, antidepressants, clonidine, Bellergal.
| | | | | | Exclusion:
| | | | | | 1. Venlafaxine ever
| | | | | | 2. Antidepressants past 2 years
| | | | | | 3. Pregnancy, breastfeeding
| | | | | | 4. Other hot flash treatments in past 2 weeks
| | | | | | 5. Uncontrolled HTN.
Loprinzi, 2002 | 81 | RCT - cross-over | P | 2 periods; 4 weeks per period | Breast cancer or perceived high risk of breast cancer | Inclusion: | Daily hot flash score (frequency × severity 1–4); hot flash frequency; Beck depression inventory; uniscale QOL instrument | NR | NR | NR | NR | NR | NR | NR | NR | Fluoxetine 20mg | Placebo | Not significant at end of 4-week period | NR | Trouble sleeping : 44% Fluoxetine, 71% P, p=0.03 for 1st study period only. | Trend for lower BDI scores with Fluoxetine (p=0.08); dichotomous analysis NS | NR | NR | NR | NR | Fluoxetine: 1 decreased, 11 increased; | NS (see p.1581) | | 6 prior to study; 9 had no baseline data (5 placebo, 4 tx); 5 hadno 5 week data (1 P, 4 tx); 2 had no 9 week data (1 P, 1 tx). | NR | Dry mouth (45 vs 23%, p=0.07); no difference in appetite, nausea, dizziness, constipation, nervousness, mood changes, fatigue, abnormal sweating. Sleep improved in period one on tx.
| | | | | | 1. > 14 bothersome hotflashes per week for ≥ 1 month (but no menopause criteria needed) | | | | | | | | | | | | Cross-over analysis: | | Not significant overall | | | | | | Placebo: 3 decreased, 9 increased.
| | | | | | 2. Breast cancer or perceived increased risk of breast cancer | | | | | | | | | | | | median Hot Flash frequency reduction 1.5 (19%, p=0.01) and score reduction 3.1 (24%, p=0.02)
| | | | | | 3. No current evidence of malignant disease
| | | | | | 4. Not on chemo, estrogens, androgens, progestins or coumadin
| | | | | | 5. Tamoxifen or raloxifene ok as long as planning to continue for duration of study
| | | | | | 6. No previous use of fluoxetine
| | | | | | 7. No antidepressants for 2 years
| | | | | | 8. No other treatments of hot flashes
Nikander, 2003 | 62 | RCT cross-over | P | 3 months | Women being treated for beast cancer at university hospital who volunteered for study. | Inclusion: | 1. Kuperman Index | 10 (18%) | NR | NR | 100% | 3/56 (5.4%) used tamoxifen ≥5 months prior | 13 (23%) smoking | 22/56 (39.3%) had used HRT at some point ≥5 months prior | NR | 114 mg phytoestrogen (6 tab/day total, 3 bid) | Placebo | Kupperman Index decreased significantly in both groups compared to baseline: by 4.2±9.6 (15.5%) in phytoestrogen group and by 4.0±8.1 (14.7%) in the P group. | NR | NR | No significant decrease in anxiety among either P or phytoestrogen group. | NR | NR | NR | NR | NR | No effect on working ability or self confidence | No change in overall severity of menopausal symptoms by VAS: 55.7±20 before (all); 46.5±26.5 after phytoestrogen; 49.3±23 after placebo (p=0.469). | 6 people withdrew: 4 phytoestrogen group (2 stomach ache, 1 recurrent breast cancer, 1 personal); 2 in placebo group (1 lack of effect, 1 vaginal bleeding) | 2 women in phytoestrogen group withdrew because of GI AE (stomach ache); 1 woman in the P group withdrew because of vaginal bleeding | Stomach ache | Serum values reported: daidzein, genistein, equol.
| | | | | Mean age: 54±6, range 35–69. | 1. No residual malignant disease | 2. Severity of menopausal symptoms with 10 cm long visual analogue scale. | | | | | | | | | | | Not significantly different between groups | | | | | | | | | | 25 (44.6%) preferred the phytoestrogen; 15 (26.8%) preferred placebo; 16 (28.6%) had no preference | | | | RCT cross-over with 2 month wash-out between each 3 month treatment period
| | | | | Age at diagnosis of breast cancer 49.9±7.8 (range 29.9–68.1). | 2. Incapacitiating climacteric complaints | 3. Self-rating 1–5 of 5 physical and mental working capacity, and present overall work capacity (scale of 1–10) in relation to lifetime best. These all factored into Work Ability Index. | | | | | | | | | | | HF not different when evaluated separately.
| | | | | | 3. FSH>30 U/L | 4. Depressive mood | | | | | | | | | | | Intensity of HF was significantly decreased in P group (-0.3, p=0.006) but not in phytoestrogen group.
| | | | | | Exclusion: | 5. Anxiety
| | | | | | 1. Use of sex steroids including tamoxifen | 6. Self-confidence
| | | | | | 2. Use of natural products with possible estrogenic activity
| | | | | | 3. Use of drugs possibly affecting climacteric symptoms, metabolism or absorption of drug (ie abx)
Pandya, 2000 | 198 | RCT | P | 12 weeks (8 weeks of intervention and follow up 4 weeks later) | Postmenopausal women on tamoxifen for breast cancer with hot flushes | Inclusion: | Patient diary daily at baseline, and weeks 4, 8 and 12. Number, severity (mild, moderate, severe, or very severe, grade 1–4) and duration of hot flashes. Combined score (mean frequency × mean severity). | NR | NR | NR | 198/198 | 198/198 | NR | NR | | Clonidine 0.1 mg tab at bedtime | Patients were on tamoxifen for at least one month for treatment of breast cancer. | No baseline differences in severity, frequency or hot flash score between C and P groups. | NR | Reported as a side effect. Increased difficulty sleeping was reported by 41% on C and 21% on P (p=0.02) | NR | NR | NR | NR | NR | NR | Quality of life scores improved in the C group compared to P at weeks 4 (p=0.003) and 8 (p=0.022). No difference in median score. | Effects of clonidine by the stratification variables duration of tamoxifen use and years past menopause. | States patient withdrawals were due to patient preference | 45/198 did not complete the full 12 weeks of the study, 31/198 did not complete the 8-week intervention. | Participants were asked to complete a symptom checklist including 18 potential side effects. The only diffference was in difficulty sleeping. | Alternate analyses were done to account for patient drop outs/missing data. The results were similar except for 1) QOL at 8 weeks (p=0.082) and 2) significantly greater benefit of C for hot flash symptoms and QOL at 12 weeks.
| | | | | Mean age 53 in C group, 55 in P group (p=0.15) Range 35–77 | 1. Postmenopausal women on tamoxifen for breast cancer for ≥ 1 month with ≥ 1 hot flash daily. | Symptom checklist for 18 potential side effects (grade 0–4). | | | | | | multiple drug exclusions including hormonal therapies | | | | | Statistically significant decrease in mean frequency at weeks 4 (p=0.001) and 8 (p=0.006) and hot flash score at weeks 4 (p=0.002) and 8 (p=0.006). | | | | | | | | | | States blood pressure was not adversely affected. | | 4/198 randomized but did not provide baseline data and were considered unevaluable.
| | | | | Stratified by time since menopause, duration of tamoxifen therapy, and baseline frequency of hot flushes. | Exclusion: | Quality of life on a scale from 1 (worst possible life) to 10 (best possible life). | | | | | | | | | | | Statistically significant difference in hot flash duration at week 12 (p=0.023).
| | | | | Recruited from clinical practices of medical oncologists from participating NCI Community Clinical Oncology Programs. | 1. Premenopausal women | Blood pressure. | | | | | | | | | | | No siginifcant difference in hot flash severity at weeks 4, 8, or 12.
| | | | | | 2. Women on chemotherapy or other endocrine therapy for breast cancer
| | | | | | 3. Multiple other exclusions
Quella, 1998 | 132 | Retrospective | None (open label for long term follow-up) | Contact was 3 years after end of initial study | 74 men; 58 women | Inclusion: | Telephone interview, unclear how data elicited | NR | NR | NR | NR | NR | NR | NR | NR | Megestrol acetate: doses ranged from <20mg/day to 160 mg/day. | N/A | Of 59 patients taking megestrol: | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | Reasons for discontinuation of the drug (men and women combined): | Toxicity: | Retrospective data collection of pts participating in an RCT placebo controlled trial of megestrol acetate; at the end of that trial all patients were given option to take open label megestrol at the lowest dose necessary to control HF.
| | | | | 55 (93%) had been on megestrate continually for 3 years. | 1. Female breast cancer survivors and male prostate cancer survivors who underwent androgen depreivation therapy. | | | | | | | | | | | | 7 women were experiencing break through HF; 6 women stated that HF were infrequent and mild; 10 patients (M and W) were experiencing daily HF and 3 notes several HF/day which were occasionally severe | | | | | | | | | | | | no benefit: 17 | 3 women (17%) had chillls once their HF were eliminated. | Where given data reported for women. Other SE occurred in men (1 had headaches, 1 indigestion, 1 RLE thromboembolic event). Where data not broken down, reported here as M and W.
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | vaginal spotting/bleeding/carmping: 14 | 5 women reported appetite stimulation
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | taking too many other drugs: 13 | 16 men and women listed weight gain as a possible side effect (8 reported wt gain of <10 lbs; 8 reported 10–20 lb weight gain).
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | HF resolved: 12 | 5 women (28%) reported abnormal vaginal bleeding
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | wt gain/appetite stimulation : 9 | 3 women (17%) complained of intermittent mild fluid retention, bloating and cramping without bleeding.
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | chills: 5 | 1 womean experienced an increase in blood pressure.
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | drug too expensive: 4
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | depression: 4
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | severe hand/wrist numbness/tingling: 3
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Hand/wrist numbness/tingling was attributed to carpal tunnel, a syndrome previously associated with megestrol.
| | | | | | | | | | | | | | | | | | | | | | | | | | | | | | Symptoms resolved within 4–6 weeks of withdrawing the drug.
Quella, 2000 | 182 | RCT, cross-over after 4 weeks | P | 9 weeks | Women age 18 and older with history of breast cancer but no residual maligant disease. | Inclusion: | 1. Frequency and intensity of hot flashes | NR | NR | NR | 100% | 68 (78%) on tamoxifen | NR | Excluded | NR | 600 mg tablets containging 50 mg of soy isoflavones: 40–45% genistein, 40–45% diadzein, and 10–20% glycitein. Subjects instructed to take 1 tablet TID (total of 150mg isoflavones/day). Soy phytoestrogen and placebos provided by pharmavite, Mission Hills, CA. | Placebo | ANOVA for HF score and frequency produced non-significant p values for all treatment effect comparisons, regardless of period, sequence, or week of observation. | NR | NR | NR | NR | NR | NR | NR | NR | NR | No difference in percent of patients reporting daily use of medications (compliance) and percentage reporting having missed <10% of pills for soy vs. placebo. | 149 (85%) had usable data at the end of 9 weeks. | None | No difference in toxicity between the two study arms: diarrhea, nausea, vomiting or bloating/gas | 1. Authors do not present results separately after the 1st 4 wks, prior to cross over. They appear to have combined groups for analyses of treatment group vs placebo, which would have biased results toward positive (and this was a negative study even with combining).
| | | | | | 1. Tamoxifen or raloxifene allowed if started 4 weeks prior and planning to continue through the trial. | 2. Toxicity: diarrhea, nausea, vomitting, gas/bloating, other | | | | | | | | | | | Among pateints receviving placebo, 36% reported that HF frequency had been cut in half compared with only 24% of patients receiving soy (p=0.01). | | | | | | | | | | | | | | 2. There was no wash-out period between cross over treatments.
| | | | | | 2. All suffering from HF ≥ 14 times/wk and “of such severity to warrant intervention” and HFfor ≥ 1 month. | 3. Compliance
| | | | | | 3. Life expectancy ≥ 6 months
| | | | | | 4. ECOG=0 or 1.
| | | | | | Exclusion:
| | | | | | 1. Curent treatment with antineoplasitc chemotherapies, androgens, estrogens, prgestational agesnts, or corticosteroids
| | | | | | 2. Use of any other agent to treat hot flashes such as megestrol acetate, vitamin E and belladonna, phenobarbital and ergotamine tartrate, or other soy products.
Secreto, 2004 | 262 | DB RCT | HH & P | 3 months | Women age 49–57 years in Italy | Inclusion: | Greene Climacteric Scale | Included | Included | NR | Included | Excluded | NR | None for 3 months prior | Mean was 23.8 – 25.0 for groups with variation of 21.5–26.8 | Group 1: midday, isoflavones 40mg; evening, isoflavones 40mg+melatonin 3 mg; | Group 4: midday and evening, placebo | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | Greene Climacteric Scale as a whole and subscales were nearly identical between groups at baseline. Decrease of 30% in Greene Score in placebo group; 25% in melatonin alone group; 32% in isoflavone alone group; and 34% in isoflavones and melatonin group; No statistically significant difference between groups in the total score or sub scores. | 4/65 withdrew from isoflavone + melatonin group; 5/64 withdrew from isoflavone group; 12/66 withdrew from melatonin + placebo group; 9/67 withdrew from placebo group | 3/65 from isoflavone and melatonin group; 2/64 from isoflavone alone group; 4/66 from melatonin group; and 3/67 from placebo group; 9 were lost to follow-up; 8 discontinued for other reasons | Not stated | Each isoflavone capsule contained 300mg of soy extract, equivalent to 40mg of isoflavones, in the following rations: daidzein 50%, glycitein 35% and genistein 15% (Soy life Nederland BV, 4283 ZG Geissen, The Netherlands
| | | | | | 1. Postmenopausal women aged > 35 | | | | | | | | | | Group 2: midday and evening, isoflavones 40mg;
| | | | | | 2. Last menstrual flow ≥ 6 months before recruitment | | | | | | | | | | Group 3: midday, placebo; evening, melatonin 3mg
| | | | | | 3. Any condition for which classic HRT is not recommended
| | | | | | 4. Written informed consent
| | | | | | Exclusion:
| | | | | | 1. Breast cancer therapy (hormone or chemotherapy) or RT during the previous 3 months
| | | | | | 2. Overt endocrinopathy (diabetes mellitus, hyperthyroidism, etc.)
| | | | | | 3. Intolerance to soy
Thompson, 2002 (abstract only) | 53 | DB RCT | P | 16 weeks | Women with breast cancer with menopausal symptoms | Not listed | Measure Yourself Medical Outcome Profile (MYMOP), Hospital Anxiety and Depression score, European Organization for Research and Treatment in Cancer Quality of Life Score, Menopausal Symptom Scale | NR | NR | NR | Included | NR | NR | NR | NR | Homeopathic intervention | Placebo | Both groups showed significant improvement over the study period by an average of 80%. No statistically significant difference betweeen groups | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | 8/43 | NR | NR | Abstract only; included as only homeopathic RCT that could be found.
Van Patten, 2002 | 157 | RCT | P | 12 weeks | 263 eligible women; 157 randomized; 123 completed the study (59 soy, 64 placebo). | Inclusion: | 1. Frequency and intensity (0–5 scale) of HF, daily diary. | “Hyster-ectomy + ooph-orectomy” | NR | NR | 100% | Tamoxifen use: | NR | (No use for 4 months prior to start of study): | Mean BMI: | Average concentration of isoflavone in the soy veberage was 45 +13mg/250mL; isoflavones were undetectable in the rice beverage. Total isoflavones consumed by soy women: 90 mg/day. | Placebo | None of the HF reductions were significantly different between groups. | NR | NR | NR | NR | NR | NR | Only reported as an adverse effect of treatment with soy (see AE column). | NR | NR | On the study exit questionnaire, a large number of women in both soy and placebo groups perceived a marginal decrease in HF number in the day (54%soy vs 58%P) and night (48%soy vs 56%P), and in the severity of HF in the day (50%soy vs 56%P) and night (52%soy vs 55%placebo). | After randomization 34 (22%) women dropped out of the study. | 10 women dropped out because of intolerance to study beverage (7 from soy group; 3 from placebo). | Frequent and severe gastrointestinal side effects in soy group: overall 28 soy women reported GI AE; 14 P women reported GI AE (list includes abdominal bloating, gas/flatulence, constipation, gastritis, diarrhea, nausea, vomiting, heartburn). This does not include the 10 women who dropped out of the study for intolerance (7 soy; 3 P). | No mention of intention to treat, but negative study anyway.
| | | | | Age at study entry 55.5+6.3; P 54.9+6.5. | 1. Breast cancer with completion of treatment >4 months prior | | soy 23 (39%) | | | | soy - 9(15%) | | soy 26 (44%) | soy (n=59) 26.8+4.5 | | | 24 hour HF number and score baseline vs final 4 weeks of treatment: number: soy (7.1+ 4.3 vs 5.3 +4.1); placebo (7.4+6.4 vs 4.9+3.9). | | | | | | | | | | At completion, only half of the women in the soy and placebo groups (48% and 52% respectively) could correctly identify wich beverage they were consuming. | | 25 dropped out because of time commitment | Weight gain occurred equally in both groups (5 soy vs 4 P). | Other CAM and Rx therapies commmon in both group: black cohosh, wild yam, red clover 3 or fewer; flaxsee and SSRI 6 women; vit E and primrose oil more common but equal in both groups.
| | | | | Conducted in Canada | 2. No use of HRT for >4 months | | P 28 (44%) | | | | P - 6 (9%) | | placebo 28 (44%) | placebo (n=64) 26.6+4.2 | | | Score (intensity × frequency): soy (18.0+13.9 vs 12.6+13.4); placebo 18.9+18.9 vs 11.4+11.3). | | | | | | | | | | | | 6 dropped out for other reasons | Vaginal spotting was reported by 4 women consuming soy and 1 consuming placebo. | Serum values reported.
| | | | | | 3. Tamoxifen allowed | | | | | | | | | | | | (also reported for day and night, also NS change). | | | | | | | | | | | | 9 women became inellgible after randomization (6 had insufficient HF, 2 had regular consumption of soy; 1 had IBD).
| | | | | | 4. Troublesome HF: score>10/wk (frequency × intensity).
| | | | | | 5. Other medications + CAM allowed if no change in >4 months.
| | | | | | Exlusion:
| | | | | | 1. Smokers
| | | | | | 2. Use of abx
| | | | | | 3. Diagnosis of IBD, liver impairment or recurrent breast cancer
| | | | | | 4. Allergy to or regular consumption of soy

Abbreviations

AE = Adverse Effect

BMI = Body mass index

C = Clonidine

CAM = Complimentary and alternative medicine

ECOG = Eastern Cooperative Oncology Group Scale

ER + = Estrogen Receptor Positive

ERT = Estrogen replacement therapy

GI = Gastrointestinal

HF = Hot flash

HH = Head to head

HRT = Hormone Replacement Therapy

HTN = Hypertension

IBD = Irritable Bowel Disorder

INT = Intervention

MVI = Multivariate

NR = Not reported

NS = Not significant

P = PlacebO

QoL = Quality of life

RAND = RAND Mental Health Inventory

RCT = Randomized Controlled Trial

SD = Standard deviation

SERMs = Selective Estrogen Receptor Modifiers

tam = Tamoxifene

tx = Treatment

UC = Usual care