# Appendix D. Inclusion and Exclusion Criteria

Criteria for Reviewing Abstracts

Key Question 1 (Symptoms)

Include | Relevant to question
| Cohort, cross-sectional, review, meta-analysis, or unclear study design
| Community or population based
| U.S. applicable
| Appropriate sample size
| Mid-aged females
| Undergoing menopause
Exclude | Not relevant to question
| Wrong design
| No data
| Wrong population
| Paper only available in non-English language
| Comment or opinion

Key Question 2 (Symptom characteristics and influencing factors)

Include | Relevant to question
| Cohort, cross-sectional, review, meta-analysis, or unclear study design
| Community or population based
| U.S. applicable
| Appropriate sample size
| Mid-aged females
| Undergoing menopause
Exclude | Not relevant to question
| Wrong design
| No data
| Wrong population
| Paper only available in non-English language
| Comment or opinion

Key Question 3 (Benefits and adverse effects of treatments)

Include | Relevant to question
| RCT, review, or meta-analysis
| One or more listed interventions
| One or more menopause-related outcomes
| Perimenopausal or menopausal women
Exclude | Not relevant to question
| Wrong study design
| No data
| Wrong population: premenopausal or postmenopausal women or men
| Available in non-English language
| Nonhuman/animal
| Methodological fatal flaw
| Comment or opinion

Key Question 4 (Specific characteristics and treatments)

Include | Relevant to question
| RCT, review, or meta-analysis
| One or more listed interventions
| One or more menopause-related outcomes
| Perimenopausal or menopausal women
Exclude | Not relevant to question
| Wrong study design
| No data
| Wrong population: premenopausal or postmenopausal women or men
| Available in non-English language
| Nonhuman/animal
| Methodological fatal flaw
| Comment or opinion

Criteria for Reviewing Full-Text Papers

Key Question 1 (Symptoms)

Include | Cohort, cross-sectional, review, or meta-analysis
| Peri, currently menopausal women, or early postmenopausal women with symptoms
| Describes one of the symptoms in key question 1
| Population based
| Data specific to women
| Appropriate outcomes measures
| N ≥ 100
Exclude | Major concurrent disease

Key Question 2 (Symptom characteristics and influencing factors)

Include | Cohort, cross-sectional, review, or meta-analysis
| Peri, currently menopausal women, or early postmenopausal women with symptoms
| Describes one of the symptoms in key question 1 and/or one of the factors in key question 2
| Population based
| Data specific to women
| Appropriate outcomes measures
| N ≥ 100
Exclude | Major concurrent disease

Key Question 3 (Benefits and adverse effects of treatments)

Include | RCT, review, or meta-analysis
| Peri, currently menopausal women, or early postmenopausal women with symptoms
| Describes one of the treatments in key question 3
| Appropriate agent (currently available, non-injectable, etc.)
| Dose explicitly stated
| Appropriate length of treatment (e.g. ≥ 12 weeks for estrogen use)
| Data specific to women
| Appropriate outcome measures
| Appropriate power (N)
Exclude | No major concurrent disease

Key Question 4 (Specific characteristics and treatments)

Include | RCT, review, or meta-analysis
| Peri, currently menopausal women, or early postmenopausal women with symptoms
| Describes one of the specific characteristics in key question 4
| Appropriate agent (currently available, non-injectable, etc.)
| Dose explicitly stated
| Appropriate length of treatment (e.g. ≥ 12 weeks for estrogen use)
| Data specific to women
| Appropriate outcome measures
| Appropriate power (N)
Exclude | No major concurrent disease