# Appendix C. Literature Search Strategies

KQ1 MEDLINE

Searched 1966 through mid-November 2004

Cognitive

Database: Ovid MEDLINE(R)

Search Strategy:

1. CLIMACTERIC/
2. MENOPAUSE/
3. 1 or 2
4. exp Neurobehavioral Manifestations/
5. 3 and 4
6. cognit$.mp. [mp=title, original title, abstract, name of substance, mesh subject heading]
7. 3 and 6
8. exp Delirium, Dementia, Amnestic, Cognitive Disorders/
9. 3 and 8
10. 5 or 7 or 9
11. limit 10 to english language
12. 10 not 11
13. limit 12 to abstracts
14. 11 or 13

Depression

Database: Ovid MEDLINE(R)

Search Strategy:

1. CLIMACTERIC/
2. MENOPAUSE/
3. 1 or 2
4. CLIMACTERIC/px [Psychology]
5. MENOPAUSE/px [Psychology]
6. 4 or 5
7. DEPRESSION/
8. exp Depressive Disorder/
9. 7 or 8
10. 6 or 9
11. 3 and 10
12. limit 11 to english language
13. 11 not 12
14. limit 13 to abstracts
15. 12 or 14

Mood

Database: Ovid MEDLINE(R)

Search Strategy:

1. CLIMACTERIC/
2. MENOPAUSE/
3. 1 or 2
4. exp Affect/
5. exp Mood Disorders/
6. mood$.mp.
7. 4 or 5 or 6
8. 3 and 7
9. exp EMOTIONS/
10. 3 and 9
11. 8 or 10
12. limit 11 to english language
13. 11 not 12
14. limit 13 to abstracts
15. 12 or 14

Ovarian Aging

Database: Ovid MEDLINE(R)

Search Strategy:

1. climacteric/ or menopause/
2. exp OVARY/
3. exp AGING/ or exp CELL AGING/
4. senescen$.mp.
5. 3 or 4
6. 1 and 2 and 5

Quality of Life

Database: Ovid MEDLINE(R)

Search Strategy:

1. CLIMACTERIC/
2. MENOPAUSE/
3. 1 or 2
4. “Quality of Life”/
5. 3 and 4
6. (qualit$ adj5 (life or living)).mp. [mp=title, original title, abstract, name of substance, mesh subject heading]
7. 3 and 6
8. 5 or 7
9. exp Life Change Events/
10. 3 and 9
11. 8 or 10
12. limit 11 to english language
13. 11 not 12
14. limit 13 to abstracts
15. 12 or 14

Sexual Function

Database: Ovid MEDLINE(R)

Search Strategy:

1. CLIMACTERIC/
2. MENOPAUSE/
3. 1 or 2
4. exp sex disorders/
5. 3 and 4
6. exp “Sexual and Gender Disorders”/
7. 3 and 6
8. (sex$ adj3 (disorder$ or dysfunctio$ or function$)).mp. [mp=title, original title, abstract, name of substance, mesh subject heading]
9. 3 and 8
10. (sex$ adj3 activ$).mp. [mp=title, original title, abstract, name of substance, mesh subject heading]
11. 3 and 10
12. exp Sexual Behavior/
13. 3 and 12
14. 5 or 7 or 9 or 11 or 13
15. limit 14 to english language
16. 14 not 15
17. limit 16 to abstracts
18. 15 or 17

Sleep

Database: Ovid MEDLINE(R)

Search Strategy:

1. CLIMACTERIC/
2. MENOPAUSE/
3. 1 or 2
4. exp Sleep Disorders/
5. 3 and 4
6. exp SLEEP/
7. 3 and 6
8. 5 or 7
9. (sleep$ or slept).mp. [mp=title, original title, abstract, name of substance, mesh subject heading]
10. 3 and 9
11. insomn$.mp. [mp=title, original title, abstract, name of substance, mesh subject heading]
12. 3 and 11
13. 5 or 8 or 10 or 12
14. limit 13 to english language
15. 13 not 14
16. limit 15 to abstracts
17. 14 or 16

Somatic

Database: Ovid MEDLINE(R)

Search Strategy:

1. CLIMACTERIC/
2. MENOPAUSE/
3. 1 or 2
4. exp pain/
5. somat$.mp.
6. 4 or 5
7. 3 and 6
8. limit 7 to english language
9. 7 not 8
10. limit 9 to abstracts
11. 8 or 10

Urination

Database: Ovid MEDLINE(R)

Search Strategy:

1. CLIMACTERIC/
2. MENOPAUSE/
3. 1 or 2
4. exp Urination Disorders/
5. 3 and 4
6. incontinen$.mp. [mp=title, original title, abstract, name of substance, mesh subject heading]
7. 3 and 6
8. 5 or 7
9. urinat$.mp. [mp=title, original title, abstract, name of substance, mesh subject heading]
10. 3 and 9
11. 8 or 10
12. limit 11 to english language
13. 11 not 12
14. limit 13 to abstracts
15. 12 or 14

Uterine Bleeding

Database: Ovid MEDLINE(R)

Search Strategy:

1. CLIMACTERIC/
2. MENOPAUSE/
3. 1 or 2
4. exp Uterine Hemorrhage/
5. 3 and 4
6. (((uterine or uterus) adj5 (bleed$ or bled or hemorrhag$)) or menorrhag$).mp.
7. 3 and 6
8. 5 or 7
9. limit 8 to english language
10. 8 not 9
11. limit 10 to abstracts
12. 9 or 11

Vaginal Dryness

Database: Ovid MEDLINE(R)

Search Strategy:

1. CLIMACTERIC/
2. MENOPAUSE/
3. 1 or 2
4. (vagina$ adj5 dry$).mp. [mp=title, original title, abstract, name of substance, mesh subject heading]
5. 3 and 4
6. exp VAGINA/mi, bs, ph, pp, en, se, ir, me [Microbiology, Blood Supply, Physiology, Physiopathology, Enzymology, Secretion, Innervation, Metabolism]
7. 3 and 6
8. 5 or 7
9. limit 8 to english language
10. 8 not 9
11. limit 10 to abstracts
12. 9 or 11

Vasomotor

Database: Ovid MEDLINE(R)

Search Strategy:

1. MENOPAUSE/
2. CLIMACTERIC/
3. 1 or 2
4. vasomotor.mp. or exp vasomotor system/
5. 3 and 4
6. (hot flash$ or hot flush$ or night sweat$).mp. [mp=title, original title, abstract, name of substance, mesh subject heading]
7. Body Temperature Regulation/ or SWEATING/
8. 6 or 7
9. 3 and 8
10. 5 or 9
11. limit 10 to english language
12. 10 not 11
13. limit 12 to abstracts
14. 11 or 13

KQ1 PSYCHINFO

Searched 1974 through May 2004

Cognitive

Database: PsycINFO

Search Strategy:

1. (menopaus$ or climacter$ or perimenopaus$).mp. [mp=title, abstract, heading word, table of contents, key concepts]
2. (cognit$ or memor$ or dement$).mp. [mp=title, abstract, heading word, table of contents, key concepts]
3. 1 and 2

Mood

Database: PsycINFO

Search Strategy:

1. (menopaus$ or climacter$ or perimenopaus$).mp. [mp=title, abstract, heading word, table of contents, key concepts]
2. exp emotional states/
3. (mood$ or depress$ or anxi$ or irritab$).mp. [mp=title, abstract, heading word, table of contents, key concepts]
4. 2 or 3
5. 1 and 4

Quality of Life

Database: PsycINFO

Search Strategy:

1. (menopaus$ or climacter$ or perimenopaus$).mp. [mp=title, abstract, heading word, table of contents, key concepts]
2. exp “quality of life”/ or exp life satisfaction/ or exp lifestyle/ or exp lifestyle changes/ or exp well being/
3. (qualit$ adj3 life).mp. [mp=title, abstract, heading word, table of contents, key concepts]
4. 2 or 3
5. 1 and 4

Sexual Function

Database: PsycINFO

Search Strategy:

1. (menopaus$ or climacter$ or perimenopaus$).mp. [mp=title, abstract, heading word, table of contents, key concepts]
2. exp Sexuality/ or exp Psychosexual Behavior/
3. (sex$ adj3 (function$ or dysfunction$ or activ$)).mp. [mp=title, abstract, heading word, table of contents, key concepts]
4. 2 or 3
5. 1 and 4

Sleep

Database: PsycINFO

Search Strategy:

1. (menopaus$ or climacter$ or perimenopaus$).mp. [mp=title, abstract, heading word, table of contents, key concepts]
2. sleep$.mp. [mp=title, abstract, heading word, table of contents, key concepts]
3. (insomn$ or hypersomn$).mp. [mp=title, abstract, heading word, table of contents, key concepts]
4. (awak$ or wak$).mp. [mp=title, abstract, heading word, table of contents, key concepts]
5. 2 or 3 or 4
6. 1 and 5

Somatic

Database: PsycINFO

Search Strategy:

1. (menopaus$ or climacter$ or perimenopaus$).mp. [mp=title, abstract, heading word, table of contents, key concepts]
2. somat$.mp. [mp=title, abstract, heading word, table of contents, key concepts]
3. exp pain/
4. (pain$ or ache$).mp. [mp=title, abstract, heading word, table of contents, key concepts]
5. 2 or 3 or 4
6. 1 and 5

Urination

Database: PsycINFO

Search Strategy:

1. (menopaus$ or climacter$ or perimenopaus$).mp. [mp=title, abstract, heading word, table of contents, key concepts]
2. (urinat$ or urinar$ or incontin$).mp. [mp=title, abstract, heading word, table of contents, key concepts]
3. 1 and 2

Uterine Bleeding

Database: PsycINFO

Search Strategy:

1. (menopaus$ or climacter$ or perimenopaus$).mp. [mp=title, abstract, heading word, table of contents, key concepts]
2. (uterin$ or uterus).mp. [mp=title, abstract, heading word, table of contents, key concepts]
3. (hemorrhag$ or menorrhag$ or bleed$).mp. [mp=title, abstract, heading word, table of contents, key concepts]
4. 2 or 3
5. 1 and 4

Vaginal Dryness

Database: PsycINFO

Search Strategy:

1. (menopaus$ or climacter$ or perimenopaus$).mp. [mp=title, abstract, heading word, table of contents, key concepts]
2. vagin$.mp. [mp=title, abstract, heading word, table of contents, key concepts]
3. 1 and 2

Vasomotor

Database: PsycINFO

Search Strategy:

1. (menopaus$ or climacter$ or perimenopaus$).mp. [mp=title, abstract, heading word, table of contents, key concepts]
2. fl#sh$.mp. [mp=title, abstract, heading word, table of contents, key concepts]
3. sweat$.mp. [mp=title, abstract, heading word, table of contents, key concepts]
4. vasomotor$.mp. [mp=title, abstract, heading word, table of contents, key concepts]
5. body temperature.mp. [mp=title, abstract, heading word, table of contents, key concepts]
6. 2 or 3 or 4 or 5
7. 1 and 6

KQ2 MEDLINE

Searched 1966 through mid-November 2004

Age of Onset

Database: Ovid MEDLINE(R)

Search Strategy:

1. CLIMACTERIC/
2. MENOPAUSE/
3. 1 or 2
4. “Age of Onset”/
5. (age adj3 onset).mp. [mp=title, original title, abstract, name of substance, mesh subject heading]
6. (age adj2 menopause).mp. [mp=title, original title, abstract, name of substance, mesh subject heading]
7. (menopaus$ adj2 transit$).mp. [mp=title, original title, abstract, name of substance, mesh subject heading]
8. 4 or 5 or 6 or 7
9. 3 and 8
10. exp Age Factors/
11. exp Time Factors/
12. 10 or 11
13. 9 and 12
14. limit 13 to english language
15. 13 not 14
16. limit 15 to abstracts
17. 14 or 16
18. from 17 keep 1–458

BMI

Database: Ovid MEDLINE(R)

Search Strategy:

1. CLIMACTERIC/
2. MENOPAUSE/
3. 1 or 2
4. (body mass index or bmi).mp. [mp=title, original title, abstract, name of substance, mesh subject heading]
5. 3 and 4
6. limit 5 to english language
7. 5 not 6
8. limit 7 to abstracts
9. 6 or 8

Depression

Database: Ovid MEDLINE(R)

Search Strategy:

1. CLIMACTERIC/
2. MENOPAUSE/
3. 1 or 2
4. CLIMACTERIC/px [Psychology]
5. MENOPAUSE/px [Psychology]
6. 4 or 5
7. DEPRESSION/
8. exp Depressive Disorder/
9. 7 or 8
10. Depress$.mp.
11. 6 and 10
12. 3 and 9
13. 11 or 12
14. limit 13 to english language
15. 13 not 14
16. limit 15 to abstracts
17. 14 or 16

Ethnicity

Database: Ovid MEDLINE(R)

Search Strategy:

1. CLIMACTERIC/
2. MENOPAUSE/
3. ((perimenopaus$ or menopaus$) adj3 (sign$ or symptom$)).mp.
4. 1 or 2 or 3
5. eh.fs.
6. exp Population Groups/
7. Cross-Cultural Comparison/
8. 5 or 6 or 7
9. 4 and 8
10. limit 9 to english language
11. 9 not 10
12. limit 11 to abstracts
13. 10 or 12

Surgical

Database: Ovid MEDLINE(R)

Search Strategy:

1. CLIMACTERIC/
2. MENOPAUSE/
3. 1 or 2
4. surgical menopause.mp.
5. exp OVARIECTOMY/
6. 3 and 5
7. (oophorectom$ or ovariectom$).mp. [mp=title, original title, abstract, name of substance, mesh subject heading]
8. (ovar$ adj3 remov$).mp. [mp=title, original title, abstract, name of substance, mesh subject heading]
9. 7 or 8
10. 3 and 9
11. 4 or 6 or 10
12. limit 11 to human
13. limit 12 to english language
14. 12 not 13
15. limit 14 to abstracts
16. 13 or 15

KQ2 PSYCHINFO

Searched 1974 through May 2004

Depression

Database: PsycINFO

Search Strategy:

1. (menopaus$ or climacter$ or perimenopaus$).mp. [mp=title, abstract, heading word, table of contents, key concepts]
2. exp emotional states/
3. (mood$ or depress$ or anxi$ or irritab$).mp. [mp=title, abstract, heading word, table of contents, key concepts]
4. 2 or 3
5. 1 and 4

KQ3 AMED

Searched 1985 through August 2004

Menopause

Database: AMED (Allied and Complementary Medicine)

Search Strategy:

1. (menopaus$ or climacter$ or perimenopaus$).mp. [mp=abstract, heading words, title]

KQ3 COCHRANE

Searched through 2^nd^ Quarter 2004

Alternative

Database: EBM Reviews - Cochrane Central Register of Controlled Trials

Search Strategy:

1. (exp menopause/ and climacterium/) or exp climacteric/ or (menopaus$ or climacter$ or premenopaus$ or postmenopaus$ or perimenopaus$).mp.
2. exp medicinal plant/ or exp plants, medicinal/ or exp plant medicinal product/ or exp plant extracts/ or (botanical$ or herb or herbal or red clover or black cohosh or primrose or yam or ginseng or dong quai or progesterone cream).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
3. exp traditional medicine/ or exp alternative medicine/ or exp complementary therapies/ or ((Alternative or complement$) adj5 (medic$ or treat$ or therap$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
4. (homeopath$ or naturopath$ or Ayurvedic).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
5. (acupunct$ or reflexol$ or magnet$ or electromagnet$ or tradition$ or folk).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
6. 2 or 3 or 4 or 5
7. 1 and 6

Androgens

Database: EBM Reviews - Cochrane Central Register of Controlled Trials

Search Strategy:

1. (exp menopause/ and climacterium/) or exp climacteric/ or (menopaus$ or climacter$ or premenopaus$ or postmenopaus$ or perimenopaus$).mp.
2. exp androgens/ or androgen$.mp. or testosteron$.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
3. (dhea or dihydroepitestosteron$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
4. dihydrotestosteron$.mp.
5. 2 or 3 or 4
6. 1 and 5
7. from 6 keep 1–384

Antidepressants

Database: EBM Reviews - Cochrane Central Register of Controlled Trials

Search Strategy:

1. (exp menopause/ and climacterium/) or exp climacteric/ or (menopaus$ or climacter$ or premenopaus$ or postmenopaus$ or perimenopaus$).mp.
2. exp antidepressant agents/ or exp antidepressive agents/ or Antidepress$.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
3. fluoxetine.mp.
4. venlafaxine.mp.
5. paroxetine.mp.
6. 2 or 3 or 4 or 5
7. 1 and 6
8. exp depression/
9. exp depressive disorder/
10. 8 or 9
11. 1 and 10
12. 7 or 11

Exercise

Database: EBM Reviews - Cochrane Central Register of Controlled Trials

Search Strategy:

1. (exp menopause/ and climacterium/) or exp climacteric/ or (menopaus$ or climacter$ or premenopaus$ or postmenopaus$ or perimenopaus$).mp.
2. exp Exercise Movement Techniques/ or exp kinesiotherapy/ or exp exercise/
3. (aerobic$ or exercis$ or yoga or tai chi or pilates).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
4. ((exp psychophysiology/ or exp feedback system/ or exp Mind-Body/) and Relaxation Techniques/) or (biofeedback$ or feedback$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
5. ((pace or paced or pacing) adj3 (breath$ or respirat$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
6. 2 or 3 or 4 or 5
7. 1 and 6

Hormones (covers estrogen and progestin)

Database: EBM Reviews - Cochrane Central Register of Controlled Trials

Search Strategy:

1. exp pain/ or (Pain or pains or painful or ache or aching or ached or aches or headach$ or migrain$ or somat$).mp.
2. exp urination disorders/ or exp urinary dysfunction/ or ((vagina$ adj5 dry$) or enuresis or polyuria or oliguria or incontinen$ or (urin$ adj3 frequen$) or urinat$ or vaginit$ or vulvovaginit$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
3. exp Delirium, Dementia, Amnestic, Cognitive Disorders/ or exp memory disorder/ or exp memory disorders/ or exp cognitive defect/ or (Cognit$ or amnes$ or deliri$ or dement$ or memor$ or remember$ or think$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
4. exp sexuality/ or exp Sexual behavior/ or exp sex disorders/ or exp sexual dysfunction/ or ((sex$ adj3 (disorder$ or dysfunctio$ or function$ or activ$ or desir$)) or Dyspareuni$ or vaginismus).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
5. exp sleep/ or exp sleep disorders/ or exp sleep disorder/ or (Sleep$ or slept or insomn$ or awak$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
6. exp uterine bleeding/ or exp uterus bleeding/ or (((uterine or uterus) adj5 (bleed$ or bled or hemorrhag$)) or menorrhag$).mp.
7. exp affect/ or exp mood disorders/ or exp mood disorder/ or exp mood/ or exp temperament/ or (mood$ or emotion$ or depression or depressive or irritat$ or anxi$ or Affective).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
8. exp quality of life/ or (qualit$ adj5 (life or living)).mp.
9. exp body temperature regulation/ or exp body temperature disorder/ or exp vasomotor disorder/ or exp vasomotor system/ or exp adrenergic system/ or (Vasomotor or fl#sh$ or sweat$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
10. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9
11. (exp menopause/ and climacterium/) or exp climacteric/ or (menopaus$ or climacter$ or premenopaus$ or postmenopaus$ or perimenopaus$).mp.
12. exp estrogens/ or exp estrogen/ or estrogen$.mp.
13. exp hormone replacement therapy/ or exp hormone substitution/ or (hormone replacement therapy or hormone substitution).mp.
14. exp progesterone/ or exp progestins/ or exp gestagen/ or (progestin$ or progesterone$ or gestegen$ or neta or mpa or megestrol).mp.
15. 12 or 13 or 14
16. 10 and 11 and 15

Other Drugs

Database: EBM Reviews - Cochrane Central Register of Controlled Trials

Search Strategy:

1. (exp menopause/ and climacterium/) or exp climacteric/ or (menopaus$ or climacter$ or premenopaus$ or postmenopaus$ or perimenopaus$).mp.
2. gabapentin.mp.
3. clonidine.mp.
4. methyldopa.mp. or exp METHYLDOPA/
5. exp Ergotamine/ or bellergal.mp.
6. 2 or 3 or 4 or 5
7. 1 and 6

Phytoestrogens

Database: EBM Reviews - Cochrane Central Register of Controlled Trials

Search Strategy:

(exp menopause/ and climacterium/) or exp climacteric/ or (menopaus$ or climacter$ or premenopaus$ or postmenopaus$ or perimenopaus$).mp.

exp phytoestrogen/ or exp isoflavones/ or exp isoflavone derivative/ or (phytoestrogen$ or isflavone$ or soy or soya or soybean$ or genistein or flax).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]

1 and 2

Tibolone

Database: EBM Reviews - Cochrane Central Register of Controlled Trials

Search Strategy:

1. (exp menopause/ and climacterium/) or exp climacteric/ or (menopaus$ or climacter$ or premenopaus$ or postmenopaus$ or perimenopaus$).mp.
2. tibolone.mp.
3. 1 and 2

KQ3 MANTIS

Searched 1880 through July 2004

Menopause

Database: Mantis

Search Strategy:

(menopaus$ or climacter$ or perimenopaus$).mp. [mp=title, abstract, descriptors]

KQ3 MEDLINE

Searched 1966 through mid-November 2004

Alternative

Database: Ovid MEDLINE(R)

Search Strategy:

1. exp CLIMACTERIC/ or (climacter$ or menopaus$).mp.
2. limit 1 to complementary medicine
3. (botanical$ or red clover or black cohosh or primrose or yam or ginseng or dong quai or progesterone cream).mp. [mp=title, original title, abstract, name of substance, mesh subject heading]
4. exp Complementary Therapies/
5. (homeopath$ or naturopath$ or Ayurvedic).mp. [mp=title, original title, abstract, name of substance, mesh subject heading]
6. 3 or 4 or 5
7. 1 and 6
8. 2 or 7
9. limit 8 to english language
10. 8 not 9
11. limit 10 to abstracts
12. 9 or 11
13. limit 12 to (guideline or meta analysis or randomized controlled trial)
14. from 13 keep 1–310

Androgens

Database: Ovid MEDLINE(R)

Search Strategy:

1. exp CLIMACTERIC/ or (climacter$ or menopaus$).mp.
2. exp androgens/ or androgen$.mp. or testosteron$.mp. [mp=title, original title, abstract, name of substance, mesh subject heading]
3. (dhea or dihydroepitestosteron$).mp. [mp=title, original title, abstract, name of substance, mesh subject heading]
4. dihydrotestosteron$.mp.
5. 2 or 3 or 4
6. 1 and 5
7. limit 6 to female
8. limit 7 to english language
9. 7 not 8
10. limit 9 to abstracts
11. 8 or 10
12. limit 11 to (guideline or meta analysis or randomized controlled trial)

Antidepressives

Database: Ovid MEDLINE(R)

Search Strategy:

1. exp CLIMACTERIC/ or (climacter$ or menopaus$).mp.
2. exp Antidepressive Agents/
3. fluoxetine.mp.
4. venlafaxine.mp.
5. paroxetine.mp.
6. exp DEPRESSION/de, dt [Drug Effects, Drug Therapy]
7. exp Depressive Disorder/dt [Drug Therapy]
8. 2 or 3 or 4 or 5 or 6 or 7
9. 1 and 8
10. limit 9 to (guideline or meta analysis or randomized controlled trial)

Eastrogen/Progestin

Database: Ovid MEDLINE(R)

Search Strategy:

1. CLIMACTERIC/
2. MENOPAUSE/
3. (climacter$ or menopaus$ or perimenopaus$).mp. [mp=title, original title, abstract, name of substance, mesh subject heading]
4. 1 or 2 or 3
5. exp Hormone Replacement Therapy/
6. exp ESTROGENS/
7. exp PROGESTINS/
8. 5 or 6 or 7
9. 4 and 8
10. limit 9 to (guideline or meta analysis or randomized controlled trial)
11. limit 10 to (guideline or meta analysis or randomized controlled trial)
12. limit 11 to english language
13. 11 not 12
14. limit 13 to abstracts
15. 12 or 14

Exercise

Database: Ovid MEDLINE(R)

Search Strategy:

1. exp CLIMACTERIC/ or (climacter$ or menopaus$).mp.
2. exp Exercise Movement Techniques/
3. (aerobic$ or exercis$ or yoga or tai chi or pilates).mp. [mp=title, original title, abstract, name of substance, mesh subject heading]
4. (biofeedback$ or feedback$).mp. [mp=title, original title, abstract, name of substance, mesh subject heading]
5. ((pace or paced or pacing) adj3 (breath$ or respirat$)).mp. [mp=title, original title, abstract, name of substance, mesh subject heading]
6. 2 or 3 or 4 or 5
7. 1 and 6
8. limit 7 to english language
9. 7 not 8
10. limit 9 to abstracts
11. 8 or 10
12. limit 11 to (guideline or meta analysis or randomized controlled trial)

Other Drugs

Database: Ovid MEDLINE(R)

Search Strategy:

1. exp CLIMACTERIC/ or (climacter$ or menopaus$).mp.
2. gabapentin.mp.
3. clonidine.mp.
4. methyldopa.mp. or exp METHYLDOPA/
5. exp Ergotamine/ or bellergal.mp.
6. 2 or 3 or 4 or 5
7. 1 and 6
8. limit 7 to english language
9. 7 not 8
10. limit 9 to abstracts
11. 8 or 10
12. limit 11 to (guideline or meta analysis or randomized controlled trial)

Phytoestrogen

Database: Ovid MEDLINE(R)

Search Strategy:

1. exp CLIMACTERIC/ or (climacter$ or menopaus$).mp.
2. exp Isoflavones/
3. (phytoestrogen$ or isflavone$ or soy or soya or flax).mp. [mp=title, original title, abstract, name of substance, mesh subject heading]
4. 2 or 3
5. 1 and 4
6. limit 5 to english language
7. 5 not 6
8. limit 7 to abstracts
9. 6 or 8
10. limit 9 to (guideline or meta analysis or randomized controlled trial)

Tibolone

Database: Ovid MEDLINE(R)

Search Strategy:

1. exp CLIMACTERIC/ or (climacter$ or menopaus$).mp.
2. tibolone.mp.
3. 1 and 2
4. limit 3 to english language
5. 3 not 4
6. limit 5 to abstracts
7. limit 7 to (guideline or meta analysis or randomized controlled trial)

KQ3 PSYCHINFO

Searched 1974 through May 2004

Alternative

Database: PsycINFO

Search Strategy:

1. (menopaus$ or climacter$ or perimenopaus$).mp. [mp=title, abstract, heading word, table of contents, key concepts]
2. exp alternative medicine/ or exp dietary supplements/ or exp “medicinal herbs and plants”/
3. (red clover or cohosh or herb or herbal$ or acupunct$ or reflex$).mp. [mp=title, abstract, heading word, table of contents, key concepts]
4. holist$.mp. [mp=title, abstract, heading word, table of contents, key concepts]
5. (complementar$ adj2 (medic$ or therap$)).mp. [mp=title, abstract, heading word, table of contents, key concepts]
6. (alternat$ adj2 (medic$ or therap$)).mp. [mp=title, abstract, heading word, table of contents, key concepts]
7. 2 or 3 or 4 or 5 or 6
8. 1 and 7

Antidepressants

Database: PsycINFO

Search Strategy:

1. (menopaus$ or climacter$ or perimenopaus$).mp. [mp=title, abstract, heading word, table of contents, key concepts]
2. exp Antidepressant Drugs/
3. (fluoxetine or venlafaxine or paroxetine).mp. [mp=title, abstract, heading word, table of contents, key concepts]
4. exp Serotonin Reuptake Inhibitors/
5. ssri.mp. [mp=title, abstract, heading word, table of contents, key concepts]
6. antidepress$.mp. [mp=title, abstract, heading word, table of contents, key concepts]
7. 2 or 3 or 4 or 5 or 6
8. 1 and 7

Exercise

Database: PsycINFO

Search Strategy:

1. (menopaus$ or climacter$ or perimenopaus$).mp. [mp=title, abstract, heading word, table of contents, key concepts]
2. exp exercise/ or exp movement therapy/
3. (exercis$ or (physical$ adj3 activ$)).mp. [mp=title, abstract, heading word, table of contents, key concepts]
4. (pac$ adj2 respir$).mp. [mp=title, abstract, heading word, table of contents, key concepts]
5. biofeed$.mp. [mp=title, abstract, heading word, table of contents, key concepts]
6. (meditat$ or relax$).mp. [mp=title, abstract, heading word, table of contents, key concepts]
7. 2 or 3 or 4 or 5 or 6
8. 1 and 7

Hormones (covers estrogen, progestin, and androgen)

Database: PsycINFO

Search Strategy:

1. (menopaus$ or climacter$ or perimenopaus$).mp. [mp=title, abstract, heading word, table of contents, key concepts]
2. exp sex hormones/
3. (estrogen$ or progestin$ or progesterone$ or estradiol$ or mpa or neta or megestrol or androgen$ or testosteron$ or dhea).mp. [mp=title, abstract, heading word, table of contents, key concepts]
4. (hormon$ adj2 therap$).mp. [mp=title, abstract, heading word, table of contents, key concepts]
5. 2 or 3 or 4
6. 1 and 5

Other Drugs

Database: PsycINFO

Search Strategy:

1. (menopaus$ or climacter$ or perimenopaus$).mp. [mp=title, abstract, heading word, table of contents, key concepts]
2. (gabpentin or clonidine or methyldopa or bellergal).mp. [mp=title, abstract, heading word, table of contents, key concepts]
3. 1 and 2

Phytoestrogens

Database: PsycINFO

Search Strategy:

1. (menopaus$ or climacter$ or perimenopaus$).mp. [mp=title, abstract, heading word, table of contents, key concepts]
2. (phytoestrogen$ or soy or soya or flax or isoflavon$).mp. [mp=title, abstract, heading word, table of contents, key concepts]
3. (phytoestrogen$ or soy or soya or flax or isoflavon$ or genistein$).mp. [mp=title, abstract, heading word, table of contents, key concepts]
4. 1 and 3

Tibolone

Database: PsycINFO

Search Strategy:

1. tibolone.mp.

KQ4 MEDLINE

Searched 1966 through mid-November 2004

Breast Cancer

Database: Ovid MEDLINE(R)

Search Strategy:

1. exp Breast Neoplasms/co [Complications]
2. (menopaus$ or perimenopaus$ or premenopaus$).mp. [mp=title, original title, abstract, name of substance, mesh subject heading]
3. 1 and 2
4. (breast adj (cancer$ or tumor$ or malignan$) adj3 survivor$).mp. [mp=title, original title, abstract, name of substance, mesh subject heading]
5. 2 and 4
6. 3 or 5
7. limit 6 to english language
8. 6 not 7
9. limit 8 to abstracts
10. 7 or 9

SERMS

Database: Ovid MEDLINE(R)

Search Strategy:

1. MENOPAUSE/
2. CLIMACTERIC/
3. 1 or 2
4. exp Selective Estrogen Receptor Modulators/ad, ae, ct, tu, to [Administration & Dosage, Adverse Effects, Contraindications, Therapeutic Use, Toxicity]
5. 3 and 4
6. limit 5 to english language
7. 5 not 6
8. limit 7 to abstracts
9. 6 or 8

All KQ's DARE

Searched through 2^nd^ Quarter 2004

Menopause

Database: EBM Reviews - Database of Abstracts of Reviews of Effects

Search Strategy:

1. menopaus$.mp. [mp=title, full text, keywords] (73)
2. perimenopaus$.mp. [mp=title, full text, keywords] (4)
3. climacter$.mp. [mp=title, full text, keywords] (6)
4. postmenopaus$.mp. [mp=title, full text, keywords] (63)
5. 1 or 2 or 3 or 4 (106)
6. from 5 keep 1–10 (10)
7. from 6 keep 1–10 (10)
8. from 6 keep 1–10 (10)