# Appendix B. Expert Reviewers

- Deborah I. Allen, MD
- Representing American Academy of Family Physicians
- Tori Hudson, ND
- Medical Director, A Women's Time
- Portland, Oregon

- Barbara L. Kass-Bartelmes, MPH, CHES
- Agency for Healthcare, Research, and Quality

- Carmen Kelly, Pharm D
- Agency for Healthcare, Research, and Quality

- Alastair MacLennan, MD
- Professor, Department of Obstetrics & Gynecology
- Women's and Children's Hospital
- Adelaide University, Australia

- Susan Meikle, MD
- Agency for Healthcare, Research, and Quality

- Diana Petitti, MD, MPH
- Director, Research and Evaluation Clinical Services
- Kaiser Permanente Southern California
- Pasadena, California

- Leon Speroff, MD
- Professor, Department of Obstetrics and Gynecology
- Oregon Health and Science University
- Portland, Oregon

- Stanley Zinberg, MD, MS
- Representing American College of Obstetricians and Gynecologists