# Appendix A. Technical Expert Panel Members

- Robert R. Freedman, PhD
- Professor
- Wayne State University School of Medicine
- Detroit, Michigan

- Tori Hudson, ND
- Medical Director
- A Women's Time
- Portland, Oregon

- Fredi Kroenenburg, PhD
- Professor of Clinical Physiology in Rehabilitation Medicine
- The Richard & Hinda Rosenthal Center for Complementary & Alternative Medicine
- New York, New York

- Kurt Kroenke, MD
- Regenstrief Institute for Health Care
- Indianapolis, Indiana

- Diana Petitti, MD, MPH
- Director, Research and Evaluation Clinical Services
- Kaiser Permanente Southern California
- Pasadena, California

- Sally Shumaker, PhD
- Department of Public Health Sciences
- Wake Forest University School of Medicine
- Winston-Salem, North Carolina

- Leon Speroff, MD
- Professor, Department of Obstetrics and Gynecology
- Oregon Health and Science University
- Portland, Oregon