# Appendixes

Appendix A. Technical Expert Panel Members

Appendix B. Expert Reviewers

Appendix C. Literature Search Strategies

Appendix D. Inclusion and Exclusion Criteria

Appendix E. Literature Search Tree

Appendix F. Evidence Tables