# Evidence Tables

Evidence table 1. Design Characteristics of Studies on Pharmacological Conversion (Alone and in Conjunction with Direct Current Cardioversion) of Atrial Fibrillation ^1^ ^2^ ^3^

Author, Journal, Year | N | Treatment Groups | | Other Treatments ^4^ | F/U Time Goal | Inclusion Criteria ^3^ | Exclusion Criteria ^5^ | Quality ^6^
Author, Journal, Year | N | Regimen | n | Other Treatments ^4^ | F/U Time Goal | Inclusion Criteria ^3^ | Exclusion Criteria ^5^ | Rep. | Bias | Tx | Outcomes | Stats | Overall
Capucci, Int J Cardiol, 1994 | 87 | Quinidine 750 mg po load over 12 hrs then 150 mg tid po + Digoxin IV | 29 | AC | 48 hrs | 18-75 yrs;AF <8 days | MI, antiarr, CHF | 50 | 67 | 83 | 80 | 83 | 73
Capucci, Int J Cardiol, 1994 | 87 | Propafenone 600 mg po load then 300 mg tid po | 29 | AC | 48 hrs | 18-75 yrs;AF <8 days | MI, antiarr, CHF | 50 | 67 | 83 | 80 | 83 | 73
Capucci, Int J Cardiol, 1994 | 87 | Placebo | 29 | AC | 48 hrs | 18-75 yrs;AF <8 days | MI, antiarr, CHF | 50 | 67 | 83 | 80 | 83 | 73
Zehender, JACC, 1992 | 40 | Quinidine 500 mg tid po | 20 | dig, AC | 3 days | No age given; AF 4 wks-2 yrs | MI, antiarr, CHF, other | 63 | 50 | 75 | 83 | 83 | 71
Zehender, JACC, 1992 | 40 | Amiodarone 200 mg/3 hr IV then 50 mg/hr IV x3 days | 20 | dig, AC | 3 days | No age given; AF 4 wks-2 yrs | MI, antiarr, CHF, other | 63 | 50 | 75 | 83 | 83 | 71
Hohnloser, JACC, 1995 | 50 | Quinidine 500 mg bid po x3 days; then 250 mg tid po + Verapamil 80 mg qid po | 25 | dig, AC, DCC at day 8 | 8 days | 18-80 yrs; AF 48 hrs-6 mos | MI, antiarr, CHF, other | 63 | 50 | 63 | 58 | 83 | 63
Hohnloser, JACC, 1995 | 50 | Sotalol 80 mg q12 hrs x2 then 160 mg bid po | 25 | dig, AC, DCC at day 8 | 8 days | 18-80 yrs; AF 48 hrs-6 mos | MI, antiarr, CHF, other | 63 | 50 | 63 | 58 | 83 | 63
Halinen, Am J Cardiol, 1995 | 61 | Quinidine 200 mg po q2 hrs x3 doses + Digoxin IV | 28 | dig, bb, ccb, DCC after 12 hrs | 12 hrs | 18-75 yrs; AF <48 hrs | MI, antiarr, CHF | 75 | 50 | 67 | 40 | 75 | 61
Halinen, Am J Cardiol, 1995 | 61 | Sotalol 80 mg po x3-4 doses | 33 | dig, bb, ccb, DCC after 12 hrs | 12 hrs | 18-75 yrs; AF <48 hrs | MI, antiarr, CHF | 75 | 50 | 67 | 40 | 75 | 61
Rasmussen, Acta Med Scand Suppl, 1981 | 50 | Quinidine 400 mg bid po + DCC | 25 | DCC after several days, AC | several days | No age given; AF >10 days | | 25 | 17 | 25 | 33 | 88 | 38
Rasmussen, Acta Med Scand Suppl, 1981 | 50 | Verapamil 80 mg tid po + DCC | 25 | DCC after several days, AC | several days | No age given; AF >10 days | | 25 | 17 | 25 | 33 | 88 | 38
Byrne-Quinn, Br Heart J, 1970 | 92 | Quinidine 600 mg po x1 dose | 45 | DCC at 4-12 hrs | 12 hrs | No age given; AF | | 25 | 83 | 100 | 75 | 83 | 73
Byrne-Quinn, Br Heart J, 1970 | 92 | Placebo | 47 | DCC at 4-12 hrs | 12 hrs | No age given; AF | | 25 | 83 | 100 | 75 | 83 | 73
Hillestad, Br Heart J, 1971 | 100 | Quinidine 0.8-1.2 g/day po + DCC | 48 | AC | 12 days | | | 25 | 50 | 63 | 50 | 50 | 48
Hillestad, Br Heart J, 1971 | 100 | DCC | 52 | AC | 12 days | | | 25 | 50 | 63 | 50 | 50 | 48
Madrid, Eur Heart J, 1993 | 80 | Procainamide 1 g IV then 2 mg/min IV | 40 | | 1 hr | <75 yrs; PAF <24 hrs | MI, antiarr, CHF | 50 | 50 | 33 | 80 | 50 | 53
Madrid, Eur Heart J, 1993 | 80 | Flecainide 3.0 mg/kg IV total | 40 | | 1 hr | <75 yrs; PAF <24 hrs | MI, antiarr, CHF | 50 | 50 | 33 | 80 | 50 | 53
Boudonas, Acta Cardiol, 1995 | 30 | Disopyramide 50 mg IV x1 dose | 16 | dig | 1 hr | No age or duration given; PAF or Afl | Antiarr, CHF, other | 25 | 25 | 100 | 90 | 75 | 63
Boudonas, Acta Cardiol, 1995 | 30 | Diltiazem .25-.3 mg/kg IV x1 dose | 14 | dig | 1 hr | No age or duration given; PAF or Afl | Antiarr, CHF, other | 25 | 25 | 100 | 90 | 75 | 63
Suttorp, JACC, 1990 | 50 | Flecainide 2 mg/kg IV | 25 | dig, AC, bb, ccb | 1 hr | No age given; PAF or Afl <6 mos | MI, antiarr, CHF, other | 50 | 67 | 67 | 90 | 75 | 70
Suttorp, JACC, 1990 | 50 | Propafenone 2 mg/kg IV | 25 | dig, AC, bb, ccb | 1 hr | No age given; PAF or Afl <6 mos | MI, antiarr, CHF, other | 50 | 67 | 67 | 90 | 75 | 70
Kingma, Am J Cardiol, 1992 | 90 | Flecainide 2 mg/kg IV | 45 | dig, bb, ccb | 1 hr | No age given; PAF or Afl <6 mos | MI, CHF, antiarr, other | 50 | 67 | 67 | 90 | 67 | 68
Kingma, Am J Cardiol, 1992 | 90 | Propafenone 2 mg/kg IV | 25 | dig, bb, ccb | 1 hr | No age given; PAF or Afl <6 mos | MI, CHF, antiarr, other | 50 | 67 | 67 | 90 | 67 | 68
Kingma, Am J Cardiol, 1992 | 90 | Verapamil 10 mg IV | 20 | dig, bb, ccb | 1 hr | No age given; PAF or Afl <6 mos | MI, CHF, antiarr, other | 50 | 67 | 67 | 90 | 67 | 68
Baldi, New Trends Arrhythmias, 1993 | 50 | Flecainide 2 mg/kg IV | 26 | | 1 hr | No age given; AF <3 days | MI, antiarr, CHF, other | 88 | 50 | 100 | 80 | 50 | 73
Baldi, New Trends Arrhythmias, 1993 | 50 | Propafenone 2 mg/kg IV | 24 | | 1 hr | No age given; AF <3 days | MI, antiarr, CHF, other | 88 | 50 | 100 | 80 | 50 | 73
Capucci, Am J Cardiol, 1992 | 41 | Flecainide 300 mg po | 22 | | 24 hrs | <75 yrs, AF <7 days | MI, valve, antiarr, CHF, other | 75 | 67 | 100 | 80 | 83 | 81
Capucci, Am J Cardiol, 1992 | 41 | Amiodarone 5 mg/kg IV load then 1.8 g over 24 hr IV | 19 | | 24 hrs | <75 yrs, AF <7 days | MI, valve, antiarr, CHF, other | 75 | 67 | 100 | 80 | 83 | 81
Suttorp, Am J Cardiol, 1989 | 40 | Flecainide 2 mg/kg IV | 20 | | 1 hr | No age given; PAF or Afl <6 mos | MI, antiarr, CHF, other | 50 | 50 | 83 | 80 | 38 | 60
Suttorp, Am J Cardiol, 1989 | 40 | Verapamil 10 mg IV | 20 | | 1 hr | No age given; PAF or Afl <6 mos | MI, antiarr, CHF, other | 50 | 50 | 83 | 80 | 38 | 60
Barranco, Intensive Care Med, 1994 | 15 | Flecainide 2 mg/kg IV then 1.5 mg/kg IV x1 hr | 7 | | 1 hr | No age or duration given | CHF | 0 | 50 | 25 | 70 | 33 | 36
Barranco, Intensive Care Med, 1994 | 15 | Verapamil .15 mg/kg IV then .005 mg/kg/min x1 hr | 8 | | 1 hr | No age or duration given | CHF | 0 | 50 | 25 | 70 | 33 | 36
Donovan, Am J Cardiol, 1992 | 49 | Flecainide 2 mg/kg IV +Digoxin IV | 25 | dig | 1 hr | <18 yrs, AF 30 min -72 hrs | Antiarr; CHF | 63 | 83 | 83 | 90 | 100 | 84
Donovan, Am J Cardiol, 1992 | 49 | Placebo +Digoxin IV | 24 | dig | 1 hr | <18 yrs, AF 30 min -72 hrs | Antiarr; CHF | 63 | 83 | 83 | 90 | 100 | 84
Bertini, J Emerg Med, 1990 | 28 | Propafenone 1 mg/kg IV x2 doses then 150 mg tid po | 16 | | 5 days | >30 yrs; AF | MI, valve, antiarr, CHF, other | 50 | 50 | 50 | 80 | 83 | 63
Bertini, J Emerg Med, 1990 | 28 | Amiodarone 5 mg/kg IV load x2 doses then 200 mg bid po | 12 | | 5 days | >30 yrs; AF | MI, valve, antiarr, CHF, other | 50 | 50 | 50 | 80 | 83 | 63
Baroffio, Clin Drug Invest, 1995 | 50 | Propafenone 2 mg/kg IV | 25 | | 1 hr | >18 yrs; AF <72 hrs | MI, antiarr, CHF, other | 63 | 50 | 33 | 80 | 75 | 60
Baroffio, Clin Drug Invest, 1995 | 50 | Digoxin 0.007 mg/kg IV | 25 | | 1 hr | >18 yrs; AF <72 hrs | MI, antiarr, CHF, other | 63 | 50 | 33 | 80 | 75 | 60
Boriani, Chest, 1995 | 87 | Propafenone 2 mg/kg IV then 0.0078 mg/kg/min infusion | 29 | AC | 8 hrs | <75 yrs; AF <7 days | Antiarr, CHF, other | 63 | 67 | 100 | 80 | 83 | 79
Boriani, Chest, 1995 | 87 | Propafenone 600 mg po | 29 | AC | 8 hrs | <75 yrs; AF <7 days | Antiarr, CHF, other | 63 | 67 | 100 | 80 | 83 | 79
Boriani, Chest, 1995 | 87 | Placebo | 29 | AC | 8 hrs | <75 yrs; AF <7 days | Antiarr, CHF, other | 63 | 67 | 100 | 80 | 83 | 79
Fresco, Clin Cardiol, 1996 | 75 | Propafenone 2 mg/kg IV then 1 mg/kg IV over 2 hrs | 41 | | 3 hrs | <70 yrs; PAF <72 hrs | MI, antiarr, CHF, other | 63 | 83 | 100 | 90 | 75 | 82
Fresco, Clin Cardiol, 1996 | 75 | Placebo | 34 | | 3 hrs | <70 yrs; PAF <72 hrs | MI, antiarr, CHF, other | 63 | 83 | 100 | 90 | 75 | 82
Stroobandt, Am J Cardiol, 1997 | 136 | Propafenone 2 mg/kg IV then 150 mg tid po | 101 | dig, AC, DCC after 48 hrs | 48 hrs | >18 yrs; AF recent onset <2 wks or AF >2 wks if chronic | antiarr, CHF, other | 63 | 67 | 63 | 75 | 70 | 67
Stroobandt, Am J Cardiol, 1997 | 136 | Placebo | 35 | dig, AC, DCC after 48 hrs | 48 hrs | >18 yrs; AF recent onset <2 wks or AF >2 wks if chronic | antiarr, CHF, other | 63 | 67 | 63 | 75 | 70 | 67
Boriani, Ann Intern Med, 1997 | 240 | Propafenone 600 mg po x1 dose | 119 | AC | 8 hrs | <80 yrs; AF <7 days | MI, antiarr, CHF, other | 88 | 67 | 83 | 80 | 100 | 84
Boriani, Ann Intern Med, 1997 | 240 | Placebo | 121 | AC | 8 hrs | <80 yrs; AF <7 days | MI, antiarr, CHF, other | 88 | 67 | 83 | 80 | 100 | 84
Azpitarte, Eur Heart J, 1997 | 55 | Propafenone 450-750 mg po x1 dose | 29 | | 24 hrs | No age given; <7 days lone AF; <72 hrs if valve disease | MI, CHF, other | 63 | 83 | 50 | 80 | 83 | 72
Azpitarte, Eur Heart J, 1997 | 55 | Placebo | 26 | | 24 hrs | No age given; <7 days lone AF; <72 hrs if valve disease | MI, CHF, other | 63 | 83 | 50 | 80 | 83 | 72
Bellandi, Cardiovasc Drugs Ther 1996 | 182 | Propafenone 2 mg/kg IV load then 0.007 mg/kg/min IV | 98 | | 24 hrs | No age given; PAF <7 days | MI, antiarr, CHF | 25 | 67 | 100 | 90 | 83 | 73
Bellandi, Cardiovasc Drugs Ther 1996 | 182 | Placebo | 84 | | 24 hrs | No age given; PAF <7 days | MI, antiarr, CHF | 25 | 67 | 100 | 90 | 83 | 73
Bianconi, JACC, 1996 | 100 | Propafenone 750 mg/day po | 49 | AC, DCC at 48 hrs | 48 hrs | No age given; AF >1 mo | CHF, antiarr, other | 50 | 100 | 83 | 90 | 75 | 80
Bianconi, JACC, 1996 | 100 | Placebo | 51 | AC, DCC at 48 hrs | 48 hrs | No age given; AF >1 mo | CHF, antiarr, other | 50 | 100 | 83 | 90 | 75 | 80
Botto, Int J Cardiol, 1997 | 105 | Propafenone 450 mg po x1 dose | 35 | | 24 hrs | <80 yrs; PAF <72 hrs | MI, antiarr, CHF, other | 63 | 67 | 100 | 90 | 83 | 81
Botto, Int J Cardiol, 1997 | 105 | Propafenone 600 mg po x1 dose | 35 | | 24 hrs | <80 yrs; PAF <72 hrs | MI, antiarr, CHF, other | 63 | 67 | 100 | 90 | 83 | 81
Botto, Int J Cardiol, 1997 | 105 | Placebo | 35 | | 24 hrs | <80 yrs; PAF <72 hrs | MI, antiarr, CHF, other | 63 | 67 | 100 | 90 | 83 | 81
Bianconi, New Trends Arrhythmias, 1993 | 35 | Propafenone 750 mg/day po | 16 | AC, DCC at 48 hrs | 48 hrs | No age given; AF >4 wks | CHF, other | 63 | 67 | 100 | 80 | 75 | 77
Bianconi, New Trends Arrhythmias, 1993 | 35 | Placebo | 19 | AC, DCC at 48 hrs | 48 hrs | No age given; AF >4 wks | CHF, other | 63 | 67 | 100 | 80 | 75 | 77
Noc, Am J Cardiol, 1990 | 24 | Amiodarone 5 mg/kg IV | 13 | | 3 hrs | No age given; PAF; no duration specified | CHF, antiarr, other | 38 | 50 | 50 | 80 | 50 | 54
Noc, Am J Cardiol, 1990 | 24 | Verapamil 0.075 mg/kg IV | 11 | | 3 hrs | No age given; PAF; no duration specified | CHF, antiarr, other | 38 | 50 | 50 | 80 | 50 | 54
Cowan, J Cardiovasc Pharmacol, 1986 | 34 | Amiodarone 1500 mg IV over 24 hr total | 18 | bb | 24 hrs | No age given; AF >1 hr | Valve, antiarr | 38 | 50 | 83 | 90 | 88 | 70
Cowan, J Cardiovasc Pharmacol, 1986 | 34 | Digoxin 1.0 mg total IV over 1 hr | 16 | bb | 24 hrs | No age given; AF >1 hr | Valve, antiarr | 38 | 50 | 83 | 90 | 88 | 70
Hou, Eur Heart J, 1995 | 50 | Amiodarone 1.6 g total IV | 26 | | 24 hrs | No age given; AF or Afl <10 days | Antiarr, other | 63 | 67 | 33 | 90 | 83 | 67
Hou, Eur Heart J, 1995 | 50 | Digoxin 0.013 mg/kg total IV | 24 | | 24 hrs | No age given; AF or Afl <10 days | Antiarr, other | 63 | 67 | 33 | 90 | 83 | 67
Singh, Am J Cardiol, 1991 | 34 | Sotalol 80-320 mg qd po + Digoxin po | 24 | dig, AC, DCC after 7 days | 7 days | >18 yrs; AF 2-52 wks | CHF, other | 25 | 67 | 38 | 58 | 63 | 50
Singh, Am J Cardiol, 1991 | 34 | Placebo + Digoxin po | 10 | dig, AC, DCC after 7 days | 7 days | >18 yrs; AF 2-52 wks | CHF, other | 25 | 67 | 38 | 58 | 63 | 50
Guo, JACC, 1996 | 35 | Ibutilide .005-.025 mg/kg IV | 25 | | 10 mins | No age given; Afl >2 days | Antiarr | 38 | 67 | 33 | 80 | 100 | 64
Guo, JACC, 1996 | 35 | Placebo | 10 | | 10 mins | No age given; Afl >2 days | Antiarr | 38 | 67 | 33 | 80 | 100 | 64
Stambler, Circulation, 1996 | 242 | Ibutilide 1.5 mg total IV | 79 | dig, AC, bb, ccb | 1.5 hrs | >18 yrs; AF or Afl 3 hrs-45 days | antiarr, CHF, other | 63 | 67 | 67 | 80 | 50 | 65
Stambler, Circulation, 1996 | 242 | Ibutilide 2.0 mg total IV | 82 | dig, AC, bb, ccb | 1.5 hrs | >18 yrs; AF or Afl 3 hrs-45 days | antiarr, CHF, other | 63 | 67 | 67 | 80 | 50 | 65
Stambler, Circulation, 1996 | 242 | Placebo | 81 | dig, AC, bb, ccb | 1.5 hrs | >18 yrs; AF or Afl 3 hrs-45 days | antiarr, CHF, other | 63 | 67 | 67 | 80 | 50 | 65
Ellenbogen, JACC, 1996 | 197 | Ibutilide .005 mg/kg IV | 40 | dig, AC, bb, ccb | 1 hr | No age given; Afl >3 hrs or AF 3 hrs to 90 days | MI, CHF | 38 | 83 | 67 | 80 | 75 | 69
Ellenbogen, JACC, 1996 | 197 | Ibutilide .010 mg/kg IV | 39 | dig, AC, bb, ccb | 1 hr | No age given; Afl >3 hrs or AF 3 hrs to 90 days | MI, CHF | 38 | 83 | 67 | 80 | 75 | 69
Ellenbogen, JACC, 1996 | 197 | Ibutilide .015 mg/kg IV | 38 | dig, AC, bb, ccb | 1 hr | No age given; Afl >3 hrs or AF 3 hrs to 90 days | MI, CHF | 38 | 83 | 67 | 80 | 75 | 69
Ellenbogen, JACC, 1996 | 197 | Ibutilide .025 mg/kg IV | 39 | dig, AC, bb, ccb | 1 hr | No age given; Afl >3 hrs or AF 3 hrs to 90 days | MI, CHF | 38 | 83 | 67 | 80 | 75 | 69
Ellenbogen, JACC, 1996 | 197 | Placebo | 40 | dig, AC, bb, ccb | 1 hr | No age given; Afl >3 hrs or AF 3 hrs to 90 days | MI, CHF | 38 | 83 | 67 | 80 | 75 | 69
Falk, JACC, 1997 | 91 | Dofetilide .004 mg/kg IV | 32 | AC | 6 hrs | <75 yrs; AF or Afl 2 wks-6 mos | | 50 | 83 | 83 | 80 | 100 | 79
Falk, JACC, 1997 | 91 | Dofetilide .008 mg/kg IV | 29 | AC | 6 hrs | <75 yrs; AF or Afl 2 wks-6 mos | | 50 | 83 | 83 | 80 | 100 | 79
Falk, JACC, 1997 | 91 | Placebo | 30 | AC | 6 hrs | <75 yrs; AF or Afl 2 wks-6 mos | | 50 | 83 | 83 | 80 | 100 | 79
Innes, Ann Emerg Med, 1997 | 41 | Verapamil 20 mg total IV + up to 1 g Quinidine po | 19 | | 6 hrs | 18-75 yrs; PAF <48 hrs | | 88 | 100 | 100 | 80 | 100 | 94
Innes, Ann Emerg Med, 1997 | 41 | Digoxin 1 mg total IV + up to 1 g Quinidine po | 22 | | 6 hrs | 18-75 yrs; PAF <48 hrs | | 88 | 100 | 100 | 80 | 100 | 94
Levi, Cardiology, 1973 | 54 | Quinidine 150 mg po after Practolol 100 mg qid x4 days | 26 | | 5-7 days | | CHF | 13 | 58 | 57 | 90 | 0 | 45
Levi, Cardiology, 1973 | 54 | Quinidine 150 mg po after Placebo for 4 days | 28 | | 5-7 days | | CHF | 13 | 58 | 57 | 90 | 0 | 45
Crijns Eur Heart J 1988 | 40 | Flecainide 400 mg po total | 20 | dig, ccb | 5 hrs | 16-80 yrs; AF <6 mos | CHF, antiarr, other | 50 | 50 | 33 | 80 | 25 | 48
Crijns Eur Heart J 1988 | 40 | Flecainide 2 mg/kg IV | 20 | dig, ccb | 5 hrs | 16-80 yrs; AF <6 mos | CHF, antiarr, other | 50 | 50 | 33 | 80 | 25 | 48
Kuhlkamp Int J Cardiol 1991 | 31 | Flecainide 200-300 mg/day po | 12 | dig, AC, ccb | 5 days | No age given; AF >7 days | MI, CHF, other | 63 | 17 | 38 | 67 | 60 | 49
Kuhlkamp Int J Cardiol 1991 | 31 | Cibenzoline 260-320 mg/day po | 19 | dig, AC, ccb | 5 days | No age given; AF >7 days | MI, CHF, other | 63 | 17 | 38 | 67 | 60 | 49
Toivonen Br Heart J 1986 | 40 | Pirmenol 50 mg x 2 doses IV | 20 | dig, bb | 1 hr | No age given; PAF <48 hrs | MI, antiarr, CHF | 38 | 83 | 50 | 40 | 83 | 59
Toivonen Br Heart J 1986 | 40 | Placebo | 20 | dig, bb | 1 hr | No age given; PAF <48 hrs | MI, antiarr, CHF | 38 | 83 | 50 | 40 | 83 | 59
Atarashi, Am J Cardiol, 1996 | 75 | Pilsicainide 150 mg po x1 dose | 40 | | 90 mins | 20-80 yrs; AF <7 days | MI, antiarr, CHF, other | 50 | 83 | 50 | 80 | 100 | 73
Atarashi, Am J Cardiol, 1996 | 75 | Placebo | 35 | | 90 mins | 20-80 yrs; AF <7 days | MI, antiarr, CHF, other | 50 | 83 | 50 | 80 | 100 | 73
Sweany, Clin Pharmacol Ther, 1985 | 81 | Timolol 1 mg x2-3 doses IV | 40 | | 1 hr | 18-73 yrs; AF or Afl | Antiarr | 38 | 50 | 50 | 90 | 75 | 61
Sweany, Clin Pharmacol Ther, 1985 | 81 | Placebo | 41 | | 1 hr | 18-73 yrs; AF or Afl | Antiarr | 38 | 50 | 50 | 90 | 75 | 61
Gullestad, Clin Cardiol, 1993 | 45 | Magnesium 5 mmol IV bolus x2 doses then 0.04 mmol/hr IV infusion | 21 | | 24 hrs | No age given; AF or Afl <1 wk | MI, antiarr, CHF, other | 50 | 33 | 50 | 80 | 63 | 55
Gullestad, Clin Cardiol, 1993 | 45 | Verapamil 5 mg IV + 0.01 mg/min IV infusion | 24 | | 24 hrs | No age given; AF or Afl <1 wk | MI, antiarr, CHF, other | 50 | 33 | 50 | 80 | 63 | 55
Ochs, J Clin Pharmacol, 1985 | 30 | Diltiazem 60-120 mg tid po | 15 | dig | 12 days | No age given; AF >6 mos | CHF, other | 50 | 67 | 100 | 42 | 50 | 62
Ochs, J Clin Pharmacol, 1985 | 30 | Verapamil 80-160 mg tid po | 15 | dig | 12 days | No age given; AF >6 mos | CHF, other | 50 | 67 | 100 | 42 | 50 | 62
Falk, Ann Intern Med, 1987 | 36 | Digoxin 1.4 mg total po | 18 | | 18 hrs | No age given; AF <7 days | MI, antiarr, CHF, other | 88 | 67 | 100 | 80 | 100 | 87
Falk, Ann Intern Med, 1987 | 36 | Placebo | 18 | | 18 hrs | No age given; AF <7 days | MI, antiarr, CHF, other | 88 | 67 | 100 | 80 | 100 | 87
The Digitalis in Acute Atrial Fibrillation (DAAF) Trial Group, Eur Heart J, 1997 | 239 | Digoxin 0.75-1.5 g IV total | 117 | ccb | 16 hrs | >18 yrs; AF <7 days | MI, antiarr, other | 100 | 92 | 83 | 90 | 100 | 93
The Digitalis in Acute Atrial Fibrillation (DAAF) Trial Group, Eur Heart J, 1997 | 239 | Placebo | 122 | ccb | 16 hrs | >18 yrs; AF <7 days | MI, antiarr, other | 100 | 92 | 83 | 90 | 100 | 93
Jordaens, Eur Heart J, 1997 | 39 | Digoxin 1.25 mg IV total | 19 | ccb | 12 hrs | No age given; AF <7 days | MI, antiarr | 38 | 58 | 83 | 90 | 25 | 59
Jordaens, Eur Heart J, 1997 | 39 | Placebo | 20 | ccb | 12 hrs | No age given; AF <7 days | MI, antiarr | 38 | 58 | 83 | 90 | 25 | 59

1 Encompasses only non-postoperative atrial fibrillation

2 Table ordered by Vaughan-Williams classification without any repetition of studies; miscellaneous drugs (with n=1 studies) or drugs considered as "control" in this analysis (verapamil, diltiazem, digoxin) are at end of table

3 AF = atrial fibrillation; Afl = atrial flutter; PAF = paroxysmal atrial fibrillation

4 Allowed but not assigned; dig = digoxin; AC = antithrombotic therapy with aspirin, warfarin or heparin; DCC = direct current cardioversion; ccb = calcium-channel-blocker; bb = Beta-blocker

5 MI = recent myocardial infarction or angina pectoris; valve = valvular heart disease; antiarr = other antiarrhythmic agent use; CHF = congestive heart failure as defined by study; other = other system disease (hepatic, pulmonary, renal and/or endocrine)

6 Rep. = representativeness of population; Bias = bias/confounding; Tx = therapy description; Outcomes = outcomes assessment; Stats = statistical analysis; Overall = average of the five categorical scores; please see section 2.6.3 for a description of these categories

Evidence table 2. Design Characteristics of Studies on Pharmacological Maintenance of Sinus Rhythm in Atrial Fibrillation ^1^1 ^2^2 ^3^

Author, Journal, Year | N | Treatment Groups | | Other Treatments ^4^ | Inclusion Criteria ^3^ | Exclusion Criteria ^5^ | Quality ^6^
Author, Journal, Year | N | Regimen | n | Other Treatments ^4^ | Inclusion Criteria ^3^ | Exclusion Criteria ^5^ | Rep | Bias | Tx | Outcomes | Stats | Overall
Naccarelli, Am J Cardiol, 1996 | 239 | Quinidine 324-648 mg bid-tid po | 117 | dig, AC, bb, ccb | >18 yrs; PAF or Afl | MI, antiarr, CHF, other | 50 | 50 | 50 | 25 | 83 | 52
Naccarelli, Am J Cardiol, 1996 | 239 | Flecainide 50-150 mg bid po | 122 | dig, AC, bb, ccb | >18 yrs; PAF or Afl | MI, antiarr, CHF, other | 50 | 50 | 50 | 25 | 83 | 52
Lau, Am Heart J, 1992 | 19 | Quinidine 600 mg bid po | 19 | bb | No age given; PAF | MI, CHF, other | 63 | 75 | 38 | 58 | 88 | 64
Lau, Am Heart J, 1992 | 19 | Flecainide 100 mg bid po | 19 | bb | No age given; PAF | MI, CHF, other | 63 | 75 | 38 | 58 | 88 | 64
Lau, Am Heart J, 1992 | 19 | Placebo | 19 | bb | No age given; PAF | MI, CHF, other | 63 | 75 | 38 | 58 | 88 | 64
Van Wijk, J Cardiovasc Pharmacol, 1989 | 26 | Quinidine 500 mg bid po | 24 | | <80 yrs; PAF | CHF, other | 50 | 50 | 100 | 58 | 70 | 66
Van Wijk, J Cardiovasc Pharmacol, 1989 | 26 | Flecainide 100 mg bid po | 26 | | <80 yrs; PAF | CHF, other | 50 | 50 | 100 | 58 | 70 | 66
Lee, J Intern Med, 1996 | 96 | Quinidine 200-400 mg qid po | 48 | | >15 yrs; PAF <48 hrs | CHF, other | 63 | 83 | 50 | 75 | 100 | 74
Lee, J Intern Med, 1996 | 96 | Propafenone 600-900 mg/day po | 48 | | >15 yrs; PAF <48 hrs | CHF, other | 63 | 83 | 50 | 75 | 100 | 74
Zehender, JACC, 1992 | 23 | Quinidine 160 mg tid po + Verapamil 80 mg tid po | 20 | dig, AC | No age given; AF 4 wks-2 yrs | MI, CHF, antiarr, other | 63 | 50 | 75 | 83 | 83 | 71
Zehender, JACC, 1992 | 23 | Amiodarone 200 mg/day po | 20 | dig, AC | No age given; AF 4 wks-2 yrs | MI, CHF, antiarr, other | 63 | 50 | 75 | 83 | 83 | 71
Juul-Moller, Circulation, 1990 | 183 | Quinidine 600 mg bid po | 85 | | No age given; AF 2 mos-1 yr | MI, CHF, other | 63 | 50 | 100 | 75 | 88 | 75
Juul-Moller, Circulation, 1990 | 183 | Sotalol 80-160 mg bid po | 98 | | No age given; AF 2 mos-1 yr | MI, CHF, other | 63 | 50 | 100 | 75 | 88 | 75
Hohnloser, JACC, 1995 | 38 | Quinidine 250 mg bid po + Verapamil 80 mg qid po | 21 | AC | 18-80 yrs; AF 2 days-6 mos | MI, antiarr, CHF, other | 63 | 50 | 63 | 58 | 83 | 63
Hohnloser, JACC, 1995 | 38 | Sotalol 160 mg bid po | 17 | AC | 18-80 yrs; AF 2 days-6 mos | MI, antiarr, CHF, other | 63 | 50 | 63 | 58 | 83 | 63
Rasmussen, Acta Med Scand Suppl, 1981 | 50 | Quinidine 400 mg bid po + DCC | 50 | AC | No age given; AF >10 days | | 25 | 17 | 25 | 33 | 88 | 38
Rasmussen, Acta Med Scand Suppl, 1981 | 50 | Verapamil 80 mg tid po + DCC | 50 | AC | No age given; AF >10 days | | 25 | 17 | 25 | 33 | 88 | 38
Sodermark, Br Heart J, 1975 | 176 | Quinidine 600-800 mg bid po | 101 | dig, AC | No age given; AF <36 mos | | 50 | 50 | 63 | 75 | 50 | 58
Sodermark, Br Heart J, 1975 | 176 | Placebo | 75 | dig, AC | No age given; AF <36 mos | | 50 | 50 | 63 | 75 | 50 | 58
Byrne-Quinn, Br Heart J, 1970 | 65 | Quinidine 600 mg bid po | 28 | | No age given; AF | | 25 | 83 | 100 | 75 | 83 | 73
Byrne-Quinn, Br Heart J, 1970 | 65 | Placebo | 37 | | No age given; AF | | 25 | 83 | 100 | 75 | 83 | 73
Hillestad, Br Heart J, 1971 | 100 | Quinidine 800-1200 mg/day po + DCC | 48 | AC | No age or duration specified | | 25 | 50 | 63 | 50 | 50 | 68
Hillestad, Br Heart J, 1971 | 100 | DCC | 52 | AC | No age or duration specified | | 25 | 50 | 63 | 50 | 50 | 68
Crijns, Cardiovasc Drugs Ther, 1996 | 56 | Disopyramide 250 mg tid po | 31 | dig, AC | 18-75 yrs; F or Afl | MI, CHF, antiarr, other | 50 | 50 | 33 | 80 | 25 | 48
Crijns, Cardiovasc Drugs Ther, 1996 | 56 | Propafenone 300 mg tid po | 25 | dig, AC | 18-75 yrs; F or Afl | MI, CHF, antiarr, other | 50 | 50 | 33 | 80 | 25 | 48
Martin, Br J Clin Pract Symp Suppl, 1986 | 70 | Disopyramide 100 mg qid po | 27 | | >65 yrs; PAF | MI | 13 | 50 | 38 | 50 | 50 | 40
Martin, Br J Clin Pract Symp Suppl, 1986 | 70 | Amiodarone 200 mg tid po x2 wks then 200 mg bid po x2 wks then 200 mg qd po | 43 | | >65 yrs; PAF | MI | 13 | 50 | 38 | 50 | 50 | 40
Karlson, Eur Heart J, 1988 | 90 | Disopyramide 250 mg bid po | 44 | dig, AC | No age given; AF >6 wks | MI, antiarr, other | 63 | 75 | 63 | 67 | 83 | 70
Karlson, Eur Heart J, 1988 | 90 | Placebo | 46 | dig, AC | No age given; AF >6 wks | MI, antiarr, other | 63 | 75 | 63 | 67 | 83 | 70
Hartel, Clin Pharmacol Ther, 1974 | 48 | Disopyramide 500 mg/day po | 24 | dig, AC | <70 yrs; AF >2 wks | MI, antiarr | 75 | 100 | 38 | 75 | 50 | 68
Hartel, Clin Pharmacol Ther, 1974 | 48 | Placebo | 24 | dig, AC | <70 yrs; AF >2 wks | MI, antiarr | 75 | 100 | 38 | 75 | 50 | 68
Aliot, Am J Cardiol, 1996 | 97 | Flecainide 50-100 mg bid po | 48 | dig, bb | >18 yrs; PAF | MI, CHF | 63 | 33 | 38 | 42 | 63 | 48
Aliot, Am J Cardiol, 1996 | 97 | Propafenone 150-300 mg bid po | 49 | dig, bb | >18 yrs; PAF | MI, CHF | 63 | 33 | 38 | 42 | 63 | 48
Van Gelder, Am J Cardiol, 1989 | 73 | Flecainide 100-150 mg bid po | 36 | AC, ccb | 16-80 yrs; AF >24 hrs | MI, antiarr, CHF, other | 88 | 67 | 63 | 25 | 63 | 61
Van Gelder, Am J Cardiol, 1989 | 73 | Placebo | 37 | AC, ccb | 16-80 yrs; AF >24 hrs | MI, antiarr, CHF, other | 88 | 67 | 63 | 25 | 63 | 61
Anderson, Circulation, 1989 | 48 | Flecainide 200-400 mg bid po | 48 | dig | >18 yrs; PAF or Afl | MI, antiarr, CHF, other | 63 | 83 | 88 | 67 | 100 | 80
Anderson, Circulation, 1989 | 48 | Placebo | 48 | dig | >18 yrs; PAF or Afl | MI, antiarr, CHF, other | 63 | 83 | 88 | 67 | 100 | 80
Pietersen, Am J Cardiol, 1991 | 43 | Flecainide 150 mg bid po | 43 | dig | No age given; PAF or Afl | CHF, other | 75 | 50 | 63 | 75 | 70 | 67
Pietersen, Am J Cardiol, 1991 | 43 | Placebo | 43 | dig | No age given; PAF or Afl | CHF, other | 75 | 50 | 63 | 75 | 70 | 67
Bellandi, Curr Ther Res, 1995 | 300 | Propafenone 4.3 mg/kg tid po | 102 | | No age given; PAF | MI, antiarr, CHF, other | 25 | 75 | 50 | 67 | 63 | 56
Bellandi, Curr Ther Res, 1995 | 300 | Sotalol 1 mg/kg tid po | 106 | | No age given; PAF | MI, antiarr, CHF, other | 25 | 75 | 50 | 67 | 63 | 56
Bellandi, Curr Ther Res, 1995 | 300 | Placebo | 92 | | No age given; PAF | MI, antiarr, CHF, other | 25 | 75 | 50 | 67 | 63 | 56
Lee, Am J Cardiol, 1997 | 79 | Propafenone 150-300 mg tid po | 41 | | >15 yrs; PAF <48 hrs | MI, antiarr, CHF, other | 50 | 50 | 33 | 67 | 50 | 50
Lee, Am J Cardiol, 1997 | 79 | Sotalol 80-160 mg bid po | 38 | | >15 yrs; PAF <48 hrs | MI, antiarr, CHF, other | 50 | 50 | 33 | 67 | 50 | 50
UK Propafenone PSVT Group, Circulation, 1995 | 48 | Propafenone 300 mg bid po | 48 | | 16-80 yrs; PAF | MI, antiarr, CHF other | 38 | 83 | 83 | 58 | 88 | 70
UK Propafenone PSVT Group, Circulation, 1995 | 48 | Propafenone 300 mg tid po | 48 | | 16-80 yrs; PAF | MI, antiarr, CHF other | 38 | 83 | 83 | 58 | 88 | 70
UK Propafenone PSVT Group, Circulation, 1995 | 48 | Placebo | 48 | | 16-80 yrs; PAF | MI, antiarr, CHF other | 38 | 83 | 83 | 58 | 88 | 70
Connolly, Am J Cardiol, 1989 | 11 | Propafenone up to 644 mg qd | 11 | dig | No age given; PAF | | 0 | 83 | 63 | 42 | 63 | 50
Connolly, Am J Cardiol, 1989 | 11 | Placebo | 11 | dig | No age given; PAF | | 0 | 83 | 63 | 42 | 63 | 50
Stroobandt, Am J Cardiol, 1997 | 102 | Propafenone 150 mg tid po | 77 | dig, AC | >18 yrs; AF recent onset <2 wks or AF >2 wks if chronic | MI, antiarr, CHF, other | 63 | 67 | 63 | 75 | 70 | 67
Stroobandt, Am J Cardiol, 1997 | 102 | Placebo | 25 | dig, AC | >18 yrs; AF recent onset <2 wks or AF >2 wks if chronic | MI, antiarr, CHF, other | 63 | 67 | 63 | 75 | 70 | 67
Singh, Am J Cardiol, 1991 | 34 | Sotalol 80-320 mg qd po + Digoxin po | 24 | dig, AC | >18 yrs; AF 2-52 wks | CHF, other | 25 | 67 | 38 | 58 | 63 | 50
Singh, Am J Cardiol, 1991 | 34 | Placebo + Digoxin po | 10 | dig, AC | >18 yrs; AF 2-52 wks | CHF, other | 25 | 67 | 38 | 58 | 63 | 50
The Atrial Fibrillation Investigation with Bidisomide (AFIB) Investigators, Circulation, 1997 | 1189 | Bidisomide 200 mg bid po | 240 | dig, AC, bb, ccb | No age given; AF or Afl | MI, CHF | 50 | 58 | 50 | 67 | 75 | 60
The Atrial Fibrillation Investigation with Bidisomide (AFIB) Investigators, Circulation, 1997 | 1189 | Bidisomide 400 mg bid po | 234 | dig, AC, bb, ccb | No age given; AF or Afl | MI, CHF | 50 | 58 | 50 | 67 | 75 | 60
The Atrial Fibrillation Investigation with Bidisomide (AFIB) Investigators, Circulation, 1997 | 1189 | Bidisomide 600 mg bid po | 235 | dig, AC, bb, ccb | No age given; AF or Afl | MI, CHF | 50 | 58 | 50 | 67 | 75 | 60
The Atrial Fibrillation Investigation with Bidisomide (AFIB) Investigators, Circulation, 1997 | 1189 | Placebo | 480 | dig, AC, bb, ccb | No age given; AF or Afl | MI, CHF | 50 | 58 | 50 | 67 | 75 | 60
Normand, Br Heart J, 1976 | 40 | Quinidine "long acting" 550 mg bid po | 20 | | No age given; AF >15 days | | 25 | 33 | 38 | 67 | 40 | 41
Normand, Br Heart J, 1976 | 40 | Quinidine, "short acting" 275 mg qid po | 20 | | No age given; AF >15 days | | 25 | 33 | 38 | 67 | 40 | 41
Feld, Cardiovasc Drugs Ther, 1989 | 18 | Quinidine up to 648 mg tid po + Digoxin .375 mg po | 10 | dig, ccb | No age given; Afl | | 25 | 50 | 63 | 67 | 75 | 51
Feld, Cardiovasc Drugs Ther, 1989 | 18 | N-acetylprocainamide up to 2.5 g tid po | 8 | dig, ccb | No age given; Afl | | 25 | 50 | 63 | 67 | 75 | 51
Babuty, J Clin Pharmacol, 1995 | 68 | Flecainide 50-100 mg bid po | 35 | dig, bb | 18-80 yrs; PAF or Afl | MI, antiarr, CHF, other | 50 | 67 | 63 | 50 | 50 | 56
Babuty, J Clin Pharmacol, 1995 | 68 | Cibenzoline 65-130 mg bid po | 33 | dig, bb | 18-80 yrs; PAF or Afl | MI, antiarr, CHF, other | 50 | 67 | 63 | 50 | 50 | 56
Kuhlkamp, Int J Cardiol, 1991 | 31 | Flecainide 200-300 mg/day po | 12 | dig, AC, ccb | No age given; AF >7 days | MI, CHF, other | 63 | 17 | 38 | 67 | 60 | 49
Kuhlkamp, Int J Cardiol, 1991 | 31 | Cibenzoline 260-320 mg/day po | 19 | dig, AC, ccb | No age given; AF >7 days | MI, CHF, other | 63 | 17 | 38 | 67 | 60 | 49

1 Encompasses only non-postoperative atrial fibrillation

2 Table ordered by Vaughan-Williams classification without any repetition of studies; miscellaneous drugs (with n=1 studies) or drugs considered as "control" in this analysis (verapamil, diltiazem, digoxin) are at end of table

3 AF = atrial fibrillation; Afl = atrial flutter; PAF = paroxysmal atrial fibrillation

4 Allowed but not assigned; dig = digoxin; AC = antithrombotic therapy with aspirin, warfarin or heparin; DCC = direct current cardioversion; ccb = calcium-channel-blocker; bb = Beta-blocker

5 MI = recent myocardial infarction or angina pectoris; valve = valvular heart disease; antiarr = other antiarrhythmic agent use; CHF = congestive heart failure as defined by study; other = other system disease (hepatic, pulmonary, renal and/or endocrine)

6 Rep = representativeness of population; Bias = bias/confounding; Tx = therapy description; Outcomes = outcomes assessment; Stats = statistical analysis; Overall = average of the five categorical scores; please see Section 2.6.3 for a description of these categories

Evidence table 3. Results of Studies on Pharmacological Conversion of Atrial Fibrillation ^1^ ^2^ ^3^

| Subject Characteristics | | | | | | | | Treatment Groups | | | Adverse Effects
Author, Journal, Year | N | Mean age (years) | Male % | Mean left atrial diameter (cm) | CAD ^4^ % | HTN ^5^ % | Valve ^6^ % | Afl ^3^ % | Regimen | # with successful cardioversion | | Ventricular fibrillation or torsades ^7^ | | Other arrhythmia ^8^ | | Other adverse effects ^9^ | | Comments ^3^
Author, Journal, Year | N | Mean age (years) | Male % | Mean left atrial diameter (cm) | CAD ^4^ % | HTN ^5^ % | Valve ^6^ % | Afl ^3^ % | | n/N | % | n/N | % | n/N | % | n/N | % | Comments ^3^
Capucci, Int J Cardiol, 1994 | 87 | | 64 | 3.7 | | 38 | 6 | | Quinidine | 23/29 | 79 | | | 0/29 | 0 | 1/29 | 3 | Study subjects defined as "recent-onset" AF
Capucci, Int J Cardiol, 1994 | 87 | | 64 | 3.7 | | 38 | 6 | | Propafenone | 26/29 | 90 | | | 0/29 | 0 | 2/29 | 7 | Study subjects defined as "recent-onset" AF
Capucci, Int J Cardiol, 1994 | 87 | | 64 | 3.7 | | 38 | 6 | | Placebo | 22/29 | 76 | | | 0/29 | 0 | 0/29 | 0 | Study subjects defined as "recent-onset" AF
Zehender, JACC, 1992 | 40 | 58 | 58 | 5.0 | 20 | 13 | 25 | | Quinidine | 5/20 | 25 | | | 0/20 | 0
Zehender, JACC, 1992 | 40 | 58 | 58 | 5.0 | 20 | 13 | 25 | | Amiodarone | 12/20 | 60 | | | 3/20 | 15
Hohnloser, JACC, 1995 | 50 | 62 | 36 | 5.0 | 30 | 20 | 28 | | Quinidine + Verapamil | 15/25 | 60 | 3/25 | 12 | 4/25 | 16 | 10/25 | 40
Hohnloser, JACC, 1995 | 50 | 62 | 36 | 5.0 | 30 | 20 | 28 | | Sotalol | 5/25 | 20 | 0/25 | 0 | 11/25 | 44 | 11/25 | 44
Halinen, Am J Cardiol, 1995 | 61 | 54 | 66 | | 25 | 38 | 3 | | Quinidine | 24/28 | 86 | | | 8/28 | 28 | | | Study subjects defined as "acute" AF
Halinen, Am J Cardiol, 1995 | 61 | 54 | 66 | | 25 | 38 | 3 | | Sotalol | 17/33 | 52 | | | 4/30 | 13 | | | Study subjects defined as "acute" AF
Rasmussen, Acta Med Scand Suppl, 1981 | 50 | | | | 30 | 23 | 11 | | Quinidine | 8/25 | 32
Rasmussen, Acta Med Scand Suppl, 1981 | 50 | | | | 30 | 23 | 11 | | Verapamil | 2/25 | 8
Byrne-Quinn Br Heart J 1970 | 92 | 54 | 53 | | | | 51 | | Quinidine | 5/45 | 11 | | | | | 1/45 | 2
Byrne-Quinn Br Heart J 1970 | 92 | 54 | 53 | | | | 51 | | Placebo | 0/47 | 0 | | | | | 0/47 | 0
Madrid, Eur Heart J, 1993 | 80 | 55 | 63 | 3.9 | 11 | 22 | 5 | | Procainamide | 25/40 | 63 | | | 0/40 | 0 | | | Study subjects defined as PAF
Madrid, Eur Heart J, 1993 | 80 | 55 | 63 | 3.9 | 11 | 22 | 5 | | Flecainide | 37/40 | 93 | | | 0/40 | 0 | | | Study subjects defined as PAF
Boudonas, Acta Cardiol 1995 | 30 | 47 | 46 | | | | | 23 | Disopyramide | 3/13 | 23 | | | | | | | 1) Afl results: diltiazem 0/4, disopyramide 1/3 2) Study subjects defined as PAF
Boudonas, Acta Cardiol 1995 | 30 | 47 | 46 | | | | | 23 | Diltiazem | 0/10 | 0 | | | | | | | 1) Afl results: diltiazem 0/4, disopyramide 1/3 2) Study subjects defined as PAF
Suttorp, JACC, 1990 | 50 | 59 | 68 | 3.8 | 28 | 8 | 14 | 20 | Flecainide | 18/20 | 90 | | | 3/25 | 12 | 0/25 | 0 | 1) Cardioversion results for AF subjects only reported here 2) Afl results: propafenone 2/5, flecainide 1/5 3) Study subjects defined as "PAF"
Suttorp, JACC, 1990 | 50 | 59 | 68 | 3.8 | 28 | 8 | 14 | 20 | Propafenone | 11/20 | 55 | | | 0/25 | 0 | 0/25 | 0 | 1) Cardioversion results for AF subjects only reported here 2) Afl results: propafenone 2/5, flecainide 1/5 3) Study subjects defined as "PAF"
Kingma, Am J Cardiol, 1992 | 90 | 59 | 74 | 3.5 | 22 | 13 | 9 | 18 | Flecainide | 32/37 | 86 | | | 4/64 | 6 | 0/64 | 0 | 1) Cardioversion results for AF subjects only reported here 2) Study subjects defined as "PAF" 3) Afl results: flecainide 1/8, propafenone 2/5, verapamil 0/3 4) Flecainide adverse effect numbers include subjects crossed over from other treatment arms
Kingma, Am J Cardiol, 1992 | 90 | 59 | 74 | 3.5 | 22 | 13 | 9 | 18 | Propafenone | 11/20 | 55 | | | 0/25 | 0 | 0/25 | 0
Kingma, Am J Cardiol, 1992 | 90 | 59 | 74 | 3.5 | 22 | 13 | 9 | 18 | Verapamil | 1/17 | 6 | | | 0/20 | 0 | 0/20 | 0
Baldi, New Trends Arrhythmias, 1993 | 50 | 52 | 64 | 3.5 | | 16 | 8 | | Flecainide | 20/26 | 77 | | | 2/22 | 9
Baldi, New Trends Arrhythmias, 1993 | 50 | 52 | 64 | 3.5 | | 16 | 8 | | Propafenone | 11/24 | 46 | | | 3/24 | 13
Capucci, Am J Cardiol, 1992 | 41 | 58 | 59 | 4.6 | | 34 | | | Flecainide | 21/22 | 95 | | | | | 0/22 | 0 | Study subjects defined as "recent onset" AF
Capucci, Am J Cardiol, 1992 | 41 | 58 | 59 | 4.6 | | 34 | | | Amiodarone | 17/19 | 89 | | | | | 0/19 | 0 | Study subjects defined as "recent onset" AF
Suttorp, Am J Cardiol, 1989 | 40 | 59 | 80 | 3.3 | 25 | 23 | 5 | | Flecainide | 14/20 | 70 | 0/20 | 0 | 0/20 | 0 | 0/20 | 0 | Study subjects defined as PAF
Suttorp, Am J Cardiol, 1989 | 40 | 59 | 80 | 3.3 | 25 | 23 | 5 | | Verapamil | 1/20 | 5 | 0/20 | 0 | 0/20 | 0 | 0/20 | 0 | Study subjects defined as PAF
Barranco, Intensive Care Med, 1994 | 15 | 67 | 63 | | | | | 27 | Flecainide | 4/5 | 80 | | | | | 0/7 | 0 | 1) Cardioversion results for AF subjects only reported here 2) Afl results: flecainine 1/2, verapamil 0/2
Barranco, Intensive Care Med, 1994 | 15 | 67 | 63 | | | | | 27 | Verapamil | 2/6 | 33 | | | | | 0/8 | 0 | 1) Cardioversion results for AF subjects only reported here 2) Afl results: flecainine 1/2, verapamil 0/2
Donovan, Am J Cardiol, 1992 | 49 | 60 | | | 31 | | | 15 | Flecainide | 13/25 | 52 | 1/51 | 2 | | | | | 1) Only non-postoperative data reported here for cardioversion outcome 2) Outcomes include AF and Afl 3) Study subjects defined as "acute" AF
Donovan, Am J Cardiol, 1992 | 49 | 60 | | | 31 | | | 15 | Placebo | 2/22 | 9 | 0/51 | 0 | | | | | 1) Only non-postoperative data reported here for cardioversion outcome 2) Outcomes include AF and Afl 3) Study subjects defined as "acute" AF
Bertini, J Emerg Med, 1990 | 28 | 67 | 41 | | | 44 | | | Propafenone | 13/16 | 81 | | | 2/16 | 12 | 0/16 | 0 | Cardioversion results on AF subjects only reported here
Bertini, J Emerg Med, 1990 | 28 | 67 | 41 | | | 44 | | | Amiodarone | 3/12 | 25 | | | 0/12 | 0 | 0/12 | 0 | Cardioversion results on AF subjects only reported here
Baroffio Clin Drug Invest, 1995 | 50 | 58 | 42 | | | 38 | | | Propafenone | 22/25 | 88 | | | 0/25 | 0 | 0/25 | 0
Baroffio Clin Drug Invest, 1995 | 50 | 58 | 42 | | | 38 | | | Digoxin | 8/25 | 32 | | | 0/25 | 0 | 0/25 | 0
Boriani, Chest, 1995 | 87 | 56 | 60 | 3.7 | | 52 | | | Propafenone (IV) | 19/29 | 66 | | | 0/29 | 0 | 1/29 | 3 | Study subjects defined as "recent onset" AF
Boriani, Chest, 1995 | 87 | 56 | 60 | 3.7 | | 52 | | | Propafenone (po) | 20/29 | 69 | | | 0/29 | 0 | 0/29 | 0 | Study subjects defined as "recent onset" AF
Boriani, Chest, 1995 | 87 | 56 | 60 | 3.7 | | 52 | | | Placebo | 7/29 | 24 | | | 0/29 | 0 | 0/29 | 0 | Study subjects defined as "recent onset" AF
Fresco, Clin Cardiol, 1996 | 75 | 54 | 67 | 4.0 | 1 | 13 | 5 | | Propafenone | 24/41 | 59 | | | | | 2/41 | 5 | Study subjects defined as PAF
Fresco, Clin Cardiol, 1996 | 75 | 54 | 67 | 4.0 | 1 | 13 | 5 | | Placebo | 10/34 | 29 | | | | | 1/34 | 3 | Study subjects defined as PAF
Stroobandt, Am J Cardiol, 1997 | 136 | 63 | 70 | 4.0 | 20 | 18 | 12 | | Propafenone | 29/101 | 29 | | | 3/101 | 3 | 4/10 | 4
Stroobandt, Am J Cardiol, 1997 | 136 | 63 | 70 | 4.0 | 20 | 18 | 12 | | Placebo | 6/35 | 17 | | | 2/35 | 6 | 0/35 | 0
Boriani, Ann Intern Med, 1997 | 240 | 59 | 57 | 4.2 | 8 | 31 | 7 | | Propafenone | 90/119 | 76 | 0/119 | 0 | 8/119 | 7 | | | Study subjects defined as "recent onset" AF
Boriani, Ann Intern Med, 1997 | 240 | 59 | 57 | 4.2 | 8 | 31 | 7 | | Placebo | 45/121 | 37 | 0/121 | 0 | 7/121 | 6 | | | Study subjects defined as "recent onset" AF
Azpitarte, Eur Heart J, 1997 | 55 | 59 | 38 | 3.6 | | | 16 | | Propafenone | 23/29 | 79 | 0/29 | 0 | 1/29 | 3 | | | 1) 27% PAF in study 2) Study subjects defined as "recent onset" AF
Azpitarte, Eur Heart J, 1997 | 55 | 59 | 38 | 3.6 | | | 16 | | Placebo | 19/26 | 73 | 0/25 | 0 | 1/25 | 4 | | | 1) 27% PAF in study 2) Study subjects defined as "recent onset" AF
Bellandi, Cardiovasc Drugs Ther, 1996 | 182 | 61 | 52 | 4.2 | 24 | 21 | 20 | | Propafenone | 89/98 | 91 | | | 0/98 | 0 | 0/98 | 0 | Study subjects defined as PAF
Bellandi, Cardiovasc Drugs Ther, 1996 | 182 | 61 | 52 | 4.2 | 24 | 21 | 20 | | Placebo | 27/84 | 32 | | | 0/84 | 0 | 0/84 | 0 | Study subjects defined as PAF
Bianconi, JACC, 1996 | 100 | 66 | 54 | 4.6 | 11 | 38 | 25 | | Propafenone | 3/49 | 6 | 0/51 | 0 | 5/49 | 10
Bianconi, JACC, 1996 | 100 | 66 | 54 | 4.6 | 11 | 38 | 25 | | Placebo | 0/51 | 0 | 0/49 | 0 | 0/42 | 0
Botto, Int J Cardiol, 1997 | 105 | 61 | 50 | 4.2 | 7 | 26 | 15 | | Propafenone (low) | 25/35 | 71 | | | 6/35 | 17 | 0/35 | 0 | Study subjects defined as PAF
Botto, Int J Cardiol, 1997 | 105 | 61 | 50 | 4.2 | 7 | 26 | 15 | | Propafenone (high) | 28/35 | 80 | | | 3/35 | 9 | 0/35 | 0 | Study subjects defined as PAF
Botto, Int J Cardiol, 1997 | 105 | 61 | 50 | 4.2 | 7 | 26 | 15 | | Placebo | 24/35 | 69 | | | 3/35 | 9 | 0/35 | 0 | Study subjects defined as PAF
Bianconi, New Trends Arrhythmias, 1993 | 35 | 66 | 51 | 4.7 | | | | | Propafenone | 1/16 | 6 | 0/16 | 0 | 0/16 | 0
Bianconi, New Trends Arrhythmias, 1993 | 35 | 66 | 51 | 4.7 | | | | | Placebo | 0/19 | 0 | 0/19 | 0 | 0/19 | 0
Noc, Am J Cardiol, 1990 | 24 | 71 | 63 | | | | | | Amiodarone | 10/13 | 77 | | | 0/13 | 0 | 0/13 | 0 | Study subjects defined as PAF
Noc, Am J Cardiol, 1990 | 24 | 71 | 63 | | | | | | Verapamil | 0/11 | 0 | | | 1/11 | 9 | 0/11 | 0 | Study subjects defined as PAF
Cowan, J Cardiovasc Pharmacol, 1986 | 34 | 68 | | | 76 | | | | Amiodarone | 15/18 | 83 | | | | | 1/18 | 6 | All subjects with acute suspected or proven myocardial infarction
Cowan, J Cardiovasc Pharmacol, 1986 | 34 | 68 | | | 76 | | | | Digoxin | 12/16 | 75 | | | | | 0/16 | 0 | All subjects with acute suspected or proven myocardial infarction
Hou, Eur Heart J, 1995 | 50 | 70 | 86 | 4.8 | 22 | 12 | 14 | | Amiodarone | 24/26 | 92 | | | | | 1/26 | 4
Hou, Eur Heart J, 1995 | 50 | 70 | 86 | 4.8 | 22 | 12 | 14 | | Digoxin | 17/24 | 71 | | | | | 0/24 | 0
Singh, Am J Cardiol, 1991 | 34 | 61 | 71 | 4.4 | | | | | Sotalol | 2/24 | 8 | | | 2/24 | | 1/24 | 4
Singh, Am J Cardiol, 1991 | 34 | 61 | 71 | 4.4 | | | | | Placebo | 2/10 | 20 | | | 0/10 | 0 | 0/10 | 0
Guo, JACC, 1996 | 35 | 67 | 94 | 4.4 | 60 | 43 | 9 | 100 | Ibutilide | see "Comments" | | | | | | | | Afl results: ibutilide 14/25, placebo 0/10
Guo, JACC, 1996 | 35 | 67 | 94 | 4.4 | 60 | 43 | 9 | 100 | Placebo | see "Comments" | | | | | | | | Afl results: ibutilide 14/25, placebo 0/10
Stambler, Circulation, 1996 | 242 | 67 | 80 | 4.6 | | | 71 | 50 | Ibutilide (low) | 35/79 | 44 | 15/161 | 9 | | | | | 1) Only one subject received "subthera¡peutic" ibutilide dose of 0.005 mg/kg 2) Adverse effect numbers combined for 2 ibutilide arms
Stambler, Circulation, 1996 | 242 | 67 | 80 | 4.6 | | | 71 | 50 | Ibutilide (high) | 40/82 | 49 | 15/161 | 9 | | | | | 1) Only one subject received "subthera¡peutic" ibutilide dose of 0.005 mg/kg 2) Adverse effect numbers combined for 2 ibutilide arms
Stambler, Circulation, 1996 | 242 | 67 | 80 | 4.6 | | | 71 | 50 | Placebo | 2/81 | 2 | 0/81 | 0 | | | | | 1) Only one subject received "subthera¡peutic" ibutilide dose of 0.005 mg/kg 2) Adverse effect numbers combined for 2 ibutilide arms
Ellenbogen, JACC, 1996 | 197 | 64 | 90 | 3.7 | | | 58 | 50 | Ibutilide (0.005 mg/kg) | 5/41 | 12 | 0/41 | 0 | | | | | 1) Overall cardioversion success for ibutilide at any dose: AF 29%, Afl 38% 2) Adverse effect numbers combined for 0.010-0.025 mg/kg ibutilide dose arms
Ellenbogen, JACC, 1996 | 197 | 64 | 90 | 3.7 | | | 58 | 50 | Ibutilide (0.010 mg/kg) | 13/39 | 33 | | | | | | | 1) Overall cardioversion success for ibutilide at any dose: AF 29%, Afl 38% 2) Adverse effect numbers combined for 0.010-0.025 mg/kg ibutilide dose arms
Ellenbogen, JACC, 1996 | 197 | 64 | 90 | 3.7 | | | 58 | 50 | Ibutilide (0.015 mg/kg) | 17/38 | 45 | 6/116 | 5 | | | | | 1) Overall cardioversion success for ibutilide at any dose: AF 29%, Afl 38% 2) Adverse effect numbers combined for 0.010-0.025 mg/kg ibutilide dose arms
Ellenbogen, JACC, 1996 | 197 | 64 | 90 | 3.7 | | | 58 | 50 | Ibutilide (0.025 mg/kg) | 18/39 | 46 | | | | | | | 1) Overall cardioversion success for ibutilide at any dose: AF 29%, Afl 38% 2) Adverse effect numbers combined for 0.010-0.025 mg/kg ibutilide dose arms
Ellenbogen, JACC, 1996 | 197 | 64 | 90 | 3.7 | | | 58 | 50 | Placebo | 1/40 | 3 | 0/40 | 0 | | | | | 1) Overall cardioversion success for ibutilide at any dose: AF 29%, Afl 38% 2) Adverse effect numbers combined for 0.010-0.025 mg/kg ibutilide dose arms
Falk, JACC, 1997 | 91 | 65 | 74 | 4.5 | 35 | 48 | 7 | 18 | Dofetilide (low) | 3/29 | 10 | 1/32 | 3 | | | | | Afl results: dofetilide (low) 1/3, dofetilide (high) 5/8, placebo 0/5
Falk, JACC, 1997 | 91 | 65 | 74 | 4.5 | 35 | 48 | 7 | 18 | Dofetilide (high) | 4/22 | 18 | 0/30 | 0 | | | | | Afl results: dofetilide (low) 1/3, dofetilide (high) 5/8, placebo 0/5
Falk, JACC, 1997 | 91 | 65 | 74 | 4.5 | 35 | 48 | 7 | 18 | Placebo | 0/30 | 0 | 0/30 | 0 | | | | | Afl results: dofetilide (low) 1/3, dofetilide (high) 5/8, placebo 0/5
Innes, Ann Emerg Med, 1997 | 41 | 60 | 61 | | 20 | 7 | 7 | | Quinidine and Verapamil | 16/19 | 84 | | | 0/19 | 0 | | | Study subjects defined as PAF
Innes, Ann Emerg Med, 1997 | 41 | 60 | 61 | | 20 | 7 | 7 | | Quinidine and Digoxin | 10/22 | 45 | | | 1/22 | 4 | | | Study subjects defined as PAF
Levi, Cardiology, 1973 | 54 | 57 | 40 | | 57 | | 43 | | Quinidine and Practolol | 11/26 | 42 | 1/26 | 4 | | | 1/26 | 4
Levi, Cardiology, 1973 | 54 | 57 | 40 | | 57 | | 43 | | Quinidine and Placebo | 13/28 | 46 | 0/28 | 0 | | | 1/28 | 4
Crijns, Eur Heart J, 1988 | 40 | 59 | 65 | | 33 | 10 | 8 | | Flecainide (po) | 10/20 | 50 | | | | | 0/20 | 0 | All converters had <24 hours duration of AF
Crijns, Eur Heart J, 1988 | 40 | 59 | 65 | | 33 | 10 | 8 | | Flecainide (IV) | 10/20 | 50 | | | | | 0/20 | 0 | All converters had <24 hours duration of AF
Kuhlkamp, Int J Cardiol, 1991 | 31 | 56 | 55 | 4.5 | 10 | 16 | 26 | | Flecainide | 3/12 | 25 | 0/24 | 0 | 2/24 | 8 | 0/24 | 0 | Adverse effect numbers include nonrandomized crossovers
Kuhlkamp, Int J Cardiol, 1991 | 31 | 56 | 55 | 4.5 | 10 | 16 | 26 | | Cibenzoline | 7/19 | 37 | 0/28 | 0 | 2/28 | 7 | 2/28 | 7 | Adverse effect numbers include nonrandomized crossovers
Toivonen, Br Heart J, 1986 | 40 | 50 | | 3.2 | 20 | 15 | | | Pirmenol | 12/20 | 60 | | | 0/20 | 0 | | | Study subjects defined as PAF
Toivonen, Br Heart J, 1986 | 40 | 50 | | 3.2 | 20 | 15 | | | Placebo | 3/20 | 15 | | | 0/20 | 0 | | | Study subjects defined as PAF
Atarashi, Am J Cardiol, 1996 | 75 | 56 | 68 | | 8 | 31 | 4 | | Pilsicainide | 18/40 | 45 | | | 0/40 | 0
Atarashi, Am J Cardiol, 1996 | 75 | 56 | 68 | | 8 | 31 | 4 | | Placebo | 3/35 | 9 | | | 0/35 | 0
Sweany, Clin Pharmacol, Ther, 1985 | 81 | 48 | 54 | | | | | 25 | Timolol | 5/29 | 17 | | | 1/48 | 2 | 2/78 | 3 | 1) Afl results: timolol 2/11, placebo 0/9 2) Adverse effect data includes subjects with junctional tachycardia
Sweany, Clin Pharmacol, Ther, 1985 | 81 | 48 | 54 | | | | | 25 | Placebo | 2/32 | 6 | | | 0/82 | 0 | 0/82 | 0 | 1) Afl results: timolol 2/11, placebo 0/9 2) Adverse effect data includes subjects with junctional tachycardia
Gullestad, Clin Cardiol, 1993 | 45 | 63 | 65 | | 47 | | 7 | 22 | Magnesium | 13/21 | 62 | | | 0/26 | 0 | 0/26 | 0 | Adverse effect numbers include subjects with supraventricular tachycardia
Gullestad, Clin Cardiol, 1993 | 45 | 63 | 65 | | 47 | | 7 | 22 | Verapamil | 11/24 | 46 | | | 0/31 | 0 | 6/31 | 19 | Adverse effect numbers include subjects with supraventricular tachycardia
Ochs, J Clin Pharmacol, 1985 | 30 | 51 | 40 | all <4.5 | | | 47 | | Diltiazem | 1/15 | 7
Ochs, J Clin Pharmacol, 1985 | 30 | 51 | 40 | all <4.5 | | | 47 | | Verapamil | 2/15 | 13
Falk, Ann Intern Med, 1987 | 36 | 60 | | 4.3 | 6 | 6 | 19 | | Digoxin | 9/18 | 50 | | | | | | | Study subjects defined as "recent onset" AF
Falk, Ann Intern Med, 1987 | 36 | 60 | | 4.3 | 6 | 6 | 19 | | Placebo | 8/18 | 44 | | | | | | | Study subjects defined as "recent onset" AF
The Digitalis in Acute Atrial Fibrillation (DAAF) Trial Group, Eur Heart J, 1997 | 239 | 66 | 54 | | 22 | 26 | 8 | | Digoxin | 60/117 | 51 | | | 4/117 | 3 | 4/117 | 3
The Digitalis in Acute Atrial Fibrillation (DAAF) Trial Group, Eur Heart J, 1997 | 239 | 66 | 54 | | 22 | 26 | 8 | | Placebo | 56/122 | 46 | | | 0/122 | 0 | 0/122 | 0
Jordaens, Eur Heart J, 1997 | 39 | 64 | 59 | | | | | | Digoxin | 9/19 | 47 | | | 1/19 | 5
Jordaens, Eur Heart J, 1997 | 39 | 64 | 59 | | | | | | Placebo | 8/20 | 40 | | | 0/20 | 0

1 Encompasses only non-postoperative atrial fibrillation

2 Table ordered by Vaughan-Williams classification without any repetition of studies; miscellaneous drugs (with n=1 studies) or drugs considered as "control" in this analysis (verapamil, diltiazem, digoxin) are at end of table

3 AF = atrial fibrillation; Afl = atrial flutter; PAF = paroxysmal atrial fibrillation

4 CAD = coronary artery disease

5 HTN = hypertension

6 Valve = valvular disease

7 Includes ventricular fibrillation, polymorphic ventricular tachycardia, or torsades de pointes

8 Includes symptomatic bradycardia, junctional rhythms, nonsustained ventricular tachycardias, and monomorphic ventricular tachycardia

9 Reported adverse effects include only those causing study drug cessation or dosage decrease

Evidence table 4. Results of Studies on Pharmacological Conversion in Conjunction with Direct Current Cardioversion^1^ of Atrial Fibrillation^2^ ^3^ ^4^

| Subject Characteristics | | | | | | | | Treatment Groups | | | Adverse Effects | | | | | | Comments ^4^
Author, Journal, Year | N | Mean age (years) | Male % | Mean left atrial diameter (cm) | CAD ^5^ % | HTN ^6^ % | Valve ^7^ % | Afl ^4^ % | Regimen | # with successful cardioversion ^8^ | | Ventricular fibrillation or torsades ^9^ | | Other arrhythmia ^10^ | | Other adverse effects ^11^ | | Comments ^4^
Author, Journal, Year | N | Mean age (years) | Male % | Mean left atrial diameter (cm) | CAD ^5^ % | HTN ^6^ % | Valve ^7^ % | Afl ^4^ % | | n/N | % | n/N | % | n/N | % | n/N | % | Comments ^4^
Halinen, Am J Cardiol, 1995 | 61 | 54 | 66 | | 25 | 38 | 3 | | Quinidine | 28/28 | 100 | | | 8/28 | 28 | | | Study subjects defined as"acute" AF
Halinen, Am J Cardiol, 1995 | 61 | 54 | 66 | | 25 | 38 | 3 | | Sotalol | 30/33 | 91 | | | 4/30 | 13 | | | Study subjects defined as"acute" AF
Hohnloser, JACC, 1995 | 50 | 62 | 36 | 5.0 | 30 | 20 | 28 | | Quinidine | 22/25 | 88 | 3/25 | 12 | 4/25 | 16 | 10/25 | 40
Hohnloser, JACC, 1995 | 50 | 62 | 36 | 5.0 | 30 | 20 | 28 | | Sotalol | 17/25 | 68 | 0/25 | 0 | 11/25 | 44 | 11/25 | 44
Rasmussen Acta Med Scand SUPpl, 1981 | 50 | | | | 30 | 23 | 11 | | Quinidine | 24/25 | 96
Rasmussen Acta Med Scand SUPpl, 1981 | 50 | | | | 30 | 23 | 11 | | Verapamil | 24/25 | 96
Byrne-Quinn, Br Heart J, 1970 | 92 | 54 | 53 | | | | 51 | | Quinidine | 33/45 | 73 | | | | | 1/45 | 2
Byrne-Quinn, Br Heart J, 1970 | 92 | 54 | 53 | | | | 51 | | Placebo | 37/47 | 78 | | | | | 0/47 | 0
Hillestad, Br Heart J, 1971 | 100 | 54 | 46 | | 10 | | 69 | | Quinidine | 40/48 | 83
Hillestad, Br Heart J, 1971 | 100 | 54 | 46 | | 10 | | 69 | | DCC alone | 42/52 | 81
Bianconi, JACC, 1996 | 100 | 66 | 54 | 4.6 | 11 | 38 | 25 | | Propafenone | 41/49 | 84 | 0/51 | 0 | 5/49 | 10
Bianconi, JACC, 1996 | 100 | 66 | 54 | 4.6 | 11 | 38 | 25 | | Placebo | 42/51 | 82 | 0/49 | 0 | 0/42 | 0
Stroobandt, Am J Cardiol, 1997 | 136 | 63 | 70 | 4.0 | 20 | 18 | 12 | | Propafenone | 77/101 | 76 | | | 3/101 | 3 | 4/10 | 4
Stroobandt, Am J Cardiol, 1997 | 136 | 63 | 70 | 4.0 | 20 | 18 | 12 | | Placebo | 25/35 | 71 | | | 2/35 | 6 | 0/35 | 0
Bianconi, New Trends Arrhythmias, 1993 | 35 | 66 | 51 | 4.7 | | | | | Propafenone | 12/16 | 75 | 0/16 | 0 | 0/16 | 0
Bianconi, New Trends Arrhythmias, 1993 | 35 | 66 | 51 | 4.7 | | | | | Placebo | 14/19 | 74 | 0/19 | 0 | 0/19 | 0
Singh, Am J Cardiol, 1991 | 34 | 61 | 71 | 4.4 | | | | | Sotalol | 12/24 | 50 | | | 2/24 | 8 | 1/24 | 4
Singh, Am J Cardiol, 1991 | 34 | 61 | 71 | 4.4 | | | | | Placebo | 6/10 | 60 | | | 1/10 | 0 | 0/10 | 0

1 DCC = direct current cardioversion

2 Encompasses only non-postoperative atrial fibrillation

3 Table ordered by Vaughan-Williams classification without any repetition of studies; miscellaneous drugs (with n=1 studies) or drugs considered as "control" in this analysis (verapamil, diltiazem, digoxin) are at end of table

4 AF = atrial fibrillation; Afl = atrial flutter; PAF = paroxysmal atrial fibrillation

5 CAD = coronary artery disease

6 HTN = hypertension

7 Valve = valvular disease

8 Cardioversion results represent successful cardioversion by both study drug alone and subsequent DCC

9 Includes ventricular fibrillation, polymorphic ventricular tachycardia, or torsades de pointes

10 Includes symptomatic bradycardia, junctional rhythms, nonsustained ventricular tachycardias, and monomorphic ventricular tachycardia

11 Reported adverse effects include only those causing study drug cessation or dosage decrease

Evidence table 5 Results of Studies on Pharmacological Maintenance of Sinus Rhythm in Atrial Fibrillation ^1^ ^2^ ^3^

| | Subject Characteristics | | | | | | | | Treatment Groups | | | | Adverse Effects | | | | | | Comments ^3^
Author, Journal, Year | N | Mean age (years) | Male % | Mean left atrial diameter (cm) | CAD ^4^ % | HTN ^5^ % | Valve ^6^ % | PAF 3 % | Afl ^3^ % | Regimen | # with successful cardioversion ^7^ , ^8^ | | | Ventricular fibrillation or torsades ^9^ | | Other arrhythmia ^10^ | | Other adverse effects ^11^
Author, Journal, Year | N | Mean age (years) | Male % | Mean left atrial diameter (cm) | CAD ^4^ % | HTN ^5^ % | Valve ^6^ % | PAF 3 % | Afl ^3^ % | Regimen | n/N | % | Goal F/U Time (months) | n/N | % | n/N | % | n/N | %
Naccarelli, Am J Cardiol, 1996 | 239 | 58 | 54 | | 6 | 39 | 4 | 92 | 8 | Quinidine | 24/117 | 21 | 9 | 0/117 | 0 | 2/117 | 2 | 35/117 | 30 | 1) Study subjects defined as PAF or paroxysmal Afl 2) "attack free" time: flecainide 72% of patient-months; quinidine 74% of patient-months
Naccarelli, Am J Cardiol, 1996 | 239 | 58 | 54 | | 6 | 39 | 4 | 92 | 8 | Flecainide | 29/122 | 24 | 9 | 0/122 | 0 | 1/122 | 1 | 22/122 | 18 | 1) Study subjects defined as PAF or paroxysmal Afl 2) "attack free" time: flecainide 72% of patient-months; quinidine 74% of patient-months
Lau, Am Heart J, 1992 | 19 | 59 | 37 | | 0 | | 0 | | | Quinidine | 2/18 | 11 | 2 | | | | | 0/18 | 0 | Study subjects defined as PAF
Lau, Am Heart J, 1992 | 19 | 59 | 37 | | 0 | | 0 | | | Flecainide | 4/18 | 22 | 2 | | | | | 0/18 | 0 | Study subjects defined as PAF
Lau, Am Heart J, 1992 | 19 | 59 | 37 | | 0 | | 0 | | | Placebo | 0/15 | 0 | 2 | | | | | 0/15 | 0 | Study subjects defined as PAF
van Wijk, J Cardiovasc Pharmacol, 1989 | 26 | 60 | 35 | | 27 | 15 | 15 | | | Quinidine | 8/23 | 35 | 1 | 0/24 | 0 | | | 5/24 | 21 | 1) Results based on 24 hr Holter 2) Study subjects defined as PAF 3) Results on final dose of medication during study period
van Wijk, J Cardiovasc Pharmacol, 1989 | 26 | 60 | 35 | | 27 | 15 | 15 | | | Flecainide | 13/26 | 50 | 1 | 0/26 | 0 | | | 5/25 | 20 | 1) Results based on 24 hr Holter 2) Study subjects defined as PAF 3) Results on final dose of medication during study period
Lee, Am J Cardiol, 1997 | 96 | 61 | 69 | 3.7 | 7 | 27 | 3 | | | Quinidine | 10/46 | 22 | 3 | 0/48 | 0 | | | 2/48 | 4 | Study subjects defined as PAF
Lee, Am J Cardiol, 1997 | 96 | 61 | 69 | 3.7 | 7 | 27 | 3 | | | Propafenone | 23/46 | 50 | 3 | 0/48 | 0 | | | 2/48 | 4 | Study subjects defined as PAF
Zehender, JACC, 1992 | 23 | 58 | 58 | 5.0 | 20 | 13 | 25 | | | Quinidine | 10/11 | 91 | 3 | | | | | 0/11 | 0
Zehender, JACC, 1992 | 23 | 58 | 58 | 5.0 | 20 | 13 | 25 | | | Amiodarone | 11/12 | 92 | 3 | | | | | 0/12 | 0
Juul-Moller, Circulation, 1990 | 183 | 59 | 81 | 4.2 | 16 | 26 | 7 | | 22 | Quinidine | 38/79 | 48 | 6 | 1/85 | 1 | | | 22/85 | 26
Juul-Moller, Circulation, 1990 | 183 | 59 | 81 | 4.2 | 16 | 26 | 7 | | 22 | Sotalol | 49/95 | 52 | 6 | 1/98 | 1 | | | 11/98 | 11
Hohnloser, JACC, 1995 | 38 | 62 | 36 | 5.0 | 30 | 20 | 28 | | | Quinidine + Verapamil | 16/21 | 76 | 2 | 3/25 | 12 | | | 10/25 | 40 | Unable to determine data at 6 mo F/U
Hohnloser, JACC, 1995 | 38 | 62 | 36 | 5.0 | 30 | 20 | 28 | | | Sotalol | 13/17 | 76 | 2 | 0/25 | 0 | | | 11/25 | 44 | Unable to determine data at 6 mo F/U
Rasmussen, Acta Med Scand Suppl, 1981 | 50 | | | | 30 | 23 | 11 | | | Quinidine | 7/? | NR | 3-33 | | | | | 5/25 | 20 | Quinidine found to be statistically significant as better treatment
Rasmussen, Acta Med Scand Suppl, 1981 | 50 | | | | 30 | 23 | 11 | | | Verapamil | 22/? | NR | 3-33 | | | | | 0/25 | 0 | Quinidine found to be statistically significant as better treatment
Sodermark, Br Heart J, 1975 | 176 | 58 | 71 | | 30 | 9 | 30 | 0 | 7 | Quinidine | 52/75 | 69 | 12 | | | | | 58/101 | 58
Sodermark, Br Heart J, 1975 | 176 | 58 | 71 | | 30 | 9 | 30 | 0 | 7 | Placebo | 21/70 | 30 | 12 | | | | | 0/75 | 0
Byrne-Quinn, Br Heart J, 1970 | 65 | 54 | 53 | | | | 51 | | | Quinidine | 16/28 | 57 | 5-15 | | | | | 2/47 | 4
Byrne-Quinn, Br Heart J, 1970 | 65 | 54 | 53 | | | | 51 | | | Placebo | 9/37 | 24 | 5-15 | | | | | 0/47 | 0
Hillestad, Br Heart J, 1971 | 100 | 54 | 46 | | 10 | | 69 | | | Quinidine + DCC | 15/48 | 31 | 12 | | | | | 3/48 | 6
Hillestad, Br Heart J, 1971 | 100 | 54 | 46 | | 10 | | 69 | | | DCC | 8/52 | 15 | 12 | | | | | 0/52 | 0
Crijns, Cardiovasc Drugs Ther, 1996 | 56 | 60 | 70 | | 14 | 16 | 32 | 0 | | Disopyramide | 18/31 | 58 | 6 | 0/31 | 0 | | | 17/31 | 55 | Life table analysis
Crijns, Cardiovasc Drugs Ther, 1996 | 56 | 60 | 70 | | 14 | 16 | 32 | 0 | | Propafenone | 11/25 | 44 | 6 | 0/25 | 0 | | | 6/25 | 55 | Life table analysis
Martin, Br J Clin Pract Symp Suppl, 1986 | 70 | 75 | 41 | | | | | | | Disopyramide | 12/22 | 55 | 1 | | | | | 14/27 | 52 | Data represent interim results
Martin, Br J Clin Pract Symp Suppl, 1986 | 70 | 75 | 41 | | | | | | | Amiodarone | 34/43 | 79 | 1 | | | | | 4/43 | 9 | Data represent interim results
Karlson, Eur Heart J, 1988 | 90 | 60 | 72 | | 15 | 13 | 18 | | | Disopyramide | 24/44 | 54 | 12 | | | | | 5/44 | 11 | Life table analysis
Karlson, Eur Heart J, 1988 | 90 | 60 | 72 | | 15 | 13 | 18 | | | Placebo | 14/46 | 30 | 12 | | | | | 2/46 | 4 | Life table analysis
Hartel, Clin Pharm Ther, 1974 | 48 | 55 | 60 | | 38 | 6 | 23 | | | Disopyramide | 13/18 | 72 | 3 | | | | | 0/18 | 0
Hartel, Clin Pharm Ther, 1974 | 48 | 55 | 60 | | 38 | 6 | 23 | | | Placebo | 6/20 | 30 | 3 | | | | | 0/20 | 0
Aliot, Am J Cardiol, 1996 | 97 | 63 | 53 | | 4 | 32 | 0 | 95 | 5 | Flecainide | 14/48 | -30 | 12 | 0/48 | 0 | 0/48 | 0 | 2/48 | 4 | 1) Life table analysis 2) Study subjects defined as PAF or paroxysmal Afl 3) "Attack free" time: flecainide = 82% of patient-months, propafenone = 82% of patient-months
Aliot, Am J Cardiol, 1996 | 97 | 63 | 53 | | 4 | 32 | 0 | 95 | 5 | Propafenone | 15/49 | -30 | 12 | 1/49 | 2 | 1/49 | 2 | 9/49 | 18 | 1) Life table analysis 2) Study subjects defined as PAF or paroxysmal Afl 3) "Attack free" time: flecainide = 82% of patient-months, propafenone = 82% of patient-months
Van Gelder, Am J Cardiol, 1989 | 73 | 58 | 60 | 4.4 | 28 | 10 | 38 | | | Flecainide | 18/36 | 49 | 12 | 0/36 | 0 | | | 3/58 | 5 | Life table analysis
Van Gelder, Am J Cardiol, 1989 | 73 | 58 | 60 | 4.4 | 28 | 10 | 38 | | | Placebo | 13/37 | 36 | 12 | 0/37 | 0 | | | 0/36 | 0 | Life table analysis
Anderson, Circulation, 1989 | 48 | 56 | 63 | | 29 | 38 | 2 | | | Flecainide | 15/48 | 31 | 2 | | | | | 3/64 | 5 | Study subjects defined as PAF
Anderson, Circulation, 1989 | 48 | 56 | 63 | | 29 | 38 | 2 | | | Placebo | 4/48 | 8 | 2 | | | | | 0/53 | 0 | Study subjects defined as PAF
Pietersen, Am J Cardiol, 1991 | 43 | 53 | 53 | | 7 | 5 | 2 | | 16 | Flecainide | 31/43 | 72 | 3 | | | | | 2/43 | 5 | Study subjects defined as PAF or paroxysmal Afl
Pietersen, Am J Cardiol, 1991 | 43 | 53 | 53 | | 7 | 5 | 2 | | 16 | Placebo | NR | NR | 3 | | | | | 0/43 | 0 | Study subjects defined as PAF or paroxysmal Afl
Bellandi, Curr Ther Res, 1995 | 300 | 52 | 56 | 4.1 | 18 | 36 | 14 | | | Propafenone | 53/96 | 55 | 12 | | | 0/99 | 0 | 3/99 | 3 | Study subjects defined as PAF
Bellandi, Curr Ther Res, 1995 | 300 | 52 | 56 | 4.1 | 18 | 36 | 14 | | | Sotalol | 67/95 | 70 | 12 | | | 2/100 | 2 | 5/100 | 5 | Study subjects defined as PAF
Bellandi, Curr Ther Res, 1995 | 300 | 52 | 56 | 4.1 | 18 | 36 | 14 | | | Placebo | 23/90 | 25 | 12 | | | 0/92 | 0 | 0/92 | 0 | Study subjects defined as PAF
Lee, Am J Cardiol, 1997 | 79 | 62 | 70 | 3.7 | 20 | 33 | | | | Propafenone | 15/39 | 38 | 3 | 0/41 | 0 | 0/41 | 0 | 2/41 | 25
Lee, Am J Cardiol, 1997 | 79 | 62 | 70 | 3.7 | 20 | 33 | | | | Sotalol | 12/34 | 35 | 3 | 0/38 | 0 | 2/38 | 6 | 4/38 | 11
UK Propafenone PSVT Group, Circulation, 1995 | 48 | 67 | 46 | | 4 | | 6 | | | Propafenone (low) | 17/30 | 57 | 3 | 1/30 | 3
UK Propafenone PSVT Group, Circulation, 1995 | 48 | 67 | 46 | | 4 | | 6 | | | Propafenone (high) | 14/25 | 56 | 3 | 0/30 | 0
UK Propafenone PSVT Group, Circulation, 1995 | 48 | 67 | 46 | | 4 | | 6 | | | Placebo | 15/55 | 27 | 3 | 0/55 | 0
Connolly, Am J Cardiol, 1989 | 11 | | | | 75 | 9 | 27 | | | Propafenone | 3/11 | 27 | 1 | | | | | 0/12 | 0 | Study subjects defined as PAF
Connolly, Am J Cardiol, 1989 | 11 | | | | 75 | 9 | 27 | | | Placebo | 0/11 | 0 | 1 | | | | | 0/12 | 0 | Study subjects defined as PAF
Stroobandt, Am J Cardiol, 1997 | 102 | 62 | 70 | 4.0 | 20 | 18 | 12 | | | Propafenone | 40/60 | 67 | 6 | | | | | 5/77 | 7
Stroobandt, Am J Cardiol, 1997 | 102 | 62 | 70 | 4.0 | 20 | 18 | 12 | | | Placebo | 8/23 | 35 | 6 | | | | | 2/25 | 8
Singh, Am J Cardiol, 1991 | 34 | 61 | 71 | 4.4 | | | | | | Sotalol | 5/12 | 42 | 6 | | | 2/24 | 8 | 3/24 | 13
Singh, Am J Cardiol, 1991 | 34 | 61 | 71 | 4.4 | | | | | | Placebo | 0/6 | 0 | 6 | | | 0/10 | 0 | 0/10 | 0
The Atrial Fibrillation Investigation with Bidisomide (AFIB) Investigators, Circulation, 1997 | 1189 | 63 | 62 | | 31 | 51 | | | | Bidisomide 200 mg | 1.19 | | 12 | | | | | | | 1) Study terminated due to lack of efficacy and increased mortality trend of Bidisomide 2) Results reported are hazard ratios relative to placebo arm
The Atrial Fibrillation Investigation with Bidisomide (AFIB) Investigators, Circulation, 1997 | 1189 | 63 | 62 | | 31 | 51 | | | | Bidisomide 400 mg | 1.03 | | 12 | | | | | | | 1) Study terminated due to lack of efficacy and increased mortality trend of Bidisomide 2) Results reported are hazard ratios relative to placebo arm
The Atrial Fibrillation Investigation with Bidisomide (AFIB) Investigators, Circulation, 1997 | 1189 | 63 | 62 | | 31 | 51 | | | | Bidisomide 600 mg | 1.14 | | 12 | | | | | | | 1) Study terminated due to lack of efficacy and increased mortality trend of Bidisomide 2) Results reported are hazard ratios relative to placebo arm
The Atrial Fibrillation Investigation with Bidisomide (AFIB) Investigators, Circulation, 1997 | 1189 | 63 | 62 | | 31 | 51 | | | | Placebo | - | | 12 | | | | | | | 1) Study terminated due to lack of efficacy and increased mortality trend of Bidisomide 2) Results reported are hazard ratios relative to placebo arm
Normand, Br Heart J, 1976 | 40 | 60 | 73 | | | 5 | | | | Quinidine "long acting" | 12/20 | 61 | 18 | | | | | 10/20 | 50 | Life table analysis
Normand, Br Heart J, 1976 | 40 | 60 | 73 | | | 5 | | | | Quinidine "short acting" | 6/20 | 28 | 18 | | | | | 3/20 | 15 | Life table analysis
Feld, Cardiovasc Drugs Ther, 1989 | 18 | 67 | 100 | 4.5 | 56 | 44 | 6 | | 100 | Quinidine | see "Comments" | | 18 | | | | | 4/12 | 25 | 1) Study included nonrandomized crossovers 2) Afl results: quinidine 8/11, N-acetyl procainamide 12/12
Feld, Cardiovasc Drugs Ther, 1989 | 18 | 67 | 100 | 4.5 | 56 | 44 | 6 | | 100 | N-acetyl procainamide | see "Comments" | | 18 | | | | | 1/12 | 8 | 1) Study included nonrandomized crossovers 2) Afl results: quinidine 8/11, N-acetyl procainamide 12/12
Babuty, J Clin Pharmacol, 1995 | 68 | 63 | 53 | | 13 | 24 | 21 | | 18 | Flecainide | 20/28 | 71 | 6 | 0/35 | 0 | 1/35 | 3 | 3/35 | 9 | Study subjects defined as PAF or paroxysmal Afl
Babuty, J Clin Pharmacol, 1995 | 68 | 63 | 53 | | 13 | 24 | 21 | | 18 | Cibenzoline | 15/24 | 63 | 6 | 0/33 | 0 | 2/33 | 6 | 7/33 | 21 | Study subjects defined as PAF or paroxysmal Afl
Kuhlkamp, Int J Cardiol, 1991 | 31 | 56 | 55 | 4.5 | 10 | 16 | 26 | | | Flecainide | 4/6 | 66 | 12 | 0/6 | 0 | | | 0/24 | 0 | Adverse effect numbers include nonrandomized crossovers
Kuhlkamp, Int J Cardiol, 1991 | 31 | 56 | 55 | 4.5 | 10 | 16 | 26 | | | Cibenzoline | 4/6 | 66 | 12 | 0/6 | 0 | | | 2/28 | 7 | Adverse effect numbers include nonrandomized crossovers

1 Encompasses only non-postoperative atrial fibrillation

2 Table ordered by Vaughan-Williams classification without any repetition of studies; miscellaneous drugs (with n=1 studies) or drugs considered as "control" in this analysis (verapamil, diltiazem, digoxin) are at end of table

3 AF = atrial fibrillation; Afl = atrial flutter; PAF = paroxysmal atrial fibrillation

4 CAD = coronary artery disease

5 HTN = hypertension

6 Valve = valvular disease

Successful maintenance of sinus rhythm defined as no episodes of atrial fibrillation flutter durings study followup

8 NR = not reported; NA = not applicable due to life-table analysis

9 Includes ventricular fibrillation, polymorphic ventricular tachncardia, or torsades de pointes

10 Includes symptomatic brachycardia, junctional rhythms, nonsustained ventricular tachycardias, and monomorphic ventricular tachycardias

11 Reported adverse effects include only those causing study drug cessation or dosage decrease

Evidence table 6A. Design of Placebo-Controlled Trials of Calcium-Channel-Blockers for Rate Control in Atrial Fibrillation^1^

Author, Journal, Year | Total No. of Subjects and Study Design | Treatment Groups | | | | Study Quality ^2^
Author, Journal, Year | Total No. of Subjects and Study Design | Regimen | Followup | Other Permitted Therapies | Inclusion/Exclusion Criteria ^3^ | Rep. | Bias | Tx | Outcomes | Stats. | Overall
Goldenberg, Am J Cardiol, 1994 | 37 2 arms | Diltiazem 0.25 mg/kg IV then 0.35 mg/kg if needed; maintenance of 10-15 mg/hr | 4 hours | Digoxin | I: age >18 years, HR > 120 bpm, CHF III or IV E: none specified | 50 | 67 | 50 | 50 | 75 | 58
Goldenberg, Am J Cardiol, 1994 | 37 2 arms | Placebo | 4 hours | Digoxin | I: age >18 years, HR > 120 bpm, CHF III or IV E: none specified | 50 | 67 | 50 | 50 | 75 | 58
Ellenbogen, JACC, 1991 | 44 2 arms | Diltiazem 10 mg/hr IV, could titrate up to 15 mg/hr if needed | 24 hours | Digoxin | I: >18 years, on digoxin E: MAT, CHF III or IV, COPD, Ren, Hep, SSS | 38 | 75 | 83 | 80 | 83 | 72
Ellenbogen, JACC, 1991 | 44 2 arms | Placebo | 24 hours | Digoxin | I: >18 years, on digoxin E: MAT, CHF III or IV, COPD, Ren, Hep, SSS | 38 | 75 | 83 | 80 | 83 | 72
Salerno, Am J Cardiol, 1989 | 11 32 arms | Diltiazem 0.25 mg/kg IV | 17 minutes | | I: age >18 years, rate > 120 bpm E: CHF III or IV, recent MI, electrolyte abn., SSS, MAT, shock | 50 | 75 | 50 | 80 | 75 | 66
Salerno, Am J Cardiol, 1989 | 11 32 arms | Placebo | 17 minutes | | I: age >18 years, rate > 120 bpm E: CHF III or IV, recent MI, electrolyte abn., SSS, MAT, shock | 50 | 75 | 50 | 80 | 75 | 66
Lewis, Irvine et al., Eur Heart J, 1988 | 6 crossover, 6 way | Digoxin 0.25 mg x 1 | Hours | | I: NYHA Class I E: none specified | 13 | 63 | 63 | 67 | 50 | 51
Lewis, Irvine et al., Eur Heart J, 1988 | 6 crossover, 6 way | Diltiazem 60 mg x 1 | Hours | | I: NYHA Class I E: none specified | 13 | 63 | 63 | 67 | 50 | 51
Lewis, Irvine et al., Eur Heart J, 1988 | 6 crossover, 6 way | Diltiazem 120 mg x 1 | Hours | | I: NYHA Class I E: none specified | 13 | 63 | 63 | 67 | 50 | 51
Lewis, Irvine et al., Eur Heart J, 1988 | 6 crossover, 6 way | Digoxin 0.25 mg x 1 diltiazem 120 mg x 1 | Hours | | I: NYHA Class I E: none specified | 13 | 63 | 63 | 67 | 50 | 51
Lewis, Irvine et al., Eur Heart J, 1988 | 6 crossover, 6 way | Verapamil 80 mg x 1 | | | I: NYHA Class I E: none specified | 13 | 63 | 63 | 67 | 50 | 51
Lewis, Irvine et al., Eur Heart J, 1988 | 6 crossover, 6 way | Placebo | | | I: NYHA Class I E: none specified | 13 | 63 | 63 | 67 | 50 | 51
Lundstrom, JACC, 1990 | 19 crossover, 3 way | Diltiazem 90 mg tid | 3 weeks | Digoxin | I: > 1 month E: none specified | 25 | 67 | 88 | 67 | 67 | 63
Lundstrom, JACC, 1990 | 19 crossover, 3 way | Verapamil 80 mg tid | 3 weeks | Digoxin | I: > 1 month E: none specified | 25 | 67 | 88 | 67 | 67 | 63
Lundstrom, JACC, 1990 | 19 crossover, 3 way | Placebo | 3 weeks | Digoxin | I: > 1 month E: none specified | 25 | 67 | 88 | 67 | 67 | 63
Lundstrom, Am Heart J, 1992 | 21 crossover, 4 way | Xamoterol 100 mg bid | 2 weeks | Digoxin | I: none specified E: recent MI, active meds, COPD, Ren, Hep | 38 | 75 | 75 | 58 | 50 | 59
Lundstrom, Am Heart J, 1992 | 21 crossover, 4 way | Xamoterol 200 mg bid | 2 weeks | Digoxin | I: none specified E: recent MI, active meds, COPD, Ren, Hep | 38 | 75 | 75 | 58 | 50 | 59
Lundstrom, Am Heart J, 1992 | 21 crossover, 4 way | Verapamil 240 mg qd | 2 weeks | Digoxin | I: none specified E: recent MI, active meds, COPD, Ren, Hep | 38 | 75 | 75 | 58 | 50 | 59
Lundstrom, Am Heart J, 1992 | 21 crossover, 4 way | Placebo | 2 weeks | Digoxin | I: none specified E: recent MI, active meds, COPD, Ren, Hep | 38 | 75 | 75 | 58 | 50 | 59
Lewis, J Cardiovasc Pharmacol, 1989 | 15 crossover, 4 way | Atenolol 50 mg bid | 4 weeks | Digoxin, coumadin | I: >1 year E: CHF, angina, DM, COPD, SSS | 38 | 75 | 88 | 50 | 50 | 60
Lewis, J Cardiovasc Pharmacol, 1989 | 15 crossover, 4 way | Verapamil 80 mg bid | 4 weeks | Digoxin, coumadin | I: >1 year E: CHF, angina, DM, COPD, SSS | 38 | 75 | 88 | 50 | 50 | 60
Lewis, J Cardiovasc Pharmacol, 1989 | 15 crossover, 4 way | Xamoterol 200 mg bid | 4 weeks | Digoxin, coumadin | I: >1 year E: CHF, angina, DM, COPD, SSS | 38 | 75 | 88 | 50 | 50 | 60
Lewis, J Cardiovasc Pharmacol, 1989 | 15 crossover, 4 way | Placebo | 4 weeks | Digoxin, coumadin | I: >1 year E: CHF, angina, DM, COPD, SSS | 38 | 75 | 88 | 50 | 50 | 60
Panidis, Am J Cardiol, 1983 | 27 crossover, 2 way | Verapamil, dose titrated tid-qid | 2 weeks | Digoxin | I: none specified E: HTN, angina, DM, Ren, Hep | 50 | 75 | 50 | 67 | 17 | 52
Panidis, Am J Cardiol, 1983 | 27 crossover, 2 way | Placebo | 2 weeks | Digoxin | I: none specified E: HTN, angina, DM, Ren, Hep | 50 | 75 | 50 | 67 | 17 | 52

1 Table excludes studies of postoperative atrial fibrillation; boldface type highlights the relevant comparisons

2 Rep. = representativeness; bias = bias and confounding; Tx = description of therapy; outcomes = outcomes assessment; stats = statistical analysis

3 Ren = renal dysfunction; Hep = hepatic dysfunction; COPD = chronic obstructive pulmonary disease; MI = myocardial infarction; CHF III or IV refers to NYHA class; SSS = sick sinus syndrome; active meds = use of antiarrhythmic therapies; PAF = paroxysmal atrial fibrillation; MAT = multifocal atrial arrhythmia; AV = atrioventricular; abn. = abnormalities

Evidence table 6B. Design of Placebo-Controlled Trials of Beta-Blockers for Rate Control in Atrial Fibrillation^1^

Author, Journal, Year | Total No. of Subjects and Study Design | Treatment Groups | | | | Study Quality ^2^
| | Regimen | Followup | Other Permitted Therapies | Inclusion/Exclusion Criteria ^3^ | Rep. | Bias | Tx | Outcomes | Stats. | Overall
Lewis, J Cardiovasc Pharmacol, 1989 | 15 crossover, 4 way | Atenolol 50 mg bid | 4 weeks | Digoxin, coumadin | I: >1 year E: CHF, angina, DM, COPD, SSS | 38 | 75 | 88 | 50 | 50 | 60
Lewis, J Cardiovasc Pharmacol, 1989 | 15 crossover, 4 way | Verapamil 80 mg bid | 4 weeks | Digoxin, coumadin | I: >1 year E: CHF, angina, DM, COPD, SSS | 38 | 75 | 88 | 50 | 50 | 60
Lewis, J Cardiovasc Pharmacol, 1989 | 15 crossover, 4 way | Xamoterol 200 mg bid | 4 weeks | Digoxin, coumadin | I: >1 year E: CHF, angina, DM, COPD, SSS | 38 | 75 | 88 | 50 | 50 | 60
Lewis, J Cardiovasc Pharmacol, 1989 | 15 crossover, 4 way | Placebo | 4 weeks | Digoxin, coumadin | I: >1 year E: CHF, angina, DM, COPD, SSS | 38 | 75 | 88 | 50 | 50 | 60
Lundstrom, Am Heart J, 1992 | 21 crossover, 4 way | Xamoterol 100 mg bid | 2 weeks | Digoxin | I: none specified E: recent MI, active meds, COPD, Ren, Hep | 38 | 75 | 75 | 58 | 50 | 59
Lundstrom, Am Heart J, 1992 | 21 crossover, 4 way | Xamoterol 200 mg bid | 2 weeks | Digoxin | I: none specified E: recent MI, active meds, COPD, Ren, Hep | 38 | 75 | 75 | 58 | 50 | 59
Lundstrom, Am Heart J, 1992 | 21 crossover, 4 way | Verapamil 240 mg qd | 2 weeks | Digoxin | I: none specified E: recent MI, active meds, COPD, Ren, Hep | 38 | 75 | 75 | 58 | 50 | 59
Lundstrom, Am Heart J, 1992 | 21 crossover, 4 way | Placebo | 2 weeks | Digoxin | I: none specified E: recent MI, active meds, COPD, Ren, Hep | 38 | 75 | 75 | 58 | 50 | 59
Ang, Br Heart J, 1990 | 13 crossover, 3 way | Xamoterol 200 mg bid | 2 weeks | | I: "rapid rate" E: none specified | 38 | 42 | 50 | 90 | 75 | 59
Ang, Br Heart J, 1990 | 13 crossover, 3 way | Digoxin, qd adjusted for serum concentration | 2 weeks | | I: "rapid rate" E: none specified | 38 | 42 | 50 | 90 | 75 | 59
Ang, Br Heart J, 1990 | 13 crossover, 3 way | Placebo | 2 weeks | | I: "rapid rate" E: none specified | 38 | 42 | 50 | 90 | 75 | 59
Sweany, Clin Pharmacol Ther, 1985 | 82 two arms | Timolol 1.0 mg IV bolus, q 20 min x2 if needed | Hours | | I: 18-73 years E: active meds | 63 | 92 | 50 | 75 | 17 | 59
Sweany, Clin Pharmacol Ther, 1985 | 82 two arms | Placebo | Hours | | I: 18-73 years E: active meds | 63 | 92 | 50 | 75 | 17 | 59
DiBianco, Am Heart J, 1984 | 17 crossover, 2 way | Nadolol, dose titrated, qd | 4 weeks | Digoxin | I: none specified E: PAF, HTN, recent MI, angina, CHF, DM, COPD, Ren | 63 | 67 | 50 | 58 | 67 | 61
DiBianco, Am Heart J, 1984 | 17 crossover, 2 way | Placebo | 4 weeks | Digoxin | I: none specified E: PAF, HTN, recent MI, angina, CHF, DM, COPD, Ren | 63 | 67 | 50 | 58 | 67 | 61
Myers, J Appl Physiol, 1987 | 9 crossover, 2 way | Celiprolol | 1 week | Digoxin | I: > 6 months E: none specified | 25 | 75 | 38 | 58 | 50 | 49
Myers, J Appl Physiol, 1987 | 9 crossover, 2 way | Placebo | 1 week | Digoxin | I: > 6 months E: none specified | 25 | 75 | 38 | 58 | 50 | 49
Lin, J Cardiovasc Pharmacol, 1986 | 21 crossover, 2 way | Celiprolol max. tolerated dose, qd 4 | 1 week | Digoxin | I: rate > 120 bpm E: none specified | 13 | 75 | 50 | 75 | 67 | 56
Lin, J Cardiovasc Pharmacol, 1986 | 21 crossover, 2 way | Placebo | 1 week | Digoxin | I: rate > 120 bpm E: none specified | 13 | 75 | 50 | 75 | 67 | 56
Channer, Br J Clin Pharmacol, 1994 | 8 crossover, 5 way | Atenolol 50 mg qd | 2 weeks | Digoxin | I: none specified E: none specified | 13 | 67 | 63 | 67 | 83 | 58
Channer, Br J Clin Pharmacol, 1994 | 8 crossover, 5 way | Atenolol 100 mg qd | 2 weeks | Digoxin | I: none specified E: none specified | 13 | 67 | 63 | 67 | 83 | 58
Channer, Br J Clin Pharmacol, 1994 | 8 crossover, 5 way | Pindolol 5 mg bid | 2 weeks | Digoxin | I: none specified E: none specified | 13 | 67 | 63 | 67 | 83 | 58
Channer, Br J Clin Pharmacol, 1994 | 8 crossover, 5 way | Pindolol 15 mg bid | 2 weeks | Digoxin | I: none specified E: none specified | 13 | 67 | 63 | 67 | 83 | 58
Channer, Br J Clin Pharmacol, 1994 | 8 crossover, 5 way | Placebo | 2 weeks | Digoxin | I: none specified E: none specified | 13 | 67 | 63 | 67 | 83 | 58
Wong, Am J Cardiol, 1990 | 11 crossover, 4 way | Labetalol max. tolerated dose 5 | 10-14 days | | I: none specified E: on digoxin | 13 | 75 | 33 | 58 | 33 | 43
Wong, Am J Cardiol, 1990 | 11 crossover, 4 way | Digoxin 0.25 mg qd | 10-14 days | | I: none specified E: on digoxin | 13 | 75 | 33 | 58 | 33 | 43
Wong, Am J Cardiol, 1990 | 11 crossover, 4 way | Digoxin 0.25 mg qd + Labetalol 1/2 of max. tolerated dose | 10-14 days | | I: none specified E: on digoxin | 13 | 75 | 33 | 58 | 33 | 43
Wong, Am J Cardiol, 1990 | 11 crossover, 4 way | Placebo | 10-14 days | | I: none specified E: on digoxin | 13 | 75 | 33 | 58 | 33 | 43

1 Excludes studies of postoperative atrial fibrillation; boldface type highlights the relevant comparisons

2 Rep. = representativeness; bias = bias and confounding; Tx = description of therapy; outcomes = outcomes assessment; stats = statistical analysis; definitions in Methods Section 2.6.3

3 Ren = renal dysfunction; Hep = hepatic dysfunction; COPD = chronic obstructive pulmonary disease; MI = myocardial infarction; CHF III or IV refers to NYHA class; SSS = sick sinus syndrome; active meds = use of antiarrhythmic therapies; PAF = paroxysmal atrial fibrillation; MAT = multifocal atrial arrhythmia; AV = atrioventricular; abn. = abnormalities

4 Dose between 200 mg and 600 mg/day

5 Maximum tolerated dose was either 200 mg bid or 400 mg bid

Evidence table 6C. Design of Placebo-Controlled Trials of Beta-Blockers for Rate Control in Atrial Fibrillation^1^

Author, Journal, Year | Total No. of Subjects and Study Design | Treatment Groups | | | | Study Quality ^2^
| | Regimen | Followup | Other Permitted Therapies | Inclusion/Exclusion Criteria ^3^ | Rep. | Bias | Tx | Outcomes | Stats. | Overall
Roth, Ann Intern Med, 1992 | 18 2 arms | Clonidine 0.075 mg x1 may repeat x1 in 2 hrs | 4 hours | | I: emergency room E: severe HTN, electrolyte abn., active meds, valve disease, COPD | 75 | 33 | 100 | 80 | 67 | 71
Roth, Ann Intern Med, 1992 | 18 2 arms | Placebo | 4 hours | | I: emergency room E: severe HTN, electrolyte abn., active meds, valve disease, COPD | 75 | 33 | 100 | 80 | 67 | 71
Scardi, Lancet, 1993 | 17 crossover, 2 way | Clonidine 0.075 mg bid | 3 days | | I: rapid rate, on E: recent MI, CHF | 25 | 67 | 63 | 75 | 33 | 53
Scardi, Lancet, 1993 | 17 crossover, 2 way | Placebo | 3 days | | I: rapid rate, on E: recent MI, CHF | 25 | 67 | 63 | 75 | 33 | 53
Botto, Int J Cardiol, 1997 | 105 3 arms | Propafenone 450 mg p.o. | 24 hours | | I: <72 hrs, age<80 E: recent MI, angina, CHF II,III,IV, active meds, on , SSS, AV block, rate<80 bpm | 63 | 67 | 100 | 90 | 83 | 81
Botto, Int J Cardiol, 1997 | 105 3 arms | Propafenone 600 mg p.o. | 24 hours | | I: <72 hrs, age<80 E: recent MI, angina, CHF II,III,IV, active meds, on , SSS, AV block, rate<80 bpm | 63 | 67 | 100 | 90 | 83 | 81
Botto, Int J Cardiol, 1997 | 105 3 arms | Placebo | 24 hours | | I: <72 hrs, age<80 E: recent MI, angina, CHF II,III,IV, active meds, on , SSS, AV block, rate<80 bpm | 63 | 67 | 100 | 90 | 83 | 81
Wong, Am J Cardiol, 1990 | 11 crossover, 4 way | Labetalol max. tolerated dose ^4^ | 10-14 days | | I: none specified E: on | 13 | 75 | 33 | 58 | 33 | 43
Wong, Am J Cardiol, 1990 | 11 crossover, 4 way | 0.25 mg qd | 10-14 days | | I: none specified E: on | 13 | 75 | 33 | 58 | 33 | 43
Wong, Am J Cardiol, 1990 | 11 crossover, 4 way | 0.25 mg qd + Labetalol 1/2 of max. tolerated dose | 10-14 days | | I: none specified E: on | 13 | 75 | 33 | 58 | 33 | 43
Wong, Am J Cardiol, 1990 | 11 crossover, 4 way | Placebo | 10-14 days | | I: none specified E: on | 13 | 75 | 33 | 58 | 33 | 43
Lewis, Irvine et al., Eur Heart J, 1988 | 6 crossover, 6 way | .25 mg x 1 | Hours | | I: NYHA Class I E: none specified | 13 | 63 | 63 | 67 | 50 | 51
Lewis, Irvine et al., Eur Heart J, 1988 | 6 crossover, 6 way | Diltiazem 60 mg x 1 | Hours | | I: NYHA Class I E: none specified | 13 | 63 | 63 | 67 | 50 | 51
Lewis, Irvine et al., Eur Heart J, 1988 | 6 crossover, 6 way | Diltiazem 120 mg x 1 | Hours | | I: NYHA Class I E: none specified | 13 | 63 | 63 | 67 | 50 | 51
Lewis, Irvine et al., Eur Heart J, 1988 | 6 crossover, 6 way | .25 mg x 1 Diltiazem 120 mg x 1 | Hours | | I: NYHA Class I E: none specified | 13 | 63 | 63 | 67 | 50 | 51
Lewis, Irvine et al., Eur Heart J, 1988 | 6 crossover, 6 way | Verapamil 80 mg x 1 | Hours | | I: NYHA Class I E: none specified | 13 | 63 | 63 | 67 | 50 | 51
Lewis, Irvine et al., Eur Heart J, 1988 | 6 crossover, 6 way | Placebo | Hours | | I: NYHA Class I E: none specified | 13 | 63 | 63 | 67 | 50 | 51
Lok, Chest, 1997 | 40 2 arms | Sotalol 80-160mg bid | 8 weeks | | I: none specified E: CHF III or IV, COPD, valve disease | 13 | 75 | 33 | 75 | 50 | 49
Lok, Chest, 1997 | 40 2 arms | Placebo | 8 weeks | | I: none specified E: CHF III or IV, COPD, valve disease | 13 | 75 | 33 | 75 | 50 | 49
Ang, Br Heart J, 1990 | 13 crossover, 3 way | Xameterol 200 mg bid | 2 weeks | | I: "rapid rate" E: none specified | 13 | 75 | 33 | 75 | 50 | 49
Ang, Br Heart J, 1990 | 13 crossover, 3 way | qd adjusted for serum concentration | 2 weeks | | I: "rapid rate" E: none specified | 13 | 75 | 33 | 75 | 50 | 49
Ang, Br Heart J, 1990 | 13 crossover, 3 way | Placebo | 2 weeks | | I: "rapid rate" E: none specified | 13 | 75 | 33 | 75 | 50 | 49
Koh, Int J Cardiol, 1995 | 35 crossover, 3 way | 0.125-0.5 mg qd and Diltiazem 90 mg bid | 4 weeks | | I: > one month E: active meds, CHF, bradycardia, COPD, MI, hypotension, diabetes | 0 | 67 | 50 | 67 | 63 | 71
Koh, Int J Cardiol, 1995 | 35 crossover, 3 way | 0.12-0.5 mg qd and Betaxolol 20 mg qd | 4 weeks | | I: > one month E: active meds, CHF, bradycardia, COPD, MI, hypotension, diabetes | 0 | 67 | 50 | 67 | 63 | 71
Koh, Int J Cardiol, 1995 | 35 crossover, 3 way | Placebo | 4 weeks | | I: > one month E: active meds, CHF, bradycardia, COPD, MI, hypotension, diabetes | 0 | 67 | 50 | 67 | 63 | 71
Koh, Am J Cardiol, 1995 | 45 4 arms | 0.125-0.50 mg qd | 4 weeks | | I: > one month E: CHF, bradycardia, hypotension, COPD, diabetes | 50 | 50 | 33 | 58 | 100 | 58
Koh, Am J Cardiol, 1995 | 45 4 arms | as above and Diltiazem 90 mg bid | 4 weeks | | I: > one month E: CHF, bradycardia, hypotension, COPD, diabetes | 50 | 50 | 33 | 58 | 100 | 58
Koh, Am J Cardiol, 1995 | 45 4 arms | as above and Betaxolol 20 mg qd | 4 weeks | | I: > one month E: CHF, bradycardia, hypotension, COPD, diabetes | 50 | 50 | 33 | 58 | 100 | 58
Koh, Am J Cardiol, 1995 | 45 4 arms | Placebo | 4 weeks | | I: > one month E: CHF, bradycardia, hypotension, COPD, diabetes | 50 | 50 | 33 | 58 | 100 | 58
Falk, Ann Intern Med,1987 | 36 2 arms | 0.6 mg x 1 | 15 min | | I: < 7days E: CHF, active meds, ren, angina, hypoxemia | 88 | 58 | 100 | 80 | 100 | 85
Falk, Ann Intern Med,1987 | 36 2 arms | Placebo | 15 min | | I: < 7days E: CHF, active meds, ren, angina, hypoxemia | 88 | 58 | 100 | 80 | 100 | 85
The Digitalis in Acute Atrial Fibrillation (DAAF) Trial Group, Eur Heart J, 1997 | 239 2 arms | 0.25-0.5 mg IV x3 q6hrs, then 0.015 -0.020 mg/kg IV | 16 hours | Verapamil (1 subject in group and 6 in placebo group) | I: < 7days, adults E: MI, angina, SSS, ren, active meds, AV block | 100 | 92 | 83 | 90 | 100 | 93
The Digitalis in Acute Atrial Fibrillation (DAAF) Trial Group, Eur Heart J, 1997 | 239 2 arms | Placebo | 16 hours | Verapamil (1 subject in group and 6 in placebo group) | I: < 7days, adults E: MI, angina, SSS, ren, active meds, AV block | 100 | 92 | 83 | 90 | 100 | 93
Jordaens, Eur Heart J, 1997 | 39 2 arms | | 30 minutes | Verapamil (1 subject in each group) | I: < 7days, HR >100 bpm E: on , active meds, MI, COPD, electrolyte abn. | 38 | 58 | 83 | 90 | 25 | 59
Jordaens, Eur Heart J, 1997 | 39 2 arms | Placebo | 30 minutes | Verapamil (1 subject in each group) | I: < 7days, HR >100 bpm E: on , active meds, MI, COPD, electrolyte abn. | 38 | 58 | 83 | 90 | 25 | 59
Brodsky, Am J Cardiol, 1994 | 18 2 arms | Magnesium sulfate 2g IV x1 then 8g over 6 hrs | 6 hours | | I: < 7days, CHF, rapid rate E: active meds, ren, hep, hypotension | 25 | 75 | 67 | 75 | 83 | 65
Brodsky, Am J Cardiol, 1994 | 18 2 arms | Placebo | 6 hours | | I: < 7days, CHF, rapid rate E: active meds, ren, hep, hypotension | 25 | 75 | 67 | 75 | 83 | 65

1 Excludes studies of postoperative atrial fibrillation; boldface type highlights the relevant comparisons

2 Rep. = representativeness; bias = bias and confounding; Tx = description of therapy; outcomes = outcomes assessment; stats = statistical analysis

3 Ren = renal dysfunction; Hep = hepatic dysfunction; COPD = chronic obstructive pulmonary disease; MI = myocardial infarction; CHF III or IV refers to NYHA class; SSS = sick sinus syndrome; active meds = use of antiarrhythmic therapies; PAF = paroxysmal atrial fibrillation; MAT = multifocal atrial arrhythmia; AV = atrioventricular; abn. = abnormalities

4 Maximum tolerated dose was either 200 mg bid or 400 mg bid

Evidence table 6D. Design of Trials of Comparing Calcium-Channel-Blockers to Digoxin for Rate Control in Atrial Fibrillation^1^

Author, Journal, Year | Total No. of Subjects and Study Design | Treatment Groups | | | | Study Quality ^2^
| | Regimen | Followup | Other Permitted Therapies | Inclusion/Exclusion Criteria ^3^ | Rep. | Bias | Tx | Outcomes | Stats. | Overall
Schreck Ann Emerg Med, 1997 | 30 3 arms | Diltiazem 0.25 mg/kg IV then 0.35 mg/kg and infusion 10-20 mg/hr | 3 hours | | none;I: new onset E: recent MI, CHF III or IV, spb<100, active meds, SSS, WPW | 75 | 17 | 50 | 90 | 50 | 56
Schreck Ann Emerg Med, 1997 | 30 3 arms | Diltiazem as above | 3 hours | | none;I: new onset E: recent MI, CHF III or IV, spb<100, active meds, SSS, WPW | 75 | 17 | 50 | 90 | 50 | 56
Schreck Ann Emerg Med, 1997 | 30 3 arms | Digoxin as below | 3 hours | | none;I: new onset E: recent MI, CHF III or IV, spb<100, active meds, SSS, WPW | 75 | 17 | 50 | 90 | 50 | 56
Schreck Ann Emerg Med, 1997 | 30 3 arms | Digoxin 0.25 mg IV repeat at 30 min x 1 | 3 hours | | none;I: new onset E: recent MI, CHF III or IV, spb<100, active meds, SSS, WPW | 75 | 17 | 50 | 90 | 50 | 56
Lewis, Laing et al., Eur Heart J, 1988 | 14 crossover, 3 way | Diltiazem 60 mg tid then 120 mg tid | 4 weeks | | none;I: > 1 year E: none specified | 38 | 75 | 50 | 50 | 100 | 63
Lewis, Laing et al., Eur Heart J, 1988 | 14 crossover, 3 way | Digoxin as below and Diltiazem 60 mg tid | 4 weeks | | none;I: > 1 year E: none specified | 38 | 75 | 50 | 50 | 100 | 63
Lewis, Laing et al., Eur Heart J, 1988 | 14 crossover, 3 way | Digoxin qd for serum level 1.3-2.6 nmol/l | 4 weeks | | none;I: > 1 year E: none specified | 38 | 75 | 50 | 50 | 100 | 63
Lewis, Irvine et al., Eur Heart J, 1988 | 6 crossover, 6 way | Digoxin .25 mg x 1 | hours | | I: NYHA Class I E: none specified | 13 | 63 | 63 | 67 | 50 | 51
Lewis, Irvine et al., Eur Heart J, 1988 | 6 crossover, 6 way | Diltiazem 60 mg x 1 | hours | | I: NYHA Class I E: none specified | 13 | 63 | 63 | 67 | 50 | 51
Lewis, Irvine et al., Eur Heart J, 1988 | 6 crossover, 6 way | Diltiazem 120 mg x 1 | hours | | I: NYHA Class I E: none specified | 13 | 63 | 63 | 67 | 50 | 51
Lewis, Irvine et al., Eur Heart J, 1988 | 6 crossover, 6 way | Digoxin 0.25 mg x 1 | hours | | I: NYHA Class I E: none specified | 13 | 63 | 63 | 67 | 50 | 51
Lewis, Irvine et al., Eur Heart J, 1988 | 6 crossover, 6 way | Diltiazem 120 mg x 1 | hours | | I: NYHA Class I E: none specified | 13 | 63 | 63 | 67 | 50 | 51
Lewis, Irvine et al., Eur Heart J, 1988 | 6 crossover, 6 way | Verapamil 80 mg x 1 | hours | | I: NYHA Class I E: none specified | 13 | 63 | 63 | 67 | 50 | 51
Lewis, Irvine et al., Eur Heart J, 1988 | 6 crossover, 6 way | Placebo | hours | | I: NYHA Class I E: none specified | 13 | 63 | 63 | 67 | 50 | 51
Pomfret, Clin Sci, 1988 | 8 crossover, 4 way | Digoxin 0.25 mg qd and Verapamil 40 mg tid | 2 weeks | | I: > 6 months, on Digoxin E: CHF, active meds | 38 | 75 | 88 | 67 | 67 | 67
Pomfret, Clin Sci, 1988 | 8 crossover, 4 way | Verapamil 40 mg tid | 2 weeks | | I: > 6 months, on Digoxin E: CHF, active meds | 38 | 75 | 88 | 67 | 67 | 67
Pomfret, Clin Sci, 1988 | 8 crossover, 4 way | Verapamil 80 mg tid | 2 weeks | | I: > 6 months, on Digoxin E: CHF, active meds | 38 | 75 | 88 | 67 | 67 | 67
Pomfret, Clin Sci, 1988 | 8 crossover, 4 way | Digoxin 0.25-0.50 mg qd | 2 weeks | | I: > 6 months, on Digoxin E: CHF, active meds | 38 | 75 | 88 | 67 | 67 | 67
Ahuja, Int J Cardiol, 1989 | 10 crossover, 3 way | Metoprolol 50-100 mg bid | 4 weeks | | none;I: none specified E: none specified | 0 | 50 | 33 | 33 | 38 | 31
Ahuja, Int J Cardiol, 1989 | 10 crossover, 3 way | Verapamil 40-80 mg tid | 4 weeks | | none;I: none specified E: none specified | 0 | 50 | 33 | 33 | 38 | 31
Ahuja, Int J Cardiol, 1989 | 10 crossover, 3 way | Digoxin 0.25 mg qd | 4 weeks | | none;I: none specified E: none specified | 0 | 50 | 33 | 33 | 38 | 31

1 Excludes studies of postoperative atrial fibrillation; boldface type highlights the relevant comparisons

2 Rep. = representativeness; bias = bias and confounding; Tx = description of therapy; outcomes = outcomes assessment; stats = statistical analysis

3 Ren = renal dysfunction; Hep = hepatic dysfunction; COPD = chronic obstructive pulmonary disease; MI = myocardial infarction; CHF III or IV refers to NYHA class; SSS = sick sinus syndrome; active meds = use of antiarrhythmic therapies; PAF = paroxysmal atrial fibrillation; MAT = multifocal atrial arrhythmia; AV = atrioventricular; abn. = abnormalities

Evidence table 6E. Design of Trials of Comparing Beta-Blockers to Digoxin for Rate Control in Atrial Fibrillation^1^

Author, Journal, Year | Total No. of Subjects and Study Design | Treatment Groups | | | | Study Quality ^2^
| | Regimen | Followup | Other Permitted Therapies | Inclusion/Exclusion Criteria ^3^ | Rep. | Bias | Tx | Outcomes | Stats. | Overall
Lawson-Matthew, Age/Ageing, 1995 | 25 crossover, 3 way | Xamoterol 200 mg bid/ Digoxin 0.125-0.5mg qd | | Coumadin, furosemide | I: on Digoxin E: CHF III or IV | 25 | 75 | 38 | 67 | 75 | 56
Lawson-Matthew, Age/Ageing, 1995 | 25 crossover, 3 way | Xamoterol 200 mg bid | | Coumadin, furosemide | I: on Digoxin E: CHF III or IV | 25 | 75 | 38 | 67 | 75 | 56
Lawson-Matthew, Age/Ageing, 1995 | 25 crossover, 3 way | Digoxin 0.125-0.50 mg qd | | Coumadin, furosemide | I: on Digoxin E: CHF III or IV | 25 | 75 | 38 | 67 | 75 | 56
Ang, Br Heart J, 1990 | 13 crossover, 3 way | Xamoterol 200 mg bid | 2 weeks | | I: rapid rate: none specified | 13 | 75 | 33 | 75 | 50 | 49
Ang, Br Heart J, 1990 | 13 crossover, 3 way | Digoxin, qd adjusted for serum concentration | 2 weeks | | I: rapid rate: none specified | 13 | 75 | 33 | 75 | 50 | 49
Ang, Br Heart J, 1990 | 13 crossover, 3 way | Placebo | 2 weeks | | I: rapid rate: none specified | 13 | 75 | 33 | 75 | 50 | 49
Ahuja, Int J Cardiol, 1989 | 10 crossover, 3 way | Metoprolol 50-100 mg bid | 4 weeks | | I: none specified E: none specified | 0 | 50 | 33 | 33 | 38 | 31
Ahuja, Int J Cardiol, 1989 | 10 crossover, 3 way | Verapamil 40-80 mg tid | 4 weeks | | I: none specified E: none specified | 0 | 50 | 33 | 33 | 38 | 31
Ahuja, Int J Cardiol, 1989 | 10 crossover, 3 way | Digoxin 0.25 mg qd | 4 weeks | | I: none specified E: none specified | 0 | 50 | 33 | 33 | 38 | 31
Wong, Am J Cardiol, 1990 | 11 crossover, 4 way | Labetalol max. tolerated dose ^4^ | 10-14 days | | I: none specified E: on Digoxin | 13 | 75 | 33 | 58 | 33 | 43
Wong, Am J Cardiol, 1990 | 11 crossover, 4 way | Digoxin 0.25 mg qd | 10-14 days | | I: none specified E: on Digoxin | 13 | 75 | 33 | 58 | 33 | 43
Wong, Am J Cardiol, 1990 | 11 crossover, 4 way | Digoxin 0.25 mg qd + Labetalol 1/2 of max. tolerated dose | 10-14 days | | I: none specified E: on Digoxin | 13 | 75 | 33 | 58 | 33 | 43
Wong, Am J Cardiol, 1990 | 11 crossover, 4 way | Placebo | 10-14 days | | I: none specified E: on Digoxin | 13 | 75 | 33 | 58 | 33 | 43

1 Excludes studies of postoperative atrial fibrillation; boldface type highlights the relevant comparisons

2 Rep. = representativeness; bias = bias and confounding; Tx = description of therapy; outcomes = outcomes assessment; stats = statistical analysis

3 Ren = renal dysfunction; Hep = hepatic dysfunction; COPD = chronic obstructive pulmonary disease; MI = myocardial infarction; CHF III or IV refers to NYHA class; SSS = sick sinus syndrome; active meds = use of antiarrhythmic therapies; PAF = paroxysmal atrial fibrillation; MAT = multifocal atrial arrhythmia; AV = atrioventricular; abn. = abnormalities

4 Maximum tolerated dose was either 200 mg bid or 400 mig bid

Evidence table 6F. Design of Digoxin-Controlled Trials of other Drugs or Combinations for Rate Control in Atrial Fibrillation^1^

Author, Journal, Year | Total No. of Subjects and Study Design | Treatment Groups | | | | Study Quality ^2^
| | Regimen | Followup | Other Permitted Therapies | Inclusion/Exclusion Criteria ^3^ | Rep. | Bias | Tx | Outcomes | Stats. | Overall
Brodsky, Am Heart J, 1994 | 60 3 arms | DL-sotalol 40 mg bid and Digoxin < 0.375 mg/d | 4 weeks | | I: >18 years, > 2 weeks E: Ren, Hep, COPD | 38 | 75 | 33 | 75 | 88 | 62
Brodsky, Am Heart J, 1994 | 60 3 arms | DL-sotalol 80 mg bid and Digoxin < 0.375 mg/d | 4 weeks | | I: >18 years, > 2 weeks E: Ren, Hep, COPD | 38 | 75 | 33 | 75 | 88 | 62
Brodsky, Am Heart J, 1994 | 60 3 arms | Digoxin <0.375 mg/d | 4 weeks | | I: >18 years, > 2 weeks E: Ren, Hep, COPD | 38 | 75 | 33 | 75 | 88 | 62
Channer, Eur Heart J, 1987 | 14 crossover, 3 way | Digoxin 2x maintenance dose up to 0.50 mg qd | 4 weeks | | I: palpitations or dyspnea with effort E: none specified | 13 | 67 | 50 | 83 | 67 | 56
Channer, Eur Heart J, 1987 | 14 crossover, 3 way | Digoxin at maintenance dose and Verapamil 120mg divided | 4 weeks | | I: palpitations or dyspnea with effort E: none specified | 13 | 67 | 50 | 83 | 67 | 56
Channer, Eur Heart J, 1987 | 14 crossover, 3 way | Digoxin at maintenance dose qd | 4 weeks | | I: palpitations or dyspnea with effort E: none specified | 13 | 67 | 50 | 83 | 67 | 56
Smit, Eur J Clin Pharmacol, 1989 | 11 2 arms | Digoxin 1.5 mg IV over 6hrs | 24 hours | | I: rate>120 bpm E: electrolyte abn., recent MI | 25 | 75 | 100 | 90 | 75 | 73
Smit, Eur J Clin Pharmacol, 1989 | 11 2 arms | Digoxin 0.5 mg IV bolus q8hrs x3 | 24 hours | | I: rate>120 bpm E: electrolyte abn., recent MI | 25 | 75 | 100 | 90 | 75 | 73
Zoble, Am J Cardiol, 1987 | 26 two arms | Digoxin 0.25 mg qd + Nadolol 67.7 mg qd | 6 weeks | | I: on Digoxin E: DM, COPD, CHF, recent MI, SSS, active meds, Ren, Hep | 25 | 42 | 52 | 75 | 17 | 42
Zoble, Am J Cardiol, 1987 | 26 two arms | Digoxin 0.25 mg qd | 6 weeks | | I: on Digoxin E: DM, COPD, CHF, recent MI, SSS, active meds, Ren, Hep | 25 | 42 | 52 | 75 | 17 | 42
Stern, Chest, 1982 | 9 crossover, 2 way | Verapamil 80 mg q8hrs or q6hrs or 120 mg q6hrs + Digoxin at pretrial dose | 14 days | | I: > 6 months, on Digoxin E: CHF, active meds | 50 | 75 | 67 | 75 | 67 | 67
Stern, Chest, 1982 | 9 crossover, 2 way | Digoxin at pretrial dose | 14 days | | I: > 6 months, on Digoxin E: CHF, active meds | 50 | 75 | 67 | 75 | 67 | 67
Lang, Am Heart J, 1983 | 20 crossover, 2 way | Verapamil, dose titrated qd ^4^ and Digoxin dosed as pretrial | 2 weeks | | I: > 1 year, on Digoxin E: DM, Ren, Hep | 0 | 63 | 75 | 75 | 50 | 53
Lang, Am Heart J, 1983 | 20 crossover, 2 way | Digoxin dosed as pretrial | 2 weeks | | I: > 1 year, on Digoxin E: DM, Ren, Hep | 0 | 63 | 75 | 75 | 50 | 53
Hays, Ann Emerg Med, 1994 | 15 2 arms | Magnesium sulfate 2g bolus then 1g/hr and Digoxin 0.5 mg x1 | 4 hours | | I: adult, rapid rate E: active meds, Ren, K+ abn., AV block | 50 | 75 | 50 | 80 | 75 | 66
Hays, Ann Emerg Med, 1994 | 15 2 arms | Digoxin 0.5 mg x1 | 4 hours | | I: adult, rapid rate E: active meds, Ren, K+ abn., AV block | 50 | 75 | 50 | 80 | 75 | 66
Schreck, Ann Emerg Med, 1997 | 30 3 arms | Diltiazem 0.25 mg/kg IV then 0.35 mg/kg and infusion 10-20 mg/hr | 3 hours | | I: new onset E: recent MI, CHF III or IV, SBP<100, active meds, SSS, WPW | 75 | 17 | 50 | 90 | 50 | 56
Schreck, Ann Emerg Med, 1997 | 30 3 arms | Diltiazem as above Digoxin as below | 3 hours | | I: new onset E: recent MI, CHF III or IV, SBP<100, active meds, SSS, WPW | 75 | 17 | 50 | 90 | 50 | 56
Schreck, Ann Emerg Med, 1997 | 30 3 arms | Digoxin 0.25 mg IV repeat at 30 min 1 | 3 hours | | I: new onset E: recent MI, CHF III or IV, SBP<100, active meds, SSS, WPW | 75 | 17 | 50 | 90 | 50 | 56
Lewis, Irvine et al. Eur Heart J, 1988 | 6 crossover, 6 way | Digoxin .25 mg x 1 | hours | | I: NYHA Class I E: none specified | 13 | 63 | 63 | 67 | 50 | 51
Lewis, Irvine et al. Eur Heart J, 1988 | 6 crossover, 6 way | Diltiazem 60 mg x 1 | hours | | I: NYHA Class I E: none specified | 13 | 63 | 63 | 67 | 50 | 51
Lewis, Irvine et al. Eur Heart J, 1988 | 6 crossover, 6 way | Diltiazem 120 mg x 1 | hours | | I: NYHA Class I E: none specified | 13 | 63 | 63 | 67 | 50 | 51
Lewis, Irvine et al. Eur Heart J, 1988 | 6 crossover, 6 way | Digoxin 0.25 mg x 1 and Diltiazem 120 mg x 1 | hours | | I: NYHA Class I E: none specified | 13 | 63 | 63 | 67 | 50 | 51
Lewis, Irvine et al. Eur Heart J, 1988 | 6 crossover, 6 way | Verapamil 80 mg x 1 | hours | | I: NYHA Class I E: none specified | 13 | 63 | 63 | 67 | 50 | 51
Lewis, Irvine et al. Eur Heart J, 1988 | 6 crossover, 6 way | Placebo | hours | | I: NYHA Class I E: none specified | 13 | 63 | 63 | 67 | 50 | 51
Pomfret, Clin Sci, 1988 | 8 crossover, 4 way | Digoxin 0.25 mg qd and Verapamil 40 mg tid | 2 weeks | | I: > 6 months, on Digoxin E: CHF, active meds | 38 | 75 | 88 | 67 | 67 | 67
Pomfret, Clin Sci, 1988 | 8 crossover, 4 way | Verapamil 40 mg tid | 2 weeks | | I: > 6 months, on Digoxin E: CHF, active meds | 38 | 75 | 88 | 67 | 67 | 67
Pomfret, Clin Sci, 1988 | 8 crossover, 4 way | Verapamil 80 mg tid | 2 weeks | | I: > 6 months, on Digoxin E: CHF, active meds | 38 | 75 | 88 | 67 | 67 | 67
Pomfret, Clin Sci, 1988 | 8 crossover, 4 way | Digoxin 0.25-0.50 mg qd | 2 weeks | | I: > 6 months, on Digoxin E: CHF, active meds | 38 | 75 | 88 | 67 | 67 | 67
Pomfret, Clin Sci, 1988 | 8 crossover, 4 way | Digoxin as below and Diltiazem 60 mg tid | 2 weeks | | I: > 6 months, on Digoxin E: CHF, active meds | 38 | 75 | 88 | 67 | 67 | 67
Pomfret, Clin Sci, 1988 | 8 crossover, 4 way | Digoxin qd for serum level 1.3-2.6 nmol/l | 2 weeks | | I: > 6 months, on Digoxin E: CHF, active meds | 38 | 75 | 88 | 67 | 67 | 67
Lewis, Laing et al., Eu Heart J, 1988 | 14 crossover, 3 way | Diltiazem 60 mg tid then 120 mg tid | 4 weeks | | I: > 1 year E: none specified | 38 | 75 | 50 | 50 | 100 | 63
Lawson-Matthew, Age/Ageing, 1995 | 25 crossover, 3 way | Xamoterol 200 mg bid/ Digoxin 0.125-0.5mg qd | | Coumadin, furosemide | I: on Digoxin E: CHF III or IV | 25 | 75 | 38 | 67 | 75 | 56
Lawson-Matthew, Age/Ageing, 1995 | 25 crossover, 3 way | Xamoterol 200 mg bid | | Coumadin, furosemide | I: on Digoxin E: CHF III or IV | 25 | 75 | 38 | 67 | 75 | 56
Lawson-Matthew, Age/Ageing, 1995 | 25 crossover, 3 way | Digoxin 0.125-0.50 mg qd | | Coumadin, furosemide | I: on Digoxin E: CHF III or IV | 25 | 75 | 38 | 67 | 75 | 56
Wong, Am J Cardiol, 1990 | 11 crossover, 4 way | Labetalol max. tolerated dose ^4^ | 10-14 days | | I: none specified E: on Digoxin | 13 | 75 | 33 | 58 | 33 | 43
Wong, Am J Cardiol, 1990 | 11 crossover, 4 way | Digoxin 0.25 mg qd | 10-14 days | | I: none specified E: on Digoxin | 13 | 75 | 33 | 58 | 33 | 43
Wong, Am J Cardiol, 1990 | 11 crossover, 4 way | Digoxin 0.25 mg qd + Labetalol 1/2 of max. tolerated dose | 10-14 days | | I: none specified E: on Digoxin | 13 | 75 | 33 | 58 | 33 | 43
Wong, Am J Cardiol, 1990 | 11 crossover, 4 way | Placebo | 10-14 days | | I: none specified E: on Digoxin | 13 | 75 | 33 | 58 | 33 | 43
Wong, Am J Cardiol, 1990 | 11 crossover, 4 way | Placebo | 10-14 days | | I: none specified E: on Digoxin | 13 | 75 | 33 | 58 | 33 | 43
Koh, Am J Cardiol, 1995 | 45 4 arms | Digoxin 0.125-0.50 mg qd | 4 weeks | | I: > one month E: CHF, bradycardia, HTN, COPD, diabetes | 50 | 50 | 33 | 58 | 100 | 58
Koh, Am J Cardiol, 1995 | 45 4 arms | Digoxin as above and Diltiazem 90 mg bid | 4 weeks | | I: > one month E: CHF, bradycardia, HTN, COPD, diabetes | 50 | 50 | 33 | 58 | 100 | 58
Koh, Am J Cardiol, 1995 | 45 4 arms | Digoxin as above and Betaxolol 20 mg qd | 4 weeks | | I: > one month E: CHF, bradycardia, HTN, COPD, diabetes | 50 | 50 | 33 | 58 | 100 | 58
Koh, Am J Cardiol, 1995 | 45 4 arms | Placebo | 4 weeks | | I: > one month E: CHF, bradycardia, HTN, COPD, diabetes | 50 | 50 | 33 | 58 | 100 | 58

1 Excludes studies of postoperative atrial fibrillation; boldface type highlights the relevant comparisons

2 Rep. = representativeness; bias = bias and confounding; Tx = description of therapy; outcomes = outcomes assessment; stats = statistical analysis

3 Ren = renal dysfunction; Hep = hepatic dysfunction; COPD = chronic obstructive pulmonary disease; MI = myocardial infarction; CHF III or IV refers to NYHA class; SSS = sick sinus syndrome; active meds = use of antiarrhythmic therapies; PAF = paroxysmal atrial fibrillation; MAT = multifocal atrial arrhythmia; AV = atrioventricular; abn. = abnormalities

Dose between 240 and 320 mg/day

Evidence table 6G. Design of Trials Comparing Other Drugs for Rate Control in Atrial Fibrillation ^1^

Author, Journal, Year | Total No. of Subjects and Study Design | Treatment Groups | | | | Study Quality ^2^
| | Regimen | Followup | Other Permitted Therapies | Inclusion/Exclusion Criteria ^3^ | Rep. | Bias | Tx | Outcomes | Stats. | Overall
Boudonas, Acta Cardiol, 1995 | 16 crossover, 2 way | Diltiazem .25-.35 mg/kg/hr IV | 1 hour | Digoxin | I: hospitalized E: CHF, active meds, Ren. | 25 | 25 | 100 | 90 | 75 | 63
Boudonas, Acta Cardiol, 1995 | 16 crossover, 2 way | Disopyramide 50 mg IV | 1 hour | Digoxin | I: hospitalized E: CHF, active meds, Ren. | 25 | 25 | 100 | 90 | 75 | 63
Suttorp, JACC, 1990 | 50 2 arms | Propafenone 2mg/kg IV | 1 hour | Digoxin,beta-blocker,Ca++ channel blocker | I: < 6months, rate > 100 bpm E: recent MI, CHF, AV block, active meds, SSS, electrolyte abn., WPW | 50 | 67 | 67 | 90 | 75 | 70
Suttorp, JACC, 1990 | 50 2 arms | Flecainide 2 mg/kg IV | 1 hour | Digoxin,beta-blocker,Ca++ channel blocker | I: < 6months, rate > 100 bpm E: recent MI, CHF, AV block, active meds, SSS, electrolyte abn., WPW | 50 | 67 | 67 | 90 | 75 | 70
Kingma, Am J Cardiol, 1992 | 40 50 2 trials | Propafenone 2mg/kg IV for 10 min | 1 hour | Digoxin, calcium-channel-blocker (except Verapamil group), beta blocker | I: <6 months, rate >100bpm E: recent MI, elec-trolyte abn., SSS, heart block | 50 | 67 | 67 | 90 | 97 | 68
Kingma, Am J Cardiol, 1992 | 40 50 2 trials | Flecainide 2mg/kg IV for 10 min | 1 hour | Digoxin, calcium-channel-blocker (except Verapamil group), beta blocker | I: <6 months, rate >100bpm E: recent MI, elec-trolyte abn., SSS, heart block | 50 | 67 | 67 | 90 | 97 | 68
Kingma, Am J Cardiol, 1992 | 40 50 2 trials | Verapamil 10 mg IV bolus in 1 min | 1 hour | Digoxin, calcium-channel-blocker (except Verapamil group), beta blocker | I: <6 months, rate >100bpm E: recent MI, elec-trolyte abn., SSS, heart block | 50 | 67 | 67 | 90 | 97 | 68
Lee, J Intern Med, 1996 | 96 2 arms | Propafenone 150-300 mg q6hrs | 3 months | | I: >15 years, PAF, symptomatic E: bradycardia, AV block, CHF IV, ren, hep, electrolyte abn, COPD | 63 | 75 | 50 | 75 | 100 | 73
Lee, J Intern Med, 1996 | 96 2 arms | Quinidine 200-400 mg q6hrs | 3 months | | I: >15 years, PAF, symptomatic E: bradycardia, AV block, CHF IV, ren, hep, electrolyte abn, COPD | 63 | 75 | 50 | 75 | 100 | 73
Dahlstrom, Clin Cardiol, 1992 | 13 crossover, 3 way | Diltiazem 60 mg tid + Digoxin | 4 weeks | | I: 30-75, > 6 months, on Digoxin E: HTN, CHF III or IV DM, COPD, Ren, Hep | 50 | 75 | 75 | 67 | 88 | 71
Dahlstrom, Clin Cardiol, 1992 | 13 crossover, 3 way | Propranolol 20 mg tid + Digoxin | 4 weeks | | I: 30-75, > 6 months, on Digoxin E: HTN, CHF III or IV DM, COPD, Ren, Hep | 50 | 75 | 75 | 67 | 88 | 71
Dahlstrom, Clin Cardiol, 1992 | 13 crossover, 3 way | Diltiazem 60 mg tid + Propranolol 20 mg tid + Digoxin | 4 weeks | | I: 30-75, > 6 months, on Digoxin E: HTN, CHF III or IV DM, COPD, Ren, Hep | 50 | 75 | 75 | 67 | 88 | 71
Joshi, J Assoc Physicians India, 1995 | 86 2 arms | Magnesium sulfate 2gm, IV repeated x1 if needed after 15 minutes | hours | | I: none specified E: Ren, SBP<90 | 38 | 67 | 33 | 50 | 50 | 48
Joshi, J Assoc Physicians India, 1995 | 86 2 arms | Verapamil 5 mg IV repeated x1 if needed after 15 minutes | hours | | I: none specified E: Ren, SBP<90 | 38 | 67 | 33 | 50 | 50 | 48
Gullestad, Cardiology, 1993 | 57 2 arms | Magnesium sulfate 5mmol, IV bolus, repeat x1 if needed, then .04 mmol/ min maintenance | 24 hours | | I: well-defined symptoms E: recent MI, CHF III or IV, active meds, SSS, electrolyte abnormalities | 50 | 33 | 50 | 80 | 63 | 55
Gullestad, Cardiology, 1993 | 57 2 arms | Verapamil 5 mg IV bolus, repeat x1 if needed then .01 mg/min maintenance | 24 hours | | I: well-defined symptoms E: recent MI, CHF III or IV, active meds, SSS, electrolyte abnormalities | 50 | 33 | 50 | 80 | 63 | 55
James, Eur Heart J, 1989 | 12 crossover, 2 way | Pindolol 15 mg bid and Digoxin 0.125-0.50 mg qd | 1 month | | I: symptomatic E: none specified | 13 | 67 | 25 | 67 | 67 | 48
James, Eur Heart J, 1989 | 12 crossover, 2 way | Verapamil 40 mg tid and Digoxin 0.125-0.50 mg qd | 1 month | | I: symptomatic E: none specified | 13 | 67 | 25 | 67 | 67 | 48
Zehender, JACC, 1992 | 40 2 arms | Quinidine 160 mg tid Verapamil 80 mg tid Digoxin to a serum level | 3 months | | I: > 4 weeks, < 2 years E: CHF IV, LA thrombus, failure of these study drugs in past | 63 | 50 | 75 | 83 | 83 | 71
Zehender, JACC, 1992 | 40 2 arms | Amiodarone 200 mg qd | 3 months | | I: > 4 weeks, < 2 years E: CHF IV, LA thrombus, failure of these study drugs in past | 63 | 50 | 75 | 83 | 83 | 71

1 Excludes studies of postoperative atrial fibrillation; boldface type highlights the relevant comparisons

2 Rep. = representativeness; bias = bias and confounding; Tx = description of therapy; outcomes = outcomes assessment; stats = statistical analysis

3 Ren = renal dysfunction; Hep = hepatic dysfunction; COPD = chronic obstructive pulmonary disease; MI = myocardial infarction; CHF III or IV refers to NYHA class; SSS = sick sinus syndrome; active meds = use of antiarrhythmic therapies; PAF = paroxysmal atrial fibrillation; MAT = multifocal atrial arrhythmia; AV = atrioventricular; abn. = abnormalities

Evidence table 7A. Reuslts of Placebo-Controlled Trials of Calcium-Channel-Blockers for Rate Control in Atrial Fibrillation ^1^

Author, Journal, Year | Treatment Groups | N | Mean HR on Drug (bpm) | Statistical Significance ^2^ | Mean Maximum Heart Rate with Exercise (bpm) | Statistical Significance | Distance walked, or time tolerating exercise; Protocol | Number of subjects reaching goal heart rate control N (%) | Other physiologic measures | Number with side effects requiring drug withdrawal
Goldenberg, Am J Cardiol, 1994 | Diltiazem | 22 | NR | | NR | | | 21/22 (95) ^3^ p<.001 | | 0
Goldenberg, Am J Cardiol, 1994 | Placebo | 15 | NR | | NR | | | 0/15 (0) | | 0
Ellenbogen, JACC, 1991 | Diltiazem | 23 | NR | | NR | | | 17/23 (74) ^3^ p<.001 | | 1 (hypotension)
Ellenbogen, JACC, 1991 | Placebo | 21 | NR | | NR | | | 0/21 (0) | | 1 (hypotension)
Salerno, Am J Cardiol, 1989 | Diltiazem | 56 | 114 | p<.001 | NR | | | 42/56 (75%) ^3^
Salerno, Am J Cardiol, 1989 | Placebo | 57 | 143 | | NR | | | 7/57 (12%)
Lewis, Irvine, Eur Heart J, 1988 | Digoxin | 6 | 97 | | 159 | NS vs. placebo | Treadmill, modified Bruce | | 12.6 cardiac-output (L/min)
Lewis, Irvine, Eur Heart J, 1988 | Diltiazem (60) | 6 | 82 | | 143 | P<.05 vs. placebo | As above | | 10.9
Lewis, Irvine, Eur Heart J, 1988 | Diltiazem (120) | 6 | 68 | | 133 | P<.05 vs. placebo | As above | | 9.1
Lewis, Irvine, Eur Heart J, 1988 | Digoxin and Diltiazem | 6 | 68 | | 122 | P<.05 vs. placebo | As above | | 9.1
Lewis, Irvine, Eur Heart J, 1988 | Verapamil (80) | 6 | 79 | | 146 | P<.05 vs. placebo | As above | | 9.5
Lewis, Irvine, Eur Heart J, 1988 | Placebo | 6 | 101 | p<.01 across all | 167 | | As above | | 9.0
Lundstrom, JACC, 1990 | Diltiazem | 18 | 76 | p<.001 vs. placebo | 159 | P<.001 vs. placebo | Treadmill 136 watts workload | | 24ml/kg/min (VO_2_) ^4^
Lundstrom, JACC, 1990 | Verapamil | 18 | 80 | p<.01 vs. placebo | 158 | P<.001 vs. placebo | Treadmill 137 watts | | 23ml/kg/min (VO_2_)
Lundstrom, JACC, 1990 | Placebo | 18 | 88 | | 179 | | Treadmill 127 watts | | 22ml/kg/min (VO_2_)
Lundstrom, Am Heart J, 1992 | Xamoterol (100) | 20 | 95 | Ns vs. placebo | 146 | P<.001 vs. placebo | Bike ergometer; Borg scale 18.2 | | | 0
Lundstrom, Am Heart J, 1992 | Xamoterol (200) | 21 | 90 | P<.01 vs.placebo | 138 | P<.001 vs. placebo | Bike ergometer; Borg scale 18.6 | | | 0
Lundstrom, Am Heart J, 1992 | Verapamil | 18 | 78 | Xamoterol (200) | 137 | P<.001 vs. placebo P<.01 vs. Xamoterol (200) | Bike ergometer; Borg scale 18.4 | | | 3 (liver toxicity, pneumonia)
Lundstrom, Am Heart J, 1992 | Placebo | 20 | 101 | | 171 | | Bike ergometer; Borg scale 18.5 | | | 0
Lewis, J Cardiovasc Pharmacol, 1989 | Atenolol | 15 | 68 | Sig. vs. placebo | 120 | P<.01 vs. placebo | 356 m modified Bruce | | | 5 /15 group not specified
Lewis, J Cardiovasc Pharmacol, 1989 | Verapamil | 11 | 68 | Sig. vs. placebo | 131 | P<.01 vs. placebo | 439 m modified Bruce
Lewis, J Cardiovasc Pharmacol, 1989 | Xamoterol | 16 | 83 | Ns vs. placebo | 130 | P<.01 vs. placebo | 402 m modified Bruce
Lewis, J Cardiovasc Pharmacol, 1989 | Placebo | 14 | 90 | P<.01 across all | 164 | P<.01 vs. placebo | 421 m modified Bruce
Panidis, Am J Cardiol, 1983 | Verapamil | 27 | 69 | P<.01 | 104 | P<.01 | Treadmill 3 mph, for 3 min | | | 1
Panidis, Am J Cardiol, 1983 | Placebo | 27 | 87 | | 135 | | As above | | | 0

1 Excludes studies of postoperative atrial fibrillation; boldface type highlights the relevant comparisons

2 Sig. = significant; ns = not statistically significant; NR = not reported

3 Target heart rate <100 bpm or >20% reduction from baseline

4 VO2 = mean oxygen uptake

Evidence table 7B. Results of Placebo-Controlled Trials of Beta-Blockers for Rate Control in Atrial Fibrillation^1^

Author, Journal, Year | Treatment Groups | N | Mean HR on Drug (bpm) | Statistical Significance ^2^ | Mean Maximum Heart Rate with Exercise (bpm) | Statistical Significance | Distance walked, or time tolerating exercise; Protocol | Number of subjects reaching goal heart rate control N (%) | Other physiologic measures | Number with side effects requiring drug withdrawal
Lewis, J Cardiovasc Pharmacol, 1989 | Atenolol | 15 | 68 | Sig. vs. placebo | 120 | P<.01 vs. placebo | 356 m modified Bruce | | | 5/15 group not specified
Lewis, J Cardiovasc Pharmacol, 1989 | Verapamil | 11 | 68 | Sig. vs. placebo | 131 | P<.01 vs. placebo | 439 m modified Bruce
Lewis, J Cardiovasc Pharmacol, 1989 | Xamoterol | 16 | 83 | Ns vs. placebo | 130 | P<.01 vs. placebo | 402 m modified Bruce
Lewis, J Cardiovasc Pharmacol, 1989 | Placebo | 14 | 90 | P<.01 across all | 164 | P<.01 vs. placebo | 421 m modified Bruce
Lundstrom, Am Heart J, 1992 | Xamoterol (100) | 20 | 95 | Ns vs. placebo | 146 | P<.001 vs. placebo | Bike ergometer; Borg scale 18.2 | | | 0
Lundstrom, Am Heart J, 1992 | Xamoterol (200) | 21 | 90 | P<.01 vs. placebo | 138 | P<.001 vs. placebo | Bike ergometer; Borg scale 18.6 | | | 0
Lundstrom, Am Heart J, 1992 | Verapamil | 18 | 78 | P<.001 vs. placebo P<.05 vs. Xamoterol (200) | 137 | P<.001 vs. placebo P<.01 vs. Xamoterol (200) | Bike ergometer; Borg scale 18.4 | | 12.6 cardiac-output (L/min) | 3 (liver toxicity, pneumonia)
Lundstrom, Am Heart J, 1992 | Placebo | 20 | 101 | | 171 | | Bike ergometer; Borg scale 18.5 | | 10.9 | 0
Sweany, Clin Pharmacol Ther, 1985 | Timolol | 40 | NR | | NR | | | 17/40 (42) ^3^ P<.01 vs. placebo | 9.1
Sweany, Clin Pharmacol Ther, 1985 | Placebo | 41 | NR | | NR | | | 2/41 (4.9) | 9.1
DiBianco, Am Heart J, 1984 | Nadolol | 17 | 73 | P<.001 | 126 | P<.001 | 6.3 min modified Bruce | | 9.5 | 0
DiBianco, Am Heart J, 1984 | Placebo | 17 | 92 | | 175 | | 7.8 min modified Bruce | | 9.0 | 0
Ang, Br Heart J, 1990 | Xamoterol | 13 | 72 | Ns vs. placebo | 136 | "significant" vs. placebo or Digoxin | 10.7 min modified Bruce | | 22 ml/kg/min (VO_2_) | 1 (nausea, dyspnea)
Ang, Br Heart J, 1990 | Digoxin | 13 | 62 | P<.01 vs. placebo P<.005 vs. Xamoterol | 150 | Ns vs. placebo | 10.2 min modified Bruce | | | 0
Ang, Br Heart J, 1990 | Placebo | 13 | 70 | | 159 | | 9.7 min modified Bruce | | | 0
Myers, J Appl Physiol, 1987 | Celiprolol | 9 | 73 | Ns vs. placebo | 118 | P<.01 vs. placebo | 10 min modified Bruce
Myers, J Appl Physiol, 1987 | Placebo | 9 | 80 | | 171 | | 11.2 min modified Bruce
Lin, J Cardiovasc Pharmacol, 1986 | Celiprolol | 21 | NR | | NR | P<.001
Lin, J Cardiovasc Pharmacol, 1986 | Placebo | 21 | NR | | NR
Channer, Br J Clin Pharmacol, 1994 | Atenolol (50) | 8 | 98 (mean maximum daily HR) | P<.001 vs. placebo, Sig vs. pindolol | NR
Channer, Br J Clin Pharmacol, 1994 | Atenolol (100) | 8 | 96 | P<.001 vs. placebo, Sig vs. Pindolol | NR
Channer, Br J Clin Pharmacol, 1994 | Pindolol (5) | 8 | 103 | P<.001 vs. placebo | NR
Channer, Br J Clin Pharmacol, 1994 | Pindolol (15) | 8 | 109 | P<.001 vs. placebo | NR
Channer, Br J Clin Pharmacol, 1994 | Placebo | 8 | 122 | | NR
Wong, Am J Cardiol, 1990 | Digoxin | 11 | 91 | Ns vs.placebo | 177 | | 14.2 min modified Bruce
Wong, Am J Cardiol, 1990 | Digoxin + Labetalol | 11 | 90 | Ns vs. placebo | 154 | P<.01 vs. Digoxin or placebo | 16.1 min modified Bruce
Wong, Am J Cardiol, 1990 | Labetalol | 11 | 91 | Ns vs. placebo | 156 | P<.01 vs. Digoxin or placebo | 15.6 min modified Bruce
Wong, Am J Cardiol, 1990 | Placebo | 11 | 102 | Ns vs. placebo | 175 | | 14.1 min modified Bruce

1 Excludes studies of postoperative atrial fibrillation; boldface type highlights the relevant comparisons

2 Sig. = significant; ns = not statistically significant; NR = not reported

3 Target heart rate <100 bpm

NOTE: VO2 = mean oxygen uptake.

Evidence table 7C. Results of Placebo-Controlled Trials of Other Drugs or Combinations for Rate Control in Atrial Fibrillation ^1^

Author Journal Year | Treatment Groups | N | Mean HR on Drug (bpm) | Statistical Significance ^2^ | Mean Maximum Heart Rate with Exercise (bpm) | Statistical Significance | Distance walked, or time tolerating exercise; Protocol | Number of subjects reaching goal heart rate control N (%) | Other physiologic measures | Number with side effects requiring drug withdrawal
Roth, Ann Intern Med, 1992 | Clonidine | 9 | 82 (includes three in sinus) | P = .07 vs. baseline | NR | | | 8/9 ^3^ (89)
Roth, Ann Intern Med, 1992 | Placebo | 9 | 117 (includes one in sinus) | P=.12 vs. baseline | NR | | | 2/9 (22)
Scardi, Lancet, 1993 | Clonidine | 17 | 90 | P=.007 vs. placebo | NR | | | | | 1 weak, hypotension
Scardi, Lancet, 1993 | Placebo | 17 | 104 | | NR | | | | | 0
Botto, Int J Cardiol, 1997 | Propafenone (450) | 35 | 19% decrease (n=19), at 4 hrs | P<.001 vs. placebo | NR | | | | | 0
Botto, Int J Cardiol, 1997 | Propafenone (600) | 35 | 30% decrease (n=15), at 4 hrs | P<.001 vs. placebo, P<.001 vs. (450) | NR | | | | | 0
Botto, Int J Cardiol, 1997 | Placebo | 35 | 7% decrease (n=29), at 4 hrs | | NR | | | | | 0
Wong, Am J Cardiol, 1990 | Digoxin | 11 | 91 | Ns vs. placebo | 177 | | 14.2 min modified Bruce
Wong, Am J Cardiol, 1990 | Digoxin and Labetalol | 11 | 90 | Ns vs. placebo | 154 | P<.01 vs. Digoxin or placebo | 16.1 min modified Bruce
Wong, Am J Cardiol, 1990 | Labetalol | 11 | 91 | Ns vs. placebo | 156 | P<.01 vs. Digoxin or placebo | 15.6 min modified Bruce
Wong, Am J Cardiol, 1990 | Placebo | 11 | 102 | Ns vs. placebo | 175 | | 14.1 min modified Bruce
Lewis Eur Heart J, 1988 | Digoxin | 6 | 97 | | 159 | Ns vs. Placebo | Treadmill, modified Bruce | | 12.6 cardiac-output (L/min)
Lewis Eur Heart J, 1988 | Diltiazem (60) | 6 | 82 | | 143 | P<.05 vs. placebo | As above | | 10.9
Lewis Eur Heart J, 1988 | Diltiazem (120) | 6 | 68 | | 133 | P<.05 vs. placebo | As above | | 9.1
Lewis Eur Heart J, 1988 | Digoxin and Diltiazem | 6 | 68 | | 122 | P<.05 vs. placebo | As above | | 9.1
Lewis Eur Heart J, 1988 | Verapamil (80) | 6 | 79 | | 146 | P<.05 vs. placebo | As above | | 9.5
Lewis Eur Heart J, 1988 | Placebo | 6 | 101 | P<.01 across all | 167 | | As above | | 9.0
Ang, Br Heart J, 1990 | Xamoterol | 13 | 72 | Ns vs. placebo | 136 | "significant" vs. placebo or Digoxin | 10.7 min modified Bruce | | 23,668 mm Hg-mn (pressure-rate product) | 1 (nausea, dyspnea)
Ang, Br Heart J, 1990 | Digoxin | 13 | 62 | P<.01 vs. placebo P<.005 vs. Xamoterol | 150 | Ns vs. placebo | 10.2 min modified Bruce | | 25,786 mm Hg-mn (pressure-rate product) | 0
Ang, Br Heart J, 1990 | Placebo | 13 | 70 | | 159 | | 9.7 min modified Bruce | | 28,612 mm Hg-mn (pressure-rate product) | 0
Koh, Song, Int J Cardiol, 1995a | Digoxin and Diltiazem | 35 | 80 | P<.05 vs. placebo | 154 | P<.05 vs. placebo | Treadmill Bruce protocol | | Improved exercise capacity with either active therapy | 0
Koh, Song, Int J Cardiol, 1995a | Digoxin and Betaxolol | 35 | 67 | P<.05 vs. dig/dilt | 135 | P<.05 vs. dig/dilt | | | | 0
Koh, Song, Int J Cardiol, 1995a | Placebo | 35 | 111 | | 191 | | | | | 0
Koh, Kwon, Am J Cardiol, 1995b | Digoxin | 11 | 84 | P<.01 vs. placebo | 165 | | Treadmill Bruce protocol | | No difference between groups in exercise capacity, or maximal tolerated exertion
Koh, Kwon, Am J Cardiol, 1995b | Digoxin and Diltiazem | 10 | 75 | P<.01 vs. placebo | 143 | P<.01 vs. Digoxin or placebo | As above
Koh, Kwon, Am J Cardiol, 1995b | Digoxin and Betaxolol | 10 | 68 | P<.01 vs. placebo | 133 | P<.01 vs. Digoxin or placebo | As above
Koh, Kwon, Am J Cardiol, 1995b | Placebo | 14 | 105 | | 196 | | As above
Falk, Ann Intern Med, 1987 | Digoxin | 18 | 123 (n=9) | Ns vs. placebo | NR | NR
Falk, Ann Intern Med, 1987 | Placebo | 18 | 125 (n=8) | | NR | NR
DAAF, Eur Heart J, 1997 | Digoxin | 117 | 91 | P<.0001 vs. placebo | NR | NR | | | | 2 significant arrhythmias
DAAF, Eur Heart J, 1997 | Placebo | 122 | 116 | | NR | NR | | | | 0 arryhthmias
Jordaens, Eur Heart J, 1997 | Digoxin | 19 | 118 | P<.02 vs. placebo | NR | NR | | | | 1 with hypotension, group unknown
Jordaens, Eur Heart J, 1997 | Placebo | 20 | 139 | | NR | NR
Brodsky, Am J Cardiol, 1994a | Magnesium sulfate | 10 | | | | | | 10/104 P<.05 vs. placebo | | 2 pauses
Brodsky, Am J Cardiol, 1994a | Placebo | 8 | | | | | | 4/8 | | 5 arrhythmias

1 Excludes studies of postoperative atrial fibrillation; boldface type highlights the relevant comparisons

2 Sig. = significant; Ns = not statistically significant; NR = not reported

3 Target heart rate <100 bpm

4 Target heart rate <90 bpm

Evidence table 7D. Results of Trials Comparing-Channel-Blockers to Digoxin for Rate Control in Atrial Fibrillation^1^

Author, Journal, Year | Treatment Groups | N | Mean HR on Drug (bpm) | Statistical Significance ^2^ | Mean Maximum Heart Rate with Exercise (bpm) ^2^ | Statistical Significance ^2^ | Distance walked, or time tolerating exercise; Protocol | Number of subjects reaching goal heart rate control N (%) | Other physiologic measures | Number with side effects requiring drug withdrawal
Schreck, Ann Emerg Med, 1997 | Digoxin | 9 | 117 | P<.01 vs. baseline at 180 min | NR | | | | | 0
Schreck, Ann Emerg Med, 1997 | Diltiazem | 11 | 90 | P<.0006 vs. baseline at 5 min, P<.003 vs. Digoxin at 5 min | NR | | | | | 0
Schreck, Ann Emerg Med, 1997 | Diltiazem/Digoxin | 10 | 88 | Ns different from Diltiazem alone | NR | | | | | 0
Lewis, Laing, et al. Eur Heart J, 1988 | Digoxin | 14 | 100 | | 152 | | 6 min walk in corridor | | | 0
Lewis, Laing, et al. Eur Heart J, 1988 | Diltiazem | 14 | 91 | | 140 | | As above | | | 3 (edema, dyspnea, chest pain)
Lewis, Laing, et al. Eur Heart J, 1988 | Digoxin and Diltiazem | 14 | 83 | P<.01 vs. Digoxin or Diltiazem | 128 | P<.01 vs. Digoxin or Diltiazem | As above | | | 0
Lewis, Irvine et al., Eur Heart J, 1988 | Digoxin | 6 | 97 | | 159 | Ns vs. placebo | Treadmill, modified Bruce | | 12.6 cardiac output (L/mn)
Lewis, Irvine et al., Eur Heart J, 1988 | Diltiazem (60) | 6 | 82 | | 143 | P<.05 vs. placebo | As above | | 10.9
Lewis, Irvine et al., Eur Heart J, 1988 | Diltiazem (120) | 6 | 68 | | 133 | P<.05 vs. placebo | As above | | 9.1
Lewis, Irvine et al., Eur Heart J, 1988 | Digoxin and Diltiazem | 6 | 68 | | 122 | P<.05 vs. placebo | As above | | 9.1
Lewis, Irvine et al., Eur Heart J, 1988 | Verapamil (80) | 6 | 79 | | 146 | P<.05 vs. placebo | As above | | 9.5
Lewis, Irvine et al., Eur Heart J, 1988 | Placebo | 6 | 101 | P<.01 across all | 167 | | As above | | 9.0
Pomfret, Clin Sci, 1988 | Digoxin | 7 | 80 | | 162 | | Treadmill, load 20ml/min/kg, Unit Mets protocol | | 10.3 ml/mn/kg (VO_2_) ^3^
Pomfret, Clin Sci, 1988 | Digoxin and Verapamil (40) | 7 | 73 | P<.05 vs. each other | 143 | P<.05 vs. Digoxin or Verapamil (40) | As above | | 14.4 ml/mn/kg (VO_2_)
Pomfret, Clin Sci, 1988 | Verapamil (40) | 7 | 92 | | 169 | | As above | | 8.5 ml/mn/kg (VO_2_)
Pomfret, Clin Sci, 1988 | Verapamil (80) | 7 | 81 | | 142 | P<.05 vs. Digoxin or Verapamil (40) | As above | | 15.8 ml/mn/kg (VO_2_)
Ahuja, Int J Cardiol, 1989 | Digoxin | 10 | 80 | Ns vs. baseline | 182 | P<.01 vs. baseline | 7.1 min until dyspnea, Chungs treadmill protocol | | | 0
Ahuja, Int J Cardiol, 1989 | Metoprolol | 10 | 72 | P<.01 vs. baseline | 149 | P<.01 vs. baseline | 10.5 min As above | | | 0
Ahuja, Int J Cardiol, 1989 | Verapamil | 10 | 65 | P<.05 vs. baseline | 138 | P<.01 vs. baseline | 11.3 min As above | | | 0

1 Excludes studies of postoperative atrial fibrillation; boldface type highlights the relevant comparisons

2 Sig. = significant; Ns = not statistically significant; NR = not reported

3 VO2 = mean oxygen uptake

Evidence table 7E. Results of Trials Comparing Beta-Blockers to Digoxin for Rate Control in Atrial Fibrillation^1^

Author, Journal, Year | Treatment Groups | N | Mean HR on Drug (bpm) | Statistical Significance ^2^ | Mean Maximum Heart Rate with Exercise (bpm) ^2^ | Statistical Significance ^2^ | Distance walked, or time tolerating exercise; Protocol | Number of subjects reaching goal heart rate control N (%) | Other physiologic measures | Number with side effects requiring drug withdrawal
Lawson-Matthew, Age/Ageing, 1995 | Digoxin | 20 completed all three arms | 123 | | NR | | | | 1,207 pauses, P<.0001 vs. Xamoterol | 0
Lawson-Matthew, Age/Ageing, 1995 | Xamoterol and Digoxin | | 110 (mean maximum daily HR) | P<.0001 vs. Digoxin | NR | | | | 427 (total # of pauses in 24 hrs) P<.001 vs. Xamoterol | 1/22 Diarrhea
Lawson-Matthew, Age/Ageing, 1995 | Xamoterol | | 135 | P<.0005 vs. Digoxin | NR | | | | 18 pauses | 1/22 CHF
Ang, Br Heart J, 1990 | Xamoterol | 13 | 72 | Ns vs. placebo | 136 | "Significant" vs. placebo or Digoxin | 10.7 min modified Bruce | | 23,668 mm Hg-min (pressure-rate product) | 1 (nausea, dyspnea)
Ang, Br Heart J, 1990 | Digoxin | 13 | 62 | P<.01 vs. placebo P<.005 vs. Xamoterol | 150 | Ns vs. placebo | 10.2 min modified Bruce | | 25,786 mm Hg-min (pressure-rate product) | 0
Ang, Br Heart J, 1990 | Placebo | 13 | 70 | | 159 | | 9.7 min modified Bruce | | 28,612 mm Hg-min (pressure-rate product) | 0
Ahuja, Int J Cardiol, 1989 | Digoxin | 10 | 80 | Ns vs. baseline | 182 | P<.01 vs. baseline | 7.1 min until dyspnea, Chungs treadmill protocol | | | 0
Ahuja, Int J Cardiol, 1989 | Metoprolol | 10 | 72 | P<.01 vs. baseline | 149 | P<.01 vs. baseline | 10.5 min As above | | | 0
Ahuja, Int J Cardiol, 1989 | Verapamil | 10 | 65 | P<.05 vs. baseline | 138 | P<.01 vs. baseline | 11.3 min As above | | | 0
Wong, Am J Cardiol, 1990 | Digoxin | 11 | 91 | Ns vs. placebo | 177 | | 14.2 min modified Bruce
Wong, Am J Cardiol, 1990 | Digoxin and Labetalol | 11 | 90 | Ns vs. placebo | 154 | P<.01 vs. Digoxin or placebo | 16.1 min modified Bruce
Wong, Am J Cardiol, 1990 | Labetalol | 11 | 91 | Ns vs. placebo | 156 | P<.01 vs. Digoxin or placebo | 15.6 min modified Bruce
Wong, Am J Cardiol, 1990 | Placebo | 11 | 102 | Ns vs. placebo | 175 | | 14.1 min modified Bruce

1 Excludes studies of postoperative atrial fibrillation; boldface type highlights the relevant comparisons

2 Sig. = significant; Ns = not statistically significant; NR = not reported

Evidence table 7F. Results of Digoxin-Controlled Trials on Other Drugs or Combinations for Rate Control for Atrial Fibrillation ^1^

Author, Journal, Year | Treatment Groups | N | Mean HR on Drug (bpm) | Statistical Significance ^2^ | Mean Maximum Heart Rate with Exercise (bpm) ^2^ | Statistical Significance ^2^ | Distance walked, or time tolerating exercise; Protocol | Number of subjects reaching goal heart rate control N (%) | Other physiologic measures | Number with side effects requiring drug withdrawal
Brodsky, Am Heart J, 1994 | Digoxin | 21 | 94 | | 173 | | Treadmill, modification of modified Bruce
Brodsky, Am Heart J, 1994 | Digoxin and Sotalol (80) | 20 | 79 | P<.05 vs. Digoxin | 150 | P<.05 vs. Digoxin | As above
Brodsky, Am Heart J, 1994 | Digoxin and Sotalol (160) | 19 | 79 | P<.05 vs. Digoxin | 153 | P<.05 vs. Digoxin | As above
Channer, Eur Heart J, 1987 | Digoxin (x2) | 12 | 2103 area under curve for max. resting HR | P<.001 vs. Digoxin | NR | | 463 meters during 6 min. corridor walk | | 9/12 (75%) with pauses >2.5 sec
Channer, Eur Heart J, 1987 | Digoxin and Verapamil | 14 | 2124 area under curve for max. resting HR | P<.001 vs. Digoxin | NR | | 454 meters during 6 min. corridor walk | | 6/14 (43%) with pauses >2.5 sec
Channer, Eur Heart J, 1987 | Digoxin | 14 | 2451 area under curve for max. resting HR | | NR | | 461 meters during 6 min. corridor walk | | 4/14 (29%) with pauses >2.5 sec
Smit, Eur J Clin Pharmacol, 1990 | Digoxin (1.5) | 6 | 60 (includes 5 in sinus)-median time 9 hours to redution in rate | | NR | | | | | 1/6 (Mobitz I block)
Smit, Eur J Clin Pharmacol, 1990 | Digoxin (0.5 x3) | 5 | 55 (includes 2 in sinus)-median time 20 hours to reduction in rate | | NR | | | | | 1/5 (NSVT)
Zoble, Am J Cardiol, 1987 | Digoxin | 13 | 84 | | 162 | | 9.1 min modified Bruce
Zoble, Am J Cardiol, 1987 | Digoxin and Nadolol | 13 | 63 | P<.001 vs. Digoxin | 120 | P<.002 vs. Digoxin | 9. min modified Bruce
Stern, Chest, 1982 | Digoxin | 9 | 108 | | 144 | | As above
Stern, Chest, 1982 | Verapamil and Digoxin | 9 | 76 | P<.01 vs. Digoxin | 113 | P<.01 vs. Digoxin | Bike 3 min at 50W or treadmill for 3.5 min
Lang, Am Heart J, 1983 | Digoxin | 20 | 90 | | 165 | | 3.6 min on bike | | 522 units
Lang, Am Heart J, 1983 | Verapamil and Digoxin | 20 | 70 | P<.0005 | 136 | P<.0005 | 4.9 min on bike | | 806 units m.e.c. ^3^
Hays, Ann Emerg Med, 1994 | Digoxin | | 131 (n=5) | | NR | | | | | 0
Hays, Ann Emerg Med, 1994 | Magnesium sulfate and Digoxin | | 120 (n=6) | Ns | NR | | | | | 0
Schreck, Ann Emerg Med, 1997 | Digoxin | 9 | 117 | P<.01 vs. baseline at 180 min | NR | | | | | 0
Schreck, Ann Emerg Med, 1997 | Diltiazem | 11 | 90 | P<.0006 vs. baseline at 5 min, P<.003 vs. Digoxin at 5 min | NR | | | | | 0
Schreck, Ann Emerg Med, 1997 | Diltiazem and Digoxin | 10 | 88 | Ns different from Diltiazem alone | NR | | | | | 0
Pomfret, Clin Sci, 1988 | Digoxin | 7 | 80 | | 162 | | Treadmill, load 20ml/min/kg, unit mets protocol | | 10.3ml/min/kg (VO_2_) ^4^
Pomfret, Clin Sci, 1988 | Digoxin and Verapamil (40) | 7 | 73 | P<.05 vs. each other | 143 | P<.05 vs. Digoxin or Verapamil (40) | As above | | 14.4 ml/min/kg (VO_2_) ^4^
Pomfret, Clin Sci, 1988 | Verapamil (40) | 7 | 92 | | 169 | | As above | | 8.5 ml/min/kg (VO_2_) ^4^
Pomfret, Clin Sci, 1988 | Verapamil (80) | 7 | 81 | | 142 | P<.05 vs. Digoxin or Verapamil (40) | As above | | 15.8 ml/min/kg (VO_2_) ^4^
Lewis, Laing, Eur Heart J, 1988 | Digoxin | 14 | 100 | | 152 | | 6 min walk in corridor | | | 0
Lewis, Laing, Eur Heart J, 1988 | Diltiazem | 14 | 91 | | 140 | | As above | | | 3 (edema, dyspnea, chest pain)
Lewis, Laing, Eur Heart J, 1988 | Digoxin and Diltiazem | 14 | 83 | P<.01 vs. Digoxin or Diltiazem | 128 | P<.01 vs. Digoxin or Diltiazem | As above | | | 0
Lawson-Matthew, Age/Ageing, 1995 | Digoxin | 20 com¡pleted all three arms | 123 | | NR | | | | 1207 pauses, p<.0001 vs. Xamoterol | 0
Lawson-Matthew, Age/Ageing, 1995 | Xamoterol | | 135 | P<.0005 vs. Digxoin | NR | | | | 18 pauses | 1/22 CHF
Lawson-Matthew, Age/Ageing, 1995 | Xamoterol and Digoxin | | 110 (mean maximum daily HR) | P<.0001 vs. Digoxin | NR | | | | 427 pauses P<.001 vs. Xamoterol | 1/22 Diarrhea
Lewis, Irvine, Eur Heart J, 1988 | Digoxin | 6 | 97 | | 159 | Ns vs. placebo | Treadmill, modified Bruce | | 12.6 (L/min) post-exercise
Lewis, Irvine, Eur Heart J, 1988 | Diltiazem (60) | 6 | 82 | | 143 | P<.05 vs. placebo | As above | | 10.9
Lewis, Irvine, Eur Heart J, 1988 | Diltiazem (120) | 6 | 68 | | 133 | P<.05 vs. placebo | As above | | 9.1
Lewis, Irvine, Eur Heart J, 1988 | Digoxin and Diltiazem | 6 | 68 | | 122 | P<.05 vs. placebo | As above | | 9.1
Lewis, Irvine, Eur Heart J, 1988 | Verapamil (80) | 6 | 79 | | 146 | P<.05 vs. placebo | As above | | 9.5
Lewis, Irvine, Eur Heart J, 1988 | Placebo | 6 | 101 | P<.01 across all | 167 | | As above | | 9.0
Wong, Am J Cardiol, 1990 | Digoxin | 11 | 91 | Ns vs. placebo | 177 | | 14.2 min modified Bruce
Wong, Am J Cardiol, 1990 | Digoxin and Labetalol | 11 | 90 | Ns vs. placebo | 154 | P<.01 vs. dig or placebo | 16.1 min modified Bruce
Wong, Am J Cardiol, 1990 | Labetalol | 11 | 91 | Ns vs. placebo | 156 | P<.01 vs. dig or placebo | 15.6 min modified Bruce
Wong, Am J Cardiol, 1990 | Placebo | 11 | 102 | Ns vs. placebo | 175 | | 14.1 min modified Bruce
Koh, Am J Cardiol, 1995 | Digoxin | 11 | 84 | P<.01 vs. placebo | 165 | | Treadmill, Bruce protocol | | No difference between groups in exercise capacity, or maximal tolerated exertion
Koh, Am J Cardiol, 1995 | Digoxin/Dilatiazem | 10 | 75 | P<.01 vs. placebo | 143 | P<.01 vs. Digoxin or placebo | As above
Koh, Am J Cardiol, 1995 | Digoxin/Betaxolol | 10 | 68 | P<.01 vs. placebo | 133 | P<.01 vs. Digoxin or placebo | As above
Koh, Am J Cardiol, 1995 | Placebo | 14 | 105 | | 196 | | As above

1 Excludes studies of postoperative atrial fibrillation; boldface type highlights the relevant comparisons

2 Sig. = significant; Ns = not statistically significant; NR = not reported

3 Maximum exercise capacity, formula provided in original article

4 VO2 = mean oxygen uptake

Evidence table 7G. Results of Trials Comparing Other Drugs for Rate Control in Atrial Fibrillation^1^

Author, Journal, Year | Treatment Groups | N | Mean HR on Drug (bpm) | Statistical Significance ^2^ | Mean Maximum Heart Rate with Exercise (bpm) ^2^ | Statistical Significance ^2^ | Distance walked, or time tolerating exercise; Protocol | Number of subjects reaching goal heart rate control N (%) | Other physiologic measures | Number with side effects requiring drug withdrawal
Boudonas, Acta Cardiol, 1995 | Diltiazem | 14 | 94 (n=20) | P< .001 vs. baseline | NR | | | | | 0
Boudonas, Acta Cardiol, 1995 | Disopyramide | 16 | 136 (n=18) | Ns vs. baseline | NR | | | | | 0
Suttorp, JACC, 1990 | Propafenone | 25 | 101 (n=12) | P<.001 vs. baseline | NR | | | | | 0/25
Suttorp, JACC, 1990 | Flecainide | 25 | 116 (n=6) | P<.05 vs. baseline | NR | | | | | 3/25 (left bundle block, junctional)
Kingma, Am J Cardiol, 1992 | Propafenone | 25 | 116 (n=11) | P<.05 vs. baseline | NR
Kingma, Am J Cardiol, 1992 | Flecainide | 45 | 101 (n=12) | P<.0001 vs. baseline | NR | | | | | 4 (conduction abnormalities)
Kingma, Am J Cardiol, 1992 | Verapamil | 20 | 84 (n=19) | P<.001 vs. baseline | NR
Dahlstrom, Clin Cardiol, 1992 | Diltiazem and Digoxin | 10 | 84 | P<.005 across all tx. | 164 | P<.0001 across all tx. | Treadmill at 30W with 10W inc. until symptoms
Dahlstrom, Clin Cardiol, 1992 | Propranolol and Digoxin | 10 | 163 | P<.05 vs. dilt/dig | 135 | P<.05 vs. Dilt/dig | As above | | | 1
Dahlstrom, Clin Cardiol, 1992 | Diltiazem and Propranolol and Digoxin | 11 | 69 | P<.05 vs. dilt/dig | 135 | P<.05 vs. Dilt/dig | As above | | | 2
Joshi, J Assoc Physicians India, 1995 | Magnesium sulfate | 41 | NR | | NR | | | 8/41 (20) ^3^ | | 0
Joshi, J Assoc Physicians India, 1995 | Verapamil | 45 | NR | | NR | | | 25/45 (56) P<.0001 | | 0
Gullestad, Clin Cardiol, 1993 | Magnesium sulfate | 26 | NR | | NR | | | 4/8 (50) ^3^ | | 0
Gullestad, Clin Cardiol, 1993 | Verapamil | 31 | NR | | NR | | | 13/19 (68) stat. sig. not given | | 6 (hypotension, and CHF)
James, Eur Heart J, 1989 | Pindolol/Digoxin | 12 | NR | | NR | | | | 2,340 maximum AUC ^4^ P<.05 vs ver/dig 2,431-max AUC
James, Eur Heart J, 1989 | Verapamil/Digoxin | 12 | NR | | NR
Zehender, J Am Coll Cardiol, 1992 | Quinidine/Verapamil/Digoxin | 20 | 72 | Ns difference from baseline | NR | | | | | 0
Zehender, J Am Coll Cardiol, 1992 | Amiodarone/Digoxin | 20 | 69 | P<.05 vs. baseline | NR | | | | | 1/20 bradycardia
Lee, J Intern Med, 1996 | Propafenone | 48 | 114 (n=23) | P<.01 vs.baseline, P<.01 vs. quinidine | NR | | | | | 2/48 dizziness
Lee, J Intern Med, 1996 | Quinidine | 48 | 138 (n=36) | P<.01 vs. baseline | NR | | | | | 2/48 gastrointestinal discomfort

1 Excludes studies of postoperative atrial fibrillation; boldface type highlights the relevant comparisons

2 Sig. = significant; Ns = not statistically significant; NR = not reported

3 Target heart rate <100 bpm

4 AUC = area under the curve of heart rate plotted against time

Evidence table 8. Designs of Studies of Antithrombotic Therapies for Patients with Atrial Fibrillation

| Treatment Groups | | | | | Study Quality ^1^
Author, Journal, Year | Regimen | N | Target INR for Warfarin Group | Inclusion ^2^ Criteria | Exclusion ^3^ Criteria | Rep. % | Bias % | Tx % | Outcome % | Statistics % | Overall %
SPAF I, Circulation, 1991 | Warfarin | 210 | 2.0-4.5 | Adults, chronic or paroxysmal | Valv, CHF | 100 | 84 | 50 | 92 | 100 | 85
SPAF I, Circulation, 1991 | Controls for Warfarin group | 211 | 2.0-4.5 | Adults, chronic or paroxysmal | Valv, CHF | 100 | 84 | 50 | 92 | 100 | 85
SPAF I, Circulation, 1991 | Aspirin 325 mg qd | 552 | 2.0-4.5 | Adults, chronic or paroxysmal | Valv, CHF | 100 | 84 | 50 | 92 | 100 | 85
SPAF I, Circulation, 1991 | Controls for aspirin group placebo | 568 | 2.0-4.5 | Adults, chronic or paroxysmal | Valv, CHF | 100 | 84 | 50 | 92 | 100 | 85
SPAF II, Lancet, 1994 | Warfarin | 358 (I) ^4^ | 2.0-4.5 | Age not specified, chronic or paroxysmal | Valv | 75 | 67 | 50 | 67 | 100 | 72
SPAF II, Lancet, 1994 | Aspirin 325 mg qd | 357 (I) | 2.0-4.5 | Age not specified, chronic or paroxysmal | Valv | 75 | 67 | 50 | 67 | 100 | 72
SPAF II, Lancet, 1994 | Warfarin | 197 (II) | 2.0-4.5 | Age not specified, chronic or paroxysmal | Valv | 75 | 67 | 50 | 67 | 100 | 72
SPAF II, Lancet, 1994 | Aspirin 325 mg qd | 188 (II) | 2.0-4.5 | Age not specified, chronic or paroxysmal | Valv | 75 | 67 | 50 | 67 | 100 | 72
SPAF III, ^5^ Lancet, 1996 | Warfarin | 523 | 2.0-3.0 | Age not specified, chronic or paroxysmal | Valv | 75 | 84 | 50 | 84 | 100 | 79
SPAF III, ^5^ Lancet, 1996 | Aspirin 325 mg qd & low dose Warfarin | 521 | 1-2-1.5 | Age not specified, chronic or paroxysmal | Valv | 75 | 84 | 50 | 84 | 100 | 79
BAATAF, N Eng J Med, 1990 | Warfarin | 212 | 1.5-2.7 | Age not specified, chronic or paroxysmal | Valv, CHF | 88 | 84 | 63 | 100 | 100 | 87
BAATAF, N Eng J Med, 1990 | Placebo (includes some on aspirin) | 208 | 1.5-2.7 | Age not specified, chronic or paroxysmal | Valv, CHF | 88 | 84 | 63 | 100 | 100 | 87
CAFA (Connolly), JACC, 1991 | Warfarin | 187 | 2.0-3.0 | [image] 19 yrs, chronic or paroxysmal | HTN, Valv | 88 | 84 | 63 | 67 | 90 | 78
CAFA (Connolly), JACC, 1991 | Placebo | 191 | 2.0-3.0 | [image] 19 yrs, chronic or paroxysmal | HTN, Valv | 88 | 84 | 63 | 67 | 90 | 78
SPINAF (Ezekowitz), N Eng J Med, 1992 | Warfarin | 260 | 1.4-2.8 | Age not specified, chronic | BP >180/105, Valv, SF, CHF | 100 | 100 | 63 | 84 | 100 | 89
SPINAF (Ezekowitz), N Eng J Med, 1992 | Placebo | 265 | 1.4-2.8 | Age not specified, chronic | BP >180/105, Valv, SF, CHF | 100 | 100 | 63 | 84 | 100 | 89
AFASAK I (Petersen), Lancet, 1989 | Warfarin | 335 | 2.8-4.2 | >18 yrs, chronic or paroxysmal | BP >180/100, Valv | 88 | 67 | 50 | 75 | 70 | 70
AFASAK I (Petersen), Lancet, 1989 | Aspirin 75 mg qd | 336 | 2.8-4.2 | >18 yrs, chronic or paroxysmal | BP >180/100, Valv | 88 | 67 | 50 | 75 | 70 | 70
AFASAK I (Petersen), Lancet, 1989 | Placebo | 336 | 2.8-4.2 | >18 yrs, chronic or paroxysmal | BP >180/100, Valv | 88 | 67 | 50 | 75 | 70 | 70
AFASAK II (Gullov), Arch Intern Med, 1998 | Warfarin | 170 | 2.0-3.0 | >18 yrs, chronic | BP >180/100, Valv | 100 | 50 | 50 | 83 | 90 | 75
AFASAK II (Gullov), Arch Intern Med, 1998 | Aspirin 300 mg qd | 169 | 2.0-3.0 | >18 yrs, chronic | BP >180/100, Valv | 100 | 50 | 50 | 83 | 90 | 75
AFASAK II (Gullov), Arch Intern Med, 1998 | Aspirin (300 mg qd) and low dose Warfarin | 171 | 2.0-3.0 | >18 yrs, chronic | BP >180/100, Valv | 100 | 50 | 50 | 83 | 90 | 75
AFASAK II (Gullov), Arch Intern Med, 1998 | Low dose Warfarin | 167 | 2.0-3.0 | >18 yrs, chronic | BP >180/100, Valv | 100 | 50 | 50 | 83 | 90 | 75
EAFT (Optimal Oral Anticoagulant), N Engl J Med, 1995 | Warfarin | 225 | 2.5-4.0 | >25 yrs, chronic or paroxysmal | BP >180/100 | 88 | 84 | 50 | 84 | 100 | 81
EAFT (Optimal Oral Anticoagulant), N Engl J Med, 1995 | Aspirin 300 mg qd | 404 | 2.5-4.0 | >25 yrs, chronic or paroxysmal | BP >180/100 | 88 | 84 | 50 | 84 | 100 | 81
EAFT (Optimal Oral Anticoagulant), N Engl J Med, 1995 | Placebo | 378 | 2.5-4.0 | >25 yrs, chronic or paroxysmal | BP >180/100 | 88 | 84 | 50 | 84 | 100 | 81
Morocutti, Stroke, 1997 | Warfarin | 454 | 2.0-3.5 | >30 yrs, chronic or paroxysmal | HTN poorly controlled, Valv | 50 | 67 | 83 | 75 | 100 | 75
Morocutti, Stroke, 1997 | Indobufen 200 mg bd | 462 | 2.0-3.5 | >30 yrs, chronic or paroxysmal | HTN poorly controlled, Valv | 50 | 67 | 83 | 75 | 100 | 75
Harenberg, Semin Thromb Hemost, 1993 | LMWH ^6^ 7500 antiFactor Xa JC units, qd | 35 | | >55 yrs, chronic | BP >200/120, Valv, CHF | 63 | 47 | 88 | 75 | 38 | 56
Harenberg, Semin Thromb Hemost, 1993 | Placebo | 40 | | >55 yrs, chronic | BP >200/120, Valv, CHF | 63 | 47 | 88 | 75 | 38 | 56

Study quality: rep = representativeness; bias = bias and confounding; Tx = description of therapy; outcomes = outcomes assessment; stats = statistical analysis; overall = average of the five categorical scores

2 Inclusion criteria: chronic = chronic atrial fibrillation; paroxysmal = Paroxysmal atrial fibrillation

3 Exclusion criteria: BP = blood pressure; valv = valvular disease; ST = stroke or TIA; CHF = congestive heart failure; HTN = hypertension, as defined in each study

4 Study resolves two parallel trials: group I patients are < 75 years old, group II patients are > 75 years old

5 Study restricted to high-risk patients defined as one of the following: systolic blood pressure > 160 mmHg, history of stroke or TIA, ejection fraction < 25% or recent symptomatic congestive heart failure, or female over 75 years old

6 LMWH = low molecular weight heparin

Evidence table 9. Results of Studies of Antithrombotic Therapies for Patients with Atrial Fibrillation

| Patient Characteristics ^1^ | | | | | | | Therapy ^2^ | | | | | Outcomes
Author, Journal, Year | Mean Age (years) | Male N (%) | Stroke or TIA N (%) | Paroxs N (%) | DM N (%) | CHF N (%) | HTN N (%) | Drug | Above Target Range (%) | In Target Range (%) | Below Target Range (%) | Mean Followup Time (months) | Stroke N (%) | Embolism N (%) | Major Bleed N (%) | Minor Bleed N (%) | Deaths N (%) | Comments
SPAF I, Circulation, 1991 | 66 | 303 (72) | 34 (8.1) | 151 (36) | 66 (16) | 70 (17) | 219 (52) | Warfarin 210 | 5 | 71 | 23 | 148 | 6 (2.9) | | 4 (1.9) | | | Had warfarin-eligible and warfarin-ineligible arms; the warfarin ineligible arm consists of patients considered to be at high risk of bleeding, aspirin vs. placebo comparison consists of patients from both warfarin eligible and warfarin ineligible arms
SPAF I, Circulation, 1991 | | | | | | | | Placebo (W) ^3^ 211 | | | | | 139 | 17 (8.0) | 1 (0.5) | 4 (1.9)
SPAF I, Circulation, 1991 | 67 | 790 (71) | 73 (6.5) | 376 (34) | 196 (18) | 224 (20) | 588 (52) | Aspirin 552 | | | | | 156 | 23 (4.2) | 3 (0.5) | 10 (1.8)
SPAF I, Circulation, 1991 | | | | | | | | Placebo (a) 568 | | | | | 154 | 42 (7.4) | 4 (0.7) | 14 (2.5)
SPAF II, Lancet, 991 | 65 | 539 (75) | 43 (6.0) | 233 (33) | 122 (17) | 125 (17) | 378 (53) | Warfarin (I) ^4^ 358 | 5 | 75 | 20 | 368 | 13 (6.6) | 1 (0.5) | 6 (2.0) | | | Study with the longest followup time, should be generalizable given liberal enrollment criteria, mean age of patients, older than iin the other trials
SPAF II, Lancet, 991 | | | | | | | | Aspirin (I) 357 | | | | 364 | 19 (5.3) | 2 (0.6) | 2 (0.6) | | | Study with the longest followup time, should be generalizable given liberal enrollment criteria, mean age of patients, older than iin the other trials
SPAF II, Lancet, 991 | 80 | 225 (58) | 37 (96) | 90 (23) | 50 (13) | 98 (25) | 200 (52) | Warfarin (II) 197 | 6 | 72 | 22 | 240 | 13 (6.6) | 1 (0.5) | 7 (4.0) | | | Study with the longest followup time, should be generalizable given liberal enrollment criteria, mean age of patients, older than iin the other trials
SPAF II, Lancet, 991 | | | | | | | | Aspirin (II) 188 | | | | 240 | 18 (9.6) | 0 | 3 (2.0) | | | Study with the longest followup time, should be generalizable given liberal enrollment criteria, mean age of patients, older than iin the other trials
SPAF III, Lancet, 1996 | 71 | 629 (60) | 381 (3.7) | 167 (16) | 191 (18) | 234 (32) | 329 (32) | Aspirin, low dose Warfarin 521 | | | | 128 | 43 (8.4) | 1 (0.2) | 13 (2.5) | | | Patients with one of four factors considered to be at high risk for stroke
SPAF III, Lancet, 1996 | | | | | | | | Warfarin 523 | | | | 133 | 41 (2.1) | 0 | 12 (2.3) | | | Patients with one of four factors considered to be at high risk for stroke
BAATAF, N Engl J Med, 1990 | 69 | 304 (72) | 14 (3.3) | 70 (17) | 63 (15) | 109 (24) | 214 (51) | Warfarin 212 | 9 | 83 | 8 | 276 | 2 (0.9) | | 2 (0.9) | | | Lowest target INR of all of the studies, achieved target range most often of all of the studies
BAATAF, N Engl J Med, 1990 | | | | | | | | Placebo 208 | | | | 252 | 13 (6.3) | | 1 (0.5) | 21 (10) | 26 (13) | Lowest target INR of all of the studies, achieved target range most often of all of the studies
CAFA, JACC, 1994 | 67 | 282 (75) | 14 93.7) | 26 (6.9) | 45 (12) | 83 (22) | 146 (39) | Warfarin 187 | 17 | 44 | 40 | 15.2 | 6 (3.2) | 1 (0.5) | 5 (2.7) | 30 (16) | 10 (5.3) | INR measurements below target range a large percentage of the tiime, study was terminated early
CAFA, JACC, 1994 | | | | | | | | Placebo 191 | | | | 15.2 | 9 (4.7) | 2 (1.0) | 1 (0.5) | 18 (9.0) | 8 (4.2) | INR measurements below target range a large percentage of the tiime, study was terminated early
SPINAF, N Engl J Med, 1992 | 67 | 525 (100) | 0 | 0 | 97 (180) | 160 (30) | 305 (58) | Warfarin 260 | 15 | 56 | 29 | 246 | 4 (1.5) | 4 (1.5) | 7 (2.7) | 64 (25) | NR | Received the highest quality score of all of the studies, only males enrolled
SPINAF, N Engl J Med, 1992 | | | | | | | | Placebo 265 | | | | 204 | 19 (7.0) | 6 (2.3) | 4 (1.5) | 46 (17) | NR | Received the highest quality score of all of the studies, only males enrolled
AFASAK I, Lancet, 1989 | 74 | 540 (54) | 58 (5.8) | 0 | 84 (8.3) | 521 (52) | 323 (32) | Warfarin 335 | 6 | 71 | 26 | unknown ^5^ | 5 (1.5) | 0 | 1 (0.3) | 20 (6.0) | NR | Received the highest quality score of all of the studies, only males enrolled
AFASAK I, Lancet, 1989 | | | | | | | | Aspirin 336 | | | | unknown | 15 (4.5) | 3 (0.9) | 1 (0.3) | 1 (0.3) | NR | Unknown actual followup time but yearly incidence of stroke presented in paper
AFASAK I, Lancet, 1989 | | | | | | | | Placebo 336 | | | | unknown | 16 (4.8) | 2 (0.6) | 0 | 0 | NR | Unknown actual followup time but yearly incidence of stroke presented in paper
AFASAK II, Arch Intern Med, 1998 | 73 | 102 (60) | 14 (9) | 0 | 23 (13) | 120 (71) | 72 (42) | Warfarin 170 | 9 | 73 | 18 | 30 | 9 (5.3) | 2 (1.2) | 4 (2.3) | 42 (25) | 17 (10)
AFASAK II, Arch Intern Med, 1998 | | | | | | | | Aspirin 169 | | | | 30 | 8 (4.7) | 1 (0.6) | 5 (3.0) | 26 (15) | 14 (8.3)
AFASAK II, Arch Intern Med, 1998 | | | | | | | | Aspirin and low dose Warfarin 171 | | | | 31 | 11 (6.4) | 1 (0.6) | 1 (0.6) | 28 (16) | 9 (5.3)
AFASAK II, Arch Intern Med, 1998 | | | | | | | | Low dose Warfarin 167 | | | | 30 | 13 97.8) | 1 (0.6) | 3 (1.8) | 21 (13) | 6 (3.4)
EAFT, Lancet, 1993 | 71 | 248 (56) | 439 (100) | 110 (25) | 57 (13) | 39 (9) | 186 (42) | Warfarin 225 | 9 | 59 | 32 | 28 | 20 (8.9) | | 13 (5.8) | 47 (21) | 41 (18) | A secondary prevention study had warfarin-eligible andwarfarin-ineligible arms similar to SPAF I; aspirin vs. placebo compari¡sonconsists of patients from both warfarin-eligible and war¡farin-ineligiblearms
EAFT, Lancet, 1993 | | | | | | | | Placebo (w) 214 | | | | 28 | 50 (23) | | 3 (1.4) | 11 (5.1) | 44 (21)
EAFT, Lancet, 1993 | 71 | 438 (56) | 782 (100) | 192 (25) | 101 (13) | 89 (11) | 376 (48) | Aspirin 404 | | | | 28 | 88 (22) | | 6 (1.5) | | 6 (1.5)
EAFT, Lancet, 1993 | | | | | | | | Placebo (a) 378) | | | | 28 | 90 (24) | | 4 (1.0) | 21 (5.5) | 99 (26)
Morocutti, Stroke, 1997 | 73 | 434 (47) | 916 (100) | 251 (27) | 160 (17) | 302 (33) | 509 (56) | Warfarin 454 | 2 | 84 | 14 | unknown | 10 (2.2) | 5 (1.1) | 5 (1.1) | 19 (4.2) | 32 (70) | Only trial of a nonsteroidal anti-inflammatory agent
Morocutti, Stroke, 1997 | | | | | | | | Indobufen 462 | | | | unknown | 18 (4.0) | 8 (1.7) | 1 (0.2) | 3 (0.6) | 35 (7.6) | Only trial of a nonsteroidal anti-inflammatory agent
Harenberg, Semin Hem Throm, 1993 | 67 | 18 (24) | 21 (28) | 0 | 24 (32) | | | LMWH ^6^ | | | | 40 | 2 (5.7) | 1 (2.8) | | | | A secondary preventionstudy, smallest study, likely under¡powered
Harenberg, Semin Hem Throm, 1993 | | | | | | | | Placebo (40) | | | | 47 | 6 (15) | 2 (5.0) | | | | A secondary preventionstudy, smallest study, likely under¡powered

1 TIA = transient ischemic attack; Parox = paroxysmal atrial fibrillation; DM = diabetes mellitus; CHF = congestive heart failure; HTN = hypertension

2 Above target range = percentage of INR measurements above the target range; in target range = percentage of INR measurements with target range; below target range = percentage of INR measurements below the target range

(W) = control group for the warfarin-treated patients; (a) control group for the aspirin-treated patients

4 Study involves two parallel trials; group I patients are < 75 yrs; group II patients are > 75 years

5 Actual time of followup is unknown; planned followup of 24 months

6 LMWH = low molecular weight heparin