# Bibliography

Abdalla A, Mazur NA, Iavorskaia NV, Sitina VK. The efficacy of combinations of anti-arrhythmia preparations in patients with the paroxysmal form of atrial fibrillation. Ter Arkh. 1992;64(4):51-5.
Aberg H. Procaine amide as a prophylactic drug against atrial fibrillation. A controlled study. Nord Med. 1969 Aug 14;82(33):1011-3. [pmid: 5808590].
Aberg H, Cullhed I. Procaine amide quinidine as prophylactic drugs against relapse of atrial fibrillation. Nord Med. 1968 Jun 13;79(24):781-2.
[No authors listed]. Adjusted-dose warfarin versus low-intensity, fixed-dose warfarin plus aspirin for high-risk patients with atrial fibrillation: Stroke Prevention in Atrial Fibrillation III randomised clinical trial. Lancet. 1996 Sep 7;348(9028):633-8.
Aguirre FV, McMahon RP, Mueller H, Kleiman NS, Kern MJ, Desvigne Nickens P, Hamilton WP, Chaitman BR. Impact of age on clinical outcome and postlytic management strategies in patients treated with intravenous thrombolytic therapy. Results from the TIMI II Study. TIMI II Investigators. Circulation. 1994 Jul;90(1):78-86.
Ahuja RC, Sinha N, Saran RK, Jain AK, Hasan M. Digoxin or verapamil or metoprolol for heart rate control in patients with mitral stenosis-a randomised cross-over study. Int J Cardiol. 1989 Dec;25(3):325-31.
Al Khadra AS, Salem DN, Rand WM, Udelson JE, Smith JJ, Konstam MA. Warfarin anticoagulation and survival: a cohort analysis from the Studies of Left Ventricular Dysfunction. J Am Coll Cardiol. 1998 Mar 15;31(4):749-53.
Al Rajeh S, Awada A, Naufal R, Amene P, Larbi E, Obeid T. Angiographic patterns of carotid ischemic cerebrovascular disease in Saudi Arabia. J Neurol. 1995 Dec;134(1-2):167-70.
Alboni P, Menozzi C, Brignole M, Paparella N, Gaggioli G, Lolli G, Cappato R. Effects of permanent pacemaker and oral theophylline in sick sinus syndrome the THEOPACE study: a randomized controlled trial. Circulation. 1997 Jul;96(1):260-6.
Ali IM, Sanalla AA, Clark V. Beta-blocker effects on postoperative atrial fibrillation. Eur J Cardiothorac Surg. 1997 Jun;11(1):1154-7.
Aliot E, Denjoy I. Comparison of the safety and efficacy of flecainide versus propafenone in hospital out-patients with symptomatic paroxysmal atrial fibrillation/flutter. The Flecainide AF French Study Group. Am J Cardiol. 1996 Jan 25;77(3):66A-71A.
Alt E, Schmitt C, Ammer R, Plewan A, Evans F, Pasquantonio J, Ideker T, Lehmann G, Putter K, Schomig A. Effect of electrode position on outcome of low-energy intracardiac cardioversion of atrial fibrillation. Am J Cardiol. 1997 Mar 1;79(5):621-5.
Amabile G, Matteoli S, Fattapposta F, Lavezzari M, Trappolini M, Heiman F, Morocutti C. Italian Study on Atrial Fibrillation (SIFA): status report. Cardiologia. 1993 Dec;38(12 Suppl 1):327-32.
Amar D, Roistacher N, Burt ME, Rusch VW, Bains MS, Leung DH, Downey RJ, Ginsberg RJ. Effects of diltiazem versus digoxin on dysrhythmias and cardiac function after pneumonectomy. Ann Thorac Surg. 1997 May;63(5):1374-81.
Ammer R, Alt E, Ayers G, Lehmann G, Schmitt C, Pasquantonio J, Schmidt M, Schomig A, Putter K. Pain threshold for low energy intracardiac cardioversion of atrial fibrillation with low or no sedation. Pacing Clin Electrophysiol. 1997 Jan;20(1 Pt 2):230-6.
Andersen HR, Thuesen L, Bagger JP, Vesterlund T, Thomsen PE. Prospective randomised trial of atrial versus ventricular pacing in sick-sinus syndrome [see comments]. Lancet. 1994 Dec 3;344(8936):1523-8.
Andersen HR, Thuesen L, Bagger JP, Vesterlund T, Thomsen PE. Sick sinus syndrome. Pacemaker with atrial versus ventricular stimulation. Ugeskr Laeger. 1996 Feb 19;158(8):1062-7.
Anderson CS, Jamrozik KD, Broadhurst RJ, Stewart Wynne EG. Predicting survival for 1 year among different subtypes of stroke. Results from the Perth Community Stroke Study [see comments]. Stroke. 1994 Oct;25(10):1935-44.
Anderson DC. Progress report of the Stroke Prevention in Atrial Fibrillation Study. Stroke. 1990 Nov;21(Suppl 11):III12-7. [pmid: 2237968].
Anderson JL, Gilbert EM, Alpert BL, Henthorn RW, Waldo AL, Bhandari AK, Hawkinson RW, Pritchett EL. Prevention of symptomatic recurrences of paroxysmal atrial fibrillation in patients initially tolerating antiarrhythmic therapy. A multi center, double-blind, crossover study of flecainide and placebo with transtelephonic monitoring. Flecainide Supraventricular Tachycardia Study Group. Circulation. 1989 Dec;80(6):1557-70.
Andren L, Hoglund P, Dotevall A, Eggertsen R, Svensson A, Olson SO, Wadenvik H. Diltiazem in hypertensive patients with type II diabetes mellitus. Am J Cardiol. 1988 Oct 5;62(11):114G-120G.
Andrivet P, Boubakri E, Dove PJ, Mach V, Vu Ngoc C. A clinical study of amiodarone as a single oral dose in patients with recent-onset atrial tachyarrhythmia [see comments]. Eur Heart J. 1994 Oct;15(10):1396-402.
Ang EL, Chan WL, Cleland JG, Moore D, Krikler SJ, Alexander ND, Oakley CM. Placebo controlled trial of xamoterol versus digoxin in chronic atrial fibrillation. Br Heart J. 1990 Oct;64(4):256-60.
Aomi S, Hashimoto A, Tagusari O, Nishida H, Nomura M, Kondoh I, Kodaka K, Koyanagi H. A new supportive method of aortic aneurysm surgery: centrifugal left heart bypass combined with an oxygenator and a heat exchanger. Artif Organs. 1996 Jun;20(6):700-3.
Aronow WS, Ahn C, Kronzon I. Effect of propranolol versus no propranolol on total mortality plus nonfatal myocardial infarction in older patients with prior myocardial infarction, congestive heart failure, and left ventricular ejection fraction > or = 40% treated with diuretics plus angiotensin-converting enzyme inhibitors. Am J Cardiol. 1997 Jul 15;80(2):207-9.
Ashraf T, Hay JW, Pitt B, Wittels E, Crouse J, Davidson M, Furbert CD, Radican L. Cost-effectiveness of pravastatin in secondary prevention of coronary heart disease. Am J Cardiol. 1996 Aug 15;78(4):409-14.
Asimakopoulos G, Della Santa R, Taggart DP. Effects of posterior pericardiotomy on the incidence of atrial fibrillation and chest drainage after coronary revascularization: a prospective randomized trial. J Thorac Cardiovasc Surg. 1997 Apr;113(4):797-9.
Assessment of Cardioversion Using Transesophageal Echocardiography. Design of a clinical trial for the Assessment of Cardioversion Using Transesophageal Echocardiography (The ACUTE Multicenter Study). The Steering and Publications Committees of the ACUTE Study, for the ACUTE Investigators. Am J Cardiol. 1998 Apr 1;81(7):877-83.
Atarashi H, Inoue H, Hiejima K, Hayakawa H. Conversion of recent-onset atrial fibrillation by a single oral dose of pilsicainide (Pilsicainide Suppression Trial on Atrial Fibrillation). The PSTAF Investigators. Am J Cardiol. 1996 Sep 15;78(6):694-7.
Atrial Fibrillation Follow-up Investigation of Rhythm Management-the AFFIRM study design. The Planning and Steering Committees of the AFFIRM study for the NHLBI AFFIRM investigators. Am J Cardiol. 1997 May 1;79(9):1198-202.
The Atrial Fibrillation Investigation with Bidisomide (AFIB) Investigators. Treatment of atrial fibrillation and paroxysmal supraventricular tachycardia with bidisomide. Circulation. 1997 Oct 21;96(8):2625-32.
Atrial Fibrillation Investigators. Risk factors for stroke and efficacy of antithrombotic therapy in atrial fibrillation. Analysis of pooled data from five randomized controlled trials. Arch Intern Med. 1994 Jul 11;154(13):1449-57.
Atrial Fibrillation Investigators. Echocardiographic predictors of stroke in patients with atrial fibrillation. A prospective study of 1066 patients from 3 clinical trials. Arch Intern Med. 1998 June 22;158(12):1316-20.
Atwood JE, Sullivan M, Forbes S, Myers J, Pewen W, Olson HG, Froelicher VF. Effect of beta-adrenergic blockade on exercise performance in patients with chronic atrial fibrillation. J Am Coll Cardiol. 1987 Aug;10(2):314-20.
Auricchio A. Reversible protective effect of propafenone or flecainide during atrial fibrillation in patients with an accessory atrioventricular connection. Am Heart J. 1992 Oct;124(4):932-7. [pmid: 1529904].
Azpitarte J, Alvarez M, Baun O, Garcia R, Moreno E, Martin F, Tercedor L, Fernandez R. Value of single oral loading dose of propafenone in converting recent-onset atrial fibrillation. Results of a randomized, double-blind, controlled study. Eur Heart J. 1997 Oct;18(10):1649-54.
Babuty D, D'Hautefeuille B, Scheck F, Mycinsky C, Pruvost P, Peraudeau P. Cibenzoline versus flecainide in the prevention of paroxysmal atrial arrhythmias: a double-blind randomized study. J Clin Pharmacol. 1995 May;35(5):471-7.
Baldi N, Russo VA, Lenti V, Marasco G, Polimeni G, Conserva R, Tripaldi R, Montervino C. Relation between plasma levels and efficacy of flecainide and propafenone for treatment of atrial fibrillation of recent onset. New Trends Arrhythmias. 1993;9(2-4):899-906.
Banasiak W, Kokot K, Pierog M, Fuglewicz A, Zapalowicz R, Lacheta W, Molenda W, Goral J, Telichowski A, Telichowski C. Correlations between left atrial size and parameters of averaged atrial signal in patients with paroxysmal atrial fibrillation in the course of ischemic heart diseases. Pol Merkuriusz Lek. 1996 Aug;1(2):95-8.
Banasiak W, Kokot K, Telichowski C, Pierog M, Lacheta W, Fuglewicz A, Wiech K, Zapalowicz R. The effect of paroxysmal atrial fibrillation during ischemic heart disease on parameters of atrial signal-averaged electrocardiography. Pol Merkuriusz Lek. 1996 Aug;1(2):91-4.
Baroffio R, Tisi G, Guzzini F, Milvio E, Annoni P. A randomised study comparing digoxin and propafenone in the treatment of recent onset atrial fibrillation. Clin Drug Invest. 1995;9(5):277-83.
Barranco F, Sanchez M, Rodriguez J, Guerrero M. Efficacy of flecainide in patients with supraventricular arrhythmias and respiratory insufficiency. Intensive Care Med. 1994;20(1):42-4. [pmid: 8163757].
Beasley R, Smith DA, McHaffie DJ. Exercise heart rates at different serum digoxin concentrations in patients with atrial fibrillation. Br Med J (Clin Res Ed). 1985 Jan 5;290(6461):9-11.
Bechler Lisinska J, Cholewa M, Gorski L, Markiewicz K. Effect of vasodilator agents on the character and incidence of cardiac arrhythmia in chronic heart failure. [German]. Z Gesamte Inn Med. 1990 Mar 1;45(3):71-6.
Bechtold H, Kleist P, Landgraf K, Moser K. Effect of low-dosage intravenous nitrate therapy on the anticoagulant effect of heparin. Med Klin. 1994 Mar 1;89(7):360-6.
Beck OA, Gunther R, Hochrein H. Conversion of chronic atrial fibrillation or flutter with disopyramide and a verapamil-quinidine combination: a comparative study. Dtsch Med Wochenschr. 1982 Sep 24;107(38):1419-23.
Beck OA, Lehmann HU, Hochrein H. Propafenon and lidoflazine in chronic atrial fibrillation and flutter [author's transl]. [German]. Dtsch Med Wochenschr. 1978 Jan 30;103(26):1068-72.
Beevers DG. Ultra low dose anticoagulation in atrial fibrillation. The National Research Register [online database]. United Kingdom: Update Software Ltd.; 1997.
Behar S, Goldbourt U, Reicher Reiss H, Kaplinsky E. Prognosis of acute myocardial infarction complicated by primary ventricular fibrillation. Principal Investigators of the SPRINT Study. Am J Cardiol. 1990 Nov 15;66(17):1208-11.
Bellandi F, Cantini F, Pedone T, Palchetti R, Bamoshmoosh M, Dabizzi RP. Effectiveness of intravenous propafenone for conversion of recent-onset atrial fibrillation: a placebo-controlled study. Clin Cardiol. 1995 Nov;18(11):631-4.
Bellandi F, Dabizzi RP, Cantini F, Natale MD, Niccoli L. Intravenous propafenone: efficacy and safety in the conversion to sinus rhythm of recent onset atrial fibrillation-a single-blind placebo- controlled study. Cardiovasc Drugs Ther. 1996 May;10(2):153-7.
Bellandi F, Dabizzi RP, Niccoli L, Cantini F. Propafenone and sotalol in the prevention of paroxysmal atrial fibrillation: long-term safety and efficacy study. Curr Ther Res. 1995 Nov;56(11):1154-68.
Bellandi F, Dabizzi RP, Niccoli L, Cantini F. Propafenone and sotalol in the prevention of paroxysmal atrial fibrillation: long-term safety and efficacy study. Munch Med Wochenschr. 1996;138:39-46.
Bellandi F, Dabizzi RP, Niccoli L, Cantini F, Palchetti R. Propafenone and sotalol: long-term efficacy and tolerability in the prevention of paroxysmal atrial fibrillation. A placebo-controlled double-blind study. G Ital Cardiol. 1996 Apr;26(4):379-90.
Bengtsson BA, Eden S, Lonn L, Kvist H, Stokland A, Lindstedt G, Bosaeus I, Tolli J, Sjostrom L, Isaksson OG. Treatment of adults with growth hormone (GH) deficiency with recombinant human GH. J Clin Endocrinol Metab. 1993 Feb;76(2):309-17.
Berlin JA. Randomized trial comparing masked/unmasked meta-analyses. University of Pennsylvania. November 30, 1996. National Technical Information Service accession number PB98-109382.0.
Bertini G, Conti A, Fradella G, Francardelli L, Giglioli C, Mangialavori G, Margheri M, Moschi G. Propafenone versus amiodarone in field treatment of primary atrial tachydysrhythmias. J Emerg Med. 1990 Jan-Feb;8(1):15-20.
Besson G, Bogousslavsky J. European Atrial Fibrillation Trial (EAFT). Secondary prevention with anticoagulants and aspirin in patients with non-valvular atrial fibrillation having suffered a transient ischemic attack or a regressive vascular accident. Rev Med Suisse Romande. 1991 Jan;111(1):49-55.
Bethge KP, Godt U, Blanco Cruz E, Lichtlen PR. Incidence of cardiac arrhythmias during antidepressant therapy with maprotiline or nomifensine. J Cardiovasc Pharmacol. 1982 Jan-Feb;4(1):142-8.
Bialy D, Lehmann MH, Schumacher DN, Steinman RT, Meissner MD. Hospitalization for arrhythmias in the United States: importance of atrial fibrillation [abstract]. J Am Coll Cardiol. 1992 March 1;19(3).
Bianconi L, Mennuni M, Lukic V, Castro A, Chieffi M, Santini M. Effects of oral propafenone administration before electrical cardioversion of chronic atrial fibrillation: a placebo-controlled study. J Am Coll Cardiol. 1996 Sept;28(3):700-6.
Bianconi L, Mennuni M, Lukic V, Tassoni G, Santini M. Pretreatment with oral propafenone in electrical cardioversion of chronic atrial fibrillation. New Trends Arrhythmias. 1993;9(2-4):1017-20.
Bigger JT Jr, Schmidt DH, Kutt H. Relationship between the plasma level of diphenylhydantoin sodium and its cardiac antiarrhythmic effects. Circulation. 1968 Aug;38(2):363-74.
Bjerkelund C, Orning OM. Kinidin-duetter and quinidine sulphate in the prevention of atrial fibrillation. A comparison. Nord Med. 1967 Mar 30;77(13):405-7.
Blackshear JL. Relative risk of atrial thrombus one month after randomization to therapy is similar to thromboembolic outcome after 1.1 years in nonrheumatic fibrillation. Cerebrovasc Dis. 1997;7.
Blackshear JL, Baker VS, Holland A, Litin SC, Ahlquist DA, Hart RG, Ellefson R, Koehler J. Fecal hemoglobin excretion in elderly patients with atrial fibrillation: combined aspirin and low-dose warfarin vs conventional warfarin therapy. Arch Intern Med. 1996 Mar 25;156(6):658-60.
Blair KL, Hatton AC, White WD, Smith LR, Lowe JE, Wolfe WG, Young WG, Oldham HN, Douglas JM Jr, Glower DD. Comparison of anticoagulation regimens after Carpentier-Edwards aortic or mitral valve replacement. Circulation. 1994 Nov;90(5 Pt 2):II214-9.
Bloch TPE, Andersen HR. The first prospective randomised trial of atrial versus ventricular pacing in sick sinus syndrome-at last. Eur J Card Pacing Electrophysiol. 1995;5:124-5.
Boahene KA, Klein GJ, Yee R, Sharma AD, Fujimura O. Termination of acute atrial fibrillation in the Wolff-Parkinson-White syndrome by procainamide and propafenone: importance of atrial fibrillatory cycle length [see comments]. J Am Coll Cardiol. 1990 Nov;16(6):1408-14.
Bohr T. Warfarin and stroke [letter; comment]. West J Med. 1989 Dec;151(6).
Boman K. Digoxin and the geriatric in-patient. A randomized trial of digoxin versus placebo. Acta Med Scand. 1983;214(5):353-60. [pmid: 6362340].
Borgeat A, Goy JJ, Maendly R, Kaufmann U, Grbic M, Sigwart U. Flecainide versus quinidine for conversion of atrial fibrillation to sinus rhythm. Am J Cardiol. 1986 Sep 1;58(6):496-8.
Borgeat A, Petropoulos P, Cavin R, Biollaz J, Munafo A, Schwander D. Prevention of arrhythmias after noncardiac thoracic operations: flecainide versus digoxin. Ann Thorac Surg. 1991 June;51(6):964-7.
Boriani G, Biff M, Capucci A, Botto GL, Broffoni T, Rubino I, Della-Casa S, Sanguinetti M, Magnani B. Oral propafenone to convert recent-onset atrial fibrillation in patients with and without underlying heart disease. A randomized, controlled trial. Ann Intern Med. 1997 Apr 15;126(8):621-5.
Boriani G, Capucci A, Lenzi T, Sanguinetti M, Magnani B. Propafenone for conversion of recent-onset atrial fibrillation. A controlled comparison between oral loading dose and intravenous administration. Chest. 1995 Aug;108(2):355-8.
The Boston Area Anticoagulation Trial for Atrial Fibrillation Investigators [see comments]. The effect of low-dose warfarin on the risk of stroke in patients with nonrheumatic atrial fibrillation. N Engl J Med. 1990 Nov 29;323(22):1505-11.
Botto GL, Bonini W, Broffoni T, Cappelletti G, Falcone C, Lombardi R, Paulesu A, Pedraglio E, Ferrari G. Regular ventricular rhythms before conversion of recent onset atrial fibrillation to sinus rhythm. Pacing Clin Electrophysiol. 1994 Nov;17(11 Pt 2):2114-7.
Botto GL, Bonini W, Broffoni T, Molteni S, Lombardi R, Alfieri G, Barone P, Bernasconi G, Ferrari G. Conversion of recent onset atrial fibrillation with single loading oral dose of propafenone: is in-hospital admission absolutely necessary?. Pacing Clin Electrophysiol. 1996 Nov;19(11 Pt 2):1939-43.
Botto GL, Capucci A, Bonini W, Boriani G, Broffoni T, Barone P, Espureo M, Lombardi R, Molteni S, Ferrari G. Conversion of recent onset atrial fibrillation to sinus rhythm using a single oral loading dose of propafenone: comparison of two regimens. Int J Cardiol. 1997 Jan 3;58(1):55-61.
Bouchart F, Bessou JP, Tabley A, Hecketsweiller B, Mouton-Schleifer D, Redonnet M, Arrignon J, Soyer R. How to protect hypertrophied myocardium? A prospective clinical trial of three preservation techniques. Int J Artif Organs. 1997 Aug;20(8):440-6.
Boudonas G, Lefkos N, Efthymiadis AP, Styliadis IG, Tsapas G. Intravenous administration of diltiazem in the treatment of supraventricular tachyarrhythmias. Acta Cardiol. 1995;50(2):125-34. [pmid: 7610735].
Bowen J, Yaste C. Effect of a stroke protocol on hospital costs of stroke patients. Neurology. 1994 Oct;44(10):1961-4. [pmcid: 153508].
Boyle M, Jacobs S, Torda TA, Shehabi Y. Assessment of the agreement between cardiac output measured by bolus thermodilution and continuous methods, with particular reference to the effect of heart rhythm. Aust Crit Care. 1997 Mar;10(1):5-8,10-1.
Boysen G, Petersen P, Godtfredsen J, Andersen ED, Andersen B. Warfarin prevents thromboembolic complications in chronic nonrheumatic atrial fibrillation. Proceedings of the 5th Scandinavian Meeting on Cerebrovascular Disease 1989:21.
Boysen G, Petersen P, Godtfredsen J, Andersen ED, Andersen B. Effect of warfarin contra aspirin and placebo in chronic atrial fibrillation. Stroke. 1990;21:I-92.
Brand FN, Abbott RD, Kannel WB, Wolf PA. Characteristics and prognosis of lone atrial fibrillation: 30-year follow-up in the Framingham Study. JAMA. 1985 Dec 27;254(24):3449-53.
Brignole M, Gianfranchi L, Menozzi C, Alboni P, Musso G, Bongiorni MG, Gasparini M, Raviele A, Lolli G, Paparella N, Acquarone S. Assessment of atrioventricular junction ablation and DDDR mode-switching pacemaker versus pharmacological treatment in patients with severely symptomatic paroxysmal atrial fibrillation: a randomized controlled study. Circulation. 1997 Oct 21;96(8):2617-24.
Brignole M, Gianfranchi L, Menozzi C, Bottoni N, Bollini R, Lolli G, Oddone D, Gaggioli G. Influence of atrioventricular junction radiofrequency ablation in patients with chronic atrial fibrillation and flutter on quality of life and cardiac performance. Am J Cardiol. 1994 Aug 1;74(3):242-6.
Brodsky MA, Orlov MV, Capparelli EV, Allen BJ, Iseri LT, Ginkel M, Orlov YS. Magnesium therapy in new-onset atrial fibrillation. Am J Cardiol. 1994 June 15;73(16):1227-9.
Brodsky M, Saini R, Bellinger R, Zoble R, Weiss R, Powers L. Comparative effects of the combination of digoxin and dl-sotalol therapy versus digoxin monotherapy for control of ventricular response in chronic atrial fibrillation. dl-Sotalol Atrial Fibrillation Study Group. Am Heart J. 1994 Mar;127(3):572-7.
Buckingham TA, Woodruff RC, Pennington DG, Redd RM, Janosik DL, Labovitz AJ, Graves R, Kennedy HL. Effect of ventricular function on the exercise hemodynamics of variable rate pacing. J Am Coll Cardiol. 1988 Jun;11(6):1269-77.
Buoncuore A, Poirier JM, Jaillon P, Ferry A, Pochmalicki G, Colombel B, Vrancea F, Cheymol G, Valty J. Pharmacokinetics of oral propafenone in patients with supraventricular arrhythmia. Therapie. 1989 Mar-Apr;44(2):79-85.
Butler J, Harriss DR, Sinclair M, Westaby S. Amiodarone prophylaxis for tachycardias after coronary artery surgery: a randomised, double blind, placebo controlled trial. Br Heart J. 1993 Jul;70(1):56-60.
Byington R, Goldstein S. Association of digitalis therapy with mortality in survivors of acute myocardial infarction: observations in the Beta-Blocker Heart Attack Trial. J Am Coll Cardiol. 1985 Nov;6(5):976-82.
Byrne-Quinn E, Wing AJ. Maintenance of sinus rhythm after DC reversion of atrial fibrillation. A double-blind controlled trial of long-acting quinidine bisulphate. Br Heart J. 1970 May;32(3):370-6.
Cacciapuoti F, Perrone N, Diaspro R, Galzerano D, Gentile S, Lapiello B. Slowing of mitral valve annular calcium in systemic hypertension by nifedipine and comparisons with enalapril and atenolol. Am J Cardiol. 1993 Nov 1;72(14):1038-42.
Caidahl K, Eden S, Bengtsson BA. Cardiovascular and renal effects of growth hormone. Clin Endocrinol (Oxf). 1994 Mar;40(3):393-400. [pmcid: 298219].
Camm AJ, Bashir Y. Clinical trials of flecainide acetate in the management of supraventricular arrhythmias [editorial]. Cardiologia. 1990 Mar;35(3):193-7.
Camm AJ, Katritsis D, Nunain SO. Effects of flecainide on atrial electrophysiology in the Wolff-Parkinson-White syndrome. Am J Cardiol. 1992 Aug 20;70(5):33A-37A.
Campbell TJ, Gavaghan TP, Morgan JJ. Intravenous sotalol for the treatment of atrial fibrillation and flutter after cardiopulmonary bypass. Comparison with disopyramide and digoxin in a randomised trial. Br Heart J. 1985 Jul;54(1):86-90.
Canessa R, Lema G, Urzua J, Dagnino J, Concha M. Anesthesia for elective cardioversion: a comparison of four anesthetic agents. J Cardiothorac Vasc Anesth. 1991 Dec;5(6):566-8.
The Captopril Prevention Project: a prospective intervention trial of angiotensin converting enzyme inhibition in the treatment of hypertension. The CAPPP Group. J Hypertens. 1990 Nov;8(11):985-90.
Capucci A, Boriani G, Rubino I, Della Casa S, Sanguinetti M, Magnani B. A controlled study on oral propafenone versus digoxin plus quinidine in converting recent onset atrial fibrillation to sinus rhythm. Int J Cardiol. 1994 Mar 1;43(3):305-13.
Capucci A, Lenzi T, Boriani G, Trisolino G, Binetti N, Cavazza M, Fontana G, Magnani B. Effectiveness of loading oral flecainide for converting recent-onset atrial fibrillation to sinus rhythm in patients without organic heart disease or with only systemic hypertension [see comments]. Am J Cardiol. 1992 July 1;70(1):69-72.
The Cardiac Arrhythmia Suppression Trial (CAST) Investigators. Preliminary report: effect of encainide and flecainide on mortality in a randomized trial of arrhythmia suppression after myocardial infarction. N Engl J Med. 1989 Aug 10;321(6):406-12.
Cardinale V, ed. Drug Topics Red Book. Oradell, NJ: Medical Economics; 1997.
Caro JJ, Groome PA, Flegel KM. Atrial fibrillation and anticoagulation: from randomised trials to practice. Lancet. 1993 May 29;341(8857):1381-4.
Carson PE, Johnson GR, Dunkman WB, Fletcher RD, Farrell L, Cohn JN. The influence of atrial fibrillation on prognosis in mild to moderate heart failure. The V-HeFT Studies. The V-HeFT VA Cooperative Studies Group. Circulation. 1993 Jun;87(6 Suppl):VI102-10.
Carunchio A, Fera MS, Mazza A, Burattini M, Greco G, Galati A, Ceci V. A comparison between flecainide and sotalol in the prevention of recurrences of paroxysmal atrial fibrillation. G Ital Cardiol. 1995 Jan;25(1):51-68.
César LA, Serrano CV, Pamplona D, D'Avila AL, Ferreira JF, Amato RV, Pfeferman E, Scanavacca M, Sosa EA, Bellotti G. Acute atrial fibrillation in the emergency room. Which is the best drug for a rapid sinus rhythm conversion?. Arq Bras Cardiol. 1994 Dec;63(6):481-4.
Chang AY, Kim K, Glick J, Anderson T, Karp D, Johnson D. Phase II study of taxol merbarone and piroxantrone in stage IV non-small-cell lung cancer: the Eastern Cooperative Oncology Group Results [see comments]. J Natl Cancer Inst. 1993 Mar 3;85(5):388-94.
Channer KS, James MA, MacConnell T, Rees JR. Beta-adrenoceptor blockers in atrial fibrillation: the importance of partial agonist activity [see comments]. Br J Clin Pharmacol. 1994 Jan;37(1):53-7.
Channer KS, Papouchado M, James MA, Pitcher DW, Rees JR. Towards improved control of atrial fibrillation. Eur Heart J. 1987 Feb;8(2):141-7.
Chen SA, Chiang CE, Wu TJ, Tai CT, Lee SH, Cheng CC, Chiou CW, Ueng KC, Wen ZC, Chang MS. Radiofrequency catheter ablation of common atrial flutter: comparison of electrophysiologically guided focal ablation technique and linear ablation technique. J Am Coll Cardiol. 1996 Mar 15;27(4):860-8.
Chen X, Borggrefe M, Martinez Rubio A, Hief C, Haverkamp W, Hindricks G, Breithardt G. Efficacy of ajmaline and propafenone in patients with accessory pathways: a prospective randomized study. J Cardiovasc Pharmacol. 1994 Oct;24(4):664-9.
Chesebro JH, Wiebers DO, Holland AE, Bardsley WT, Litin SC, Meissner I, Zerbe DM, Flaker GC, Webel R, Nolte B, Stevenson P, Byer J, Wright W, Anderson DC, Asinger RW, Newburg SM, Bundlie SR, Farmer CC, McBride R, et al. Bleeding during antithrombotic therapy in patients with atrial fibrillation. Arch Intern Med. 1996;156(4):409-16. [pmid: 8607726].
Chimienti M, Cullen MT Jr, Casadei G. Safety of flecainide versus propafenone for the long-term management of symptomatic paroxysmal supraventricular tachyarrhythmias. Report from the Flecainide and Propafenone Italian Study (FAPIS) Group. Eur Heart J. 1995 Dec;16(12):1943-51.
Chimienti M, Cullen MT Jr, Casadei G. Safety of long-term flecainide and propafenone in the management of patients with symptomatic paroxysmal atrial fibrillation: report from the Flecainide and Propafenone Italian Study Investigators. Am J Cardiol. 1996 Jan;77(3):60A-75A.
Chiquette E, Amato MG, Bussey HI. Comparison of an anticoagulation clinic with usual medical care: anticoagulation control, patient outcomes, and health care costs. Arch Intern Med. 1998 Aug 10-24;158(15):1641-7.
Chung MK, Schweikert RA, Wilkoff BL, Niebauer MJ, Pinski SL, Trohman RG, Kidwell GA, Jaeger FJ, Morant VA, Miller DP, Tchou PJ. Is hospital admission for initiation of antiarrhythmic therapy with sotalol for atrial arrhythmias required? Yield of in-hospital monitoring and predicting of risk for significant arrhythmia complications. J Am Coll Cardiol. 1998 Jul;32(1):169-76.
Cobbe SM. Using the right drug. A treatment algorithm for AF. Eur Heart J. 1997 May;18(Suppl C):C33-9. [pmid: 9152673].
Cochrane AD, Siddins M, Rosenfeldt FL, Salamonsen R, McConaghy L, Marasco S, Davis BB. A comparison of amiodarone and digoxin for treatment of supraventricular arrhythmias after cardiac surgery. Eur J Cardiothorac Surg. 1994;8(4):194-8. [pmid: 8031562].
Cochrane DJ, McEneaney DJ, Anderson JM, Adgey AA. Transoesophageal versus transchest DC cardioversion. Q J Med. 1993 Aug;86(8):507-11.
Cohen A, Weber H, Chauvel C, Monin JL, Dib JC, Diebold B, Gueret P. Comparison of arbutamine and exercise echocardiography in diagnosing myocardial ischemia. Am J Cardiol. 1997 Mar 15;79(6):713-6.
Connolly S. How to evaluate antiarrhythmic agents in an essentially asymptomatic population. Can J Cardiol. 1994 Apr;10(3).
Connolly SJ, Hoffert DL. Usefulness of propafenone for recurrent paroxysmal atrial fibrillation. Am J Cardiol. 1989 Apr 1;63(2):817-9.
Connolly SJ, Laupacis A, Gent M, Roberts RS, Cairns JA, Joyner C. Canadian Atrial Fibrillation Anticoagulation (CAFA) Study. J Am Coll Cardiol. 1991 Aug;18(2):349-55.
Connolly SJ, Mulji AS, Hoffert DL, Davis C, Shragge BW. Randomized placebo-controlled trial of propafenone for treatment of atrial tachyarrhythmias after cardiac surgery. J Am Coll Cardiol. 1987 Nov;10(5):1145-8.
Coplen SE, Antman EM, Berlin JA, Hewitt P, Chalmers TC. Efficacy and safety of quinidine therapy for maintenance of sinus rhythm after cardioversion. A meta-analysis of randomized control trials [see comments]. Circulation. 1990 Oct;82(4):1106-16.
Cowan JC, Gardiner P, Reid DS, Newell DJ, Campbell RW. A comparison of amiodarone and digoxin in the treatment of atrial fibrillation complicating suspected acute myocardial infarction. J Cardiovasc Pharmacol. 1986 Mar-Apr;8(2):252-6.
Cramer G. Arrhythmia. 8. Quinidine for the maintenance of the sinus rhythm after regularization. Lakartidningen. 1971 Jan 14;68(Suppl II).
Crenshaw BS, Ward SR, Granger CB, Stebbins AL, Topol EJ, Califf RM. Atrial fibrillation in the setting of acute myocardial infarction: the GUSTO-I experience. Global Utilization of Streptokinase and TPA for Occluded Coronary Arteries. J Am Coll Cardiol. 1997 Aug;30(2):406-13.
Crijns HJ, Gosselink AT, Lie KI. Propafenone versus disopyramide for maintenance of sinus rhythm after electrical cardioversion of chronic atrial fibrillation: a randomized, double-blind study. PRODIS Study Group. Cardiovasc Drugs Ther. 1996 May;10(2):145-52.
Crijns HJ, Van Gelder IC, Kingma JH, Dunselman PH, Gosselink AT, Lie KI. Atrial flutter can be terminated by a class III antiarrhythmic drug but not by a class IC drug. Eur Heart J. 1994 Oct;15(10):1403-8.
Crijns HJ, van Wijk LM, van Gilst WH, Kingma JH, van Gelder IC, Lie KI. Acute conversion of atrial fibrillation to sinus rhythm: clinical efficacy of flecainide acetate. Comparison of two regimens. Eur Heart J. 1988 Jun;9(6):634-8.
Cutler N, Sramek J, Anand R. Safety and tolerance of ENA 713 in Alzheimer's disease (AD). 8th ECNP (European College of Neuropsychopharmacology) Congress, Venice, Italy, 1995.
Dahlstrom CG, Edvardsson N, Nasheng C, Olsson SB. Effects of diltiazem, propranolol, and their combination in the control of atrial fibrillation. Clin Cardiol. 1992 Apr;15(4):280-4.
Dailey SM, Bubien RS, Kay GN. Effect of chronotropic response pattern on oxygen kinetics. Pacing Clin Electrophysiol. 1994 Dec;17(12 Pt 1):2307-14.
Daoud EG, Strickberger SA, Man KC, Goyal R, Deeb GM, Bolling SF, Pagani FD, Bitar C, Meissner MD, Morady F. Preoperative amiodarone as prophylaxis against atrial fibrillation after heart surgery. N Engl J Med. 1997 Dec 18;337(25):1785-91.
Dattilo GL, Eiriksson CE Jr, Vestal RE. Increased ventricular response rate during exercise in patients with atrial fibrillation treated with theophylline. Arch Intern Med. 1992 Apr;152(4):797-803.
Daudon P, Corcos T, Gandjbakhch I, Levasseur JP, Cabrol A, Cabrol C. Prevention of atrial fibrillation or flutter by acebutolol after coronary bypass grafting. Am J Cardiol. 1986 Nov 1;58(10):933-6.
Davison R, Hartz R, Kaplan K, Parker M, Feiereisel P, Michaelis L. Prophylaxis of supraventricular tachyarrhythmia after coronary bypass surgery with oral verapamil: a randomized double-blind trial. Ann Thorac Surg. 1985 Apr;39(4):336-9.
Dawson J, Cockel R. Oesophageal perforation at fibreoptic gastroscopy. Br Med J. 1981 Aug 29;283(6291):583-5.
De Vil C, Bruyneel K. Cardioversion and treatment of chronic atrial dysrhythmias with guinidine or lidoflazine: a comparative study. Acta Cardiol. 1974;29(59):383-98. [pmid: 4615536].
Dennis MS, Burn JPS, Sandercock AG, Bamford JM, Wade DT, Warlow CP. Long-term survival after first-ever stroke: the Oxfordshire Community stroke project. Stroke. 1993 Jun;24(6):796-800.
Design of a multicenter randomized trial for the Stroke Prevention in Atrial Fibrillation Study. The Stroke Prevention in Atrial Fibrillation Investigators. Stroke. 1990 Apr;21(4):538-45.
D'Este D, Bertaglia E, Mantovan R, Zanocco A, Franceschi M, Pascotto P. Efficacy of intravenous propafenone in termination of atrial flutter by overdrive transesophageal pacing previously ineffective. Am J Cardiol. 1997 Feb 15;79(4):500-2.
Detsky AS, Naylor CD, O'Rourke K, McGeer AJ, L'Abbe KA. Incorporating variations in the quality of individual randomized trials into meta-analysis. J Clin Epidemiol. 1992 Mar;45(3):255-65.
Di Biasi P, Scrofani R, Paje A, Cappiello E, Mangini A, Santoli C. Intravenous amiodarone vs propafenone for atrial fibrillation and flutter after cardiac operation. Eur J Cardiothorac Surg. 1995(10);9:587-91.
Di MG, Natale E, Pulignano G, Tubaro M, Carelli M, Giampaolo P, Becchis A, Patruno N, Malinconico U, Polizzi CA, Milazzotto F. Efficacy of oral lidoflazine in drug-induced cardiac effusion in atrial and flutter fibrillation during acute myocardial infarction. [Efficacia Della Lidoflazina per Os Nella Cardioversione Farmacologica Della Fibrillazione E Del Flutter Atriale in Corso Di Infarto Miocardico Acuto.]. Cuore. 1993;10:401-8.
Dias VC, Plumb VJ. Intravenous diltiazem in patients with atrial fibrillation/atrial flutter. A pilot dose-response study. Drug Invest. 1991;3:8-13.
Dias VC, Weir SJ, Ellenbogen KA. Pharmacokinetics and pharmacodynamics of intravenous diltiazem in patients with atrial fibrillation or atrial flutter. Circulation. 1992 Nov;86(5):1421-8.
DiBianco R, Morganroth J, Freitag JA, Ronan JA Jr, Lindgren KM, Donohue DJ, Larca LJ, Chadda KD, Olukotun AY. Effects of nadolol on the spontaneous and exercise-provoked heart rate of patients with chronic atrial fibrillation receiving stable dosages of digoxin. Am Heart J. 1984 Oct;108(4 pt 2):1121-7.
Dietl CA, Cazzaniga ME, Dubner SJ, Perez-Balino NA, Torres AR, Favaloro RG. Life-threatening arrhythmias and RV dysfunction after surgical repair of tetralogy of Fallot. Comparison between transventricular and transatrial approaches. Circulation. 1994 Nov;90(5 Pt 2):II7-12.
The Digitalis in Acute Atrial Fibrillation (DAAF) Trial Group. Intravenous digoxin in acute atrial fibrillation. Results of a randomized, placebo-controlled multicentre trial in 239 patients. Eur Heart J. 1997 Apr;18(4):649-54.
Dluzniewski M, Krol J, Kuch M, Syska-Suminska J, Cedro K. Increased efficacy of ajmaline after magnesium administration in the treatment of paroxysmal supraventricular tachyarrhythmias. Kardiol Pol. 1994;41:201-6.
Dobbs SM, Kenyon WI, Dobbs RJ. Maintenance digoxin after an episode of heart failure: placebo-controlled trial in outpatients. Br Med J. 1977 Mar 19;1(6063):749-52.
Doni F, Della Bella P, Kheir A, Manfredi M, Piemonti C, Staffiere E, Rimondini A, Fiorentini C. Atrial flutter termination by overdrive transesophageal pacing and the facilitating effect of oral propafenone. Am J Cardiol. 1995 Dec 15;76(17):1243-6.
Doni F, Staffiere E, Manfredi M, Piemonti C, Todd S, Rimondini A, Fiorentini C. Type II atrial flutter interruption with transesophageal pacing: use of propafenone and possible change of the substrate. Pacing Clin Electrophysiol. 1996 Nov;19(11 Pt 2):1958-61.
Donovan KD, Dobb GJ, Coombs LJ, Lee KY, Weekes JN, Murdock CJ, Clarke GM. Reversion of recent-onset atrial fibrillation to sinus rhythm by intravenous flecainide. Am J Cardiol. 1991 Jan 15;67(2):137-41.
Donovan KD, Dobb GJ, Coombs LJ, Lee KY, Weekes JN, Murdock CJ, Clarke GM. Efficacy of flecainide for the reversion of acute onset atrial fibrillation. Am J Cardiol. 1992 Aug 20;70(5):50A-54A.
Donovan KD, Power BM, Hockings BE, Dobb GJ, Lee KY. Intravenous flecainide versus amiodarone for recent-onset atrial fibrillation. Am J Cardiol. 1995 Apr 1;75(10):693-7.
Dorian P, Naccarelli GV, Coumel P, Hohnloser SH, Maser MJ. A randomized comparison of flecainide versus verapamil in paroxysmal supraventricular tachycardia. The Flecainide Multicenter Investigators Group. Am J Cardiol. 1996 Jan 25;77(3):89A-95A.
Dries DL, Domanski MJ, Waclawiw MA, Gersh BJ. Effect of antithrombotic therapy on risk of sudden coronary death in patients with congestive heart failure. Am J Cardiol. 1997 Apr 1;79(7):909-13.
Dunkman WB, Johnson GR, Carson PE, Bhat G, Farrell L, Cohn JN. Incidence of thromboembolic events in congestive heart failure. The V-HeFT VA Cooperative Studies Group. Circulation. 1993 Jun;87(6 Suppl):VI94-101.
EAFT (European Atrial Fibrillation Trial) Study Group [see comments]. Secondary prevention in non-rheumatic atrial fibrillation after transient ischaemic attack or minor stroke. Lancet. 1993 Nov 20;342(8882):1255-62.
Eckman MH, Levine HJ, Pauker SG. Decision analytic and cost-effectiveness issues concerning anticoagulant prophylaxis in heart disease. Chest. 1992 Oct;102(4 Suppl):538S-49S.
Edner M, Jogestrand T. Effect of physical activity on the day-to-day variation in serum digoxin concentration. Clin Physiol. 1994 Nov;14(6):627-32.
[No authors listed]. The effect of low-dose warfarin on the risk of stroke in patients with nonrheumatic atrial fibrillation. The Boston Area Anticoagulation Trial for Atrial Fibrillation Investigators [see comments]. N Engl J Med. 1990 Nov 29;323(22):1505-11.
[No authors listed]. Effects of RheothRx on mortality morbidity, left ventricular function, and infarct size in patients with acute myocardial infarction. Collaborative Organization for RheothRx Evaluation (CORE). Circulation. 1997 Jul 1;96(1):192-201.
Effert S, Merx W. [On the treatment of atrial fibrillation following surgery of mitral stenosis]. Dtsch Med Wochenschr. 1967 Apr 14;92(15):691-5.
Ejima J, Kaneda K, Moriyama H, Ohmura I, Maruyama T, Kaji Y, Tsuda Y, Kanaya S, Fujino T, Niho Y. Coronary dilating effects of intracoronary nicorandil. Comparison with isosorbide dinitrate. Jpn Heart J. 1995 Nov;36(6):699-707.
Ellenbogen KA, Dias VC, Plumb VJ, Heywood JT, Mirvis DM. A placebo-controlled trial of continuous intravenous diltiazem infusion for 24-hour heart rate control during atrial fibrillation and atrial flutter: a multicenter study. J Am Coll Cardiol. 1991 Oct;18(4):891-7.
Ellenbogen KA, Stambler BS, Wood MA, Sager PT, Wesley RC Jr, Meissner MC, Zoble RG, Wakefield LK, Perry KT, Vanderlugt JT. Efficacy of intravenous ibutilide for rapid termination of atrial fibrillation and atrial flutter: a dose-response study. J Am Coll Cardiol. 1996 Jul;28(1):130-6.
[Embolic complications in atrial fibrillation. Data of the Studio Italiano Fibrillazione Atriale (SIFA)]. G Chir. 1995 Mar;16(3):137-9.
Epperlein S, Kreft A, Siegert V, Liebrich A, Himmrich E, Treese N. [DDD versus DDDR pacemaker stimulation: comparison of cardiopulmonary performance incidence of atrial arrhythmias and quality of life]. Z Kardiol. 1996 Apr;85(4):226-36.
Ezekowitz MD, Bridgers SL, James KE, Carliner NH, Colling CL, Gornick CC, Krause-Steinrauf H, Kurtzke JF, Nazarian SM, Radford MJ, et al. Warfarin in the prevention of stroke associated with nonrheumatic atrial fibrillation. Veterans Affairs Stroke Prevention in Nonrheumatic Atrial Fibrillation Investigators [see comments]. N Engl J Med. 1992 Nov 12;327(20):1406-12.
Ezekowitz MD, Bridgers SL, James KE, SPINAF Investigators. Embolic stroke-atrial fibrillation patent foramen ovale and transesophageal echo [abstract]. Circulation. 1991;84S:II-45.
Ezekowitz MD, James KE. Stroke Prevention in Atrial Fibrillation II Study. Lancet. 1994 Jun 11;343(8911):1508-9.
Ezekowitz MD, James KE, Nazarian SM, Davenport J, Broderick JP, Gupta SR, Thadani V, Meyer ML, Bridgers SL. Silent cerebral infarction in patients with nonrheumatic atrial fibrillation. The Veterans Affairs Stroke Prevention in Nonrheumatic Atrial Fibrillation Investigators. Circulation. 1995 Oct 15;92(8):2178-82.
Faerestrand S, Breivik K, Ohm OJ. Assessment of the work capacity and relationship between rate response and exercise tolerance associated with activity-sensing rate-responsive ventricular pacing. Pacing Clin Electrophysiol. 1987 Nov;10(6):1277-90.
Falk RH. Proarrhythmia in patients treated for atrial fibrillation or flutter. Ann Intern Med. 1992 Jul 15;117(2):141-50. [pmid: 1605429].
Falk RH, Knowlton AA, Bernard SA, Gotlieb NE, Battinelli NJ. Digoxin for converting recent-onset atrial fibrillation to sinus rhythm. A randomized, double-blinded trial. Ann Intern Med. 1987 Apr;106(4):503-6.
Falk RH, Pollak A, Singh SN, Friedrich T. Intravenous dofetilide, a class III antiarrhythmic agent, for the termination of sustained atrial fibrillation or flutter. Intravenous Dofetilide Investigators [see comments]. J Am Coll Cardiol. 1997 Feb;29(2):385-90.
Fanning WJ, Thomas CS Jr, Roach A, Tomichek R, Alford WC, Stoney WS Jr. Prophylaxis of atrial fibrillation with magnesium sulfate after coronary artery bypass grafting [see comments]. Ann Thorac Surg. 1991 Sep;52(3):529-33.
Feinberg MS, Waggoner AD, Kater KM, Cox JL, Lindsay BD, Perez JE. Restoration of atrial function after the maze procedure for patients with atrial fibrillation. Assessment by Doppler echocardiography. Circulation. 1994 Nov;90(5 Pt 2):II285-92.
Feinberg WM, Seeger JF, Carmody RF, Anderson DC, Hart RG, Pearce LA. Epidemiologic features of asymptomatic cerebral infarction in patients with nonvalvular atrial fibrillation. Arch Intern Med. 1990 Nov;150(11):2340-4.
Feinberg WM, SPAF Investigators. Warfarin vs. aspirin in atrial fibrillation:SPAF II study results. Stroke. 1994;25(8).
Feinberg WM, Bovill EG, Nightingale SD, Cornell ES, Koehler JL. Assessing optimal intensity of anticoagulation in patients with atrial fibrillation: prothrombin fragment F1.2 levels compared to Inr. Twenty-first International Joint Conference on Stroke and Cerebral Circulation, 1997.
Feld GK, Nademanee K, Noll E, Singh BN. Oral N-acetylprocainamide compared to quinidine plus digoxin in the chronic suppression of atrial flutter in humans. Cardiovasc Drugs Ther. 1989 Apr;3(2):191-8.
Fera MS, Carunchio A, Burattini M, Mazza A, Coletta C, Galati A, Ceci V. [Comparison of anti-arrhythmic therapy guided by the transesophageal electropharmacologic test and emperic therapy in the prophylaxis of atrial fibrillation recurrence]. G Ital Cardiol. 1997 Feb;27(2):152-63.
Fihn SD, McDonell M, Martin D, Henikoff J, Vermes D, Kent D, White RH, for the Warfarin Optimized Outpatient Follow-up Study Group. Risk factors for complications of chronic anticoagulation. A multicenter study. Ann Intern Med. 1993 Apr 1;118(7):511-20.
Flaker GC, Blackshear JL, McBride R, Kronmal RA, Halperin JL, Hart RG. Antiarrhythmic drug therapy and cardiac mortality in atrial fibrillation. The Stroke Prevention in Atrial Fibrillation Investigators. J Am Coll Cardiol. 1992 Sep;20(3):527-32.
Flegel KM, Shipley MJ, Rose G. Risk of stroke in non-rheumatic atrial fibrillation. Lancet. 1987 Mar 7;1(8532):526-9.
Fomina IG, Iankin VV. [Prospective course of therapy arresting attacks of atrial fibrillation in patients with preexcitation syndromes]. Klin Med (Mosk). 1992 Feb;70(2):37-40. [pmcid: 358319].
Fonrose HA, Ahlbaum N, Bugatch E, Cohen M, Genovese C, Kelly J. The efficacy of digitalis withdrawal in an institutional aged population. J Am Geriatr Soc. 1974 May;22(5):208-11.
Fontan F, Madonna F, Naftel DC, Kirklin JW, Blackstone EH, Digerness S. Modifying myocardial management in cardiac surgery: a randomized trial. Eur J Cardiothorac Surg. 1992;6(3):127-36. [pmid: 1567626].
Ford SR, Maze M, Gaba DM. A comparison of etomidate and thiopental anesthesia for cardioversion. J Cardiothorac Vasc Anesth. 1991 Dec;5(6):563-5.
Frances Y, Luccioni R, Delaage M, Donnarel G, Medvedowsky JL, Quiret JC. [Long-term prevention of the recurrence of auricular fibrillation using cibenzoline. Multicenter study apropos of 89 case reports]. Arch Mal Coeur Vaiss. 1985 Oct;78(Spec No):99-103. [pmid: 3938266].
Frank R, Rougier I, Tonet JL, Harding S, Bons J, Fontaine G, Grosgogeat Y. [Effect on atrioventricular conduction of a new calcium antagonist:lacidipine. Evaluation by the Holter method]. Ann Cardiol Angeiol (Paris). 1990 Jun;39(6):363-9.
Fresco C, Proclemer A, Pavan A, Buia G, Vicentini A, Pavan D, Morgera T. Intravenous propafenone in paroxysmal atrial fibrillation: a randomized, placebo-controlled, double-blind, multicenter clinical trial. Paroxysmal Atrial Fibrillation Italian Trial (PAFIT)-2 Investigators. Clin Cardiol. 1996 May;19(5):409-12.
Frost L, Mortensen PE, Tingleff J, Platou ES, Christiansen EH, Christiansen N. Efficacy and safety of dofetilide, a new class III antiarrhythmic agent, in acute termination of atrial fibrillation or flutter after coronary artery bypass surgery. Dofetilide Post-CABG Study Group. Int J Cardiol. 1997 Jan 31;58(2):135-40.
Furberg CD, Psaty BM, Manolio TA, Gardin JM, Smith VE, Rautaharju PM, for the CHS Collaborative Research Group. Prevalence of atrial fibrillation in elderly subjects (the Cardiovascular Health Study). Am J Cardiol. 1994 Aug 1;74(3):236-41.
Gage BF, Cardinalli AB, Albers GW, Owens DK. Cost-effectiveness of warfarin and aspirin for prophylaxis of stroke in patients with nonvalvular atrial fibrillation. J Am Med Assoc. 1995 Dec 20;274(23):1839-45.
Gage BF, Cardinalli AB, Owens DK. The effect of stroke and stroke prophylaxis with aspirin or warfarin on quality of life. Arch Intern Med. 1996 Sep 9;156(16):1829-36.
Gage BF, Cardinalli AB, Owens DK. Cost-effectiveness of preference-based antithrombotic therapy for patients with nonvalvular atrial fibrillation. Stroke. 1998 Jun;29(6):1083-91.
Gale DW, Grissom TE, Mirenda JV. Titration of intravenous anesthetics for cardioversion: a comparison of propofol, methohexital, and midazolam. Crit Care Med. 1993 Oct;21(10):1509-13.
Galve E, Rius T, Ballester R, Artaza MA, Arnau JM, Garcia-Dorado D, Soler-Soler J. Intravenous amiodarone in treatment of recent-onset atrial fibrillation: results of a randomized, controlled study. J Am Coll Cardiol. 1996 Apr;27(5):1079-82.
Gammage M, Schofield S, Rankin I, Bennett M, Coles P, Pentecost B. Benefit of single setting rate responsive ventricular pacing compared with fixed rate demand pacing in elderly patients. Pacing Clin Electrophysiol. 1991 Feb;14(2 Pt 1):174-80.
Ganiats TG, Palinkas LA, Kaplan RM. Comparison of Quality of Well-Being Scale and Functional Status Index in patients with atrial fibrillation. Med Care. 1992 Oct;30(10):958-64.
Garner TI, Dardis R. Cost-effectiveness analysis of end-stage renal disease treatments. Med Care. 1987 Jan;25(1):25-34.
Gauss A, Druck A, Hemmer W, Georgieff M. [Abdominal complications following heart surgery]. Anasthesiol Intensivmed Notfallmed Schmerzther. 1994 Feb;29(1):23-9.
Gavaghan TP, Koegh AM, Kelly RP, Campbell TJ, Thorburn C, Morgan JJ. Flecainide compared with a combination of digoxin and disopyramide for acute atrial arrhythmias after cardiopulmonary bypass. Br Heart J. 1988 Dec;60(6):497-501.
Gelder I, Crijns HJ, Gilst WH, Lie KI. Efficacy of flecainide to maintain sinus rhythm after cardioversion of chronic atrial fibrillation and flutter [abstract]. Circulation. 1988;78 (Supp).
Gold JA. Warfarin encouraged for stroke prevention in atrial fibrillation. Wis Med J. 1996 Jan;95(1):42-3. [pmid: 8650954].
Gold MR, Kavesh NG, Peters RW, Shorofsky SR. Biphasic waveforms prevent the chronic rise of defibrillation thresholds with a transvenous lead system. J Am Coll Cardiol. 1997 Jul;30(1):233-6.
Gold MR, O'Gara PT, Buckley MJ, DeSanctis RW. Efficacy and safety of procainamide in preventing arrhythmias after coronary artery bypass surgery. Am J Cardiol. 1996 Nov 1;78(9):975-9.
Gold MR, Siegel JE, Russell LB, Weinstein MD, eds. Cost-Effectiveness in Health and Medicine. New York: Oxford Univ Press, 1996.
Goldenberg IF, Lewis WR, Dias VC, Heywood JT, Pedersen WR. Intravenous diltiazem for the treatment of patients with atrial fibrillation or flutter and moderate to severe congestive heart failure [see comments]. Am J Cardiol. 1994 Nov 1;74(9):884-9.
Gosselink AT, Crijns HJ, van den Berg MP, van den Broek SA, Hillege H, Landsman ML, Lie KI. Functional capacity before and after cardioversion of atrial fibrillation: a controlled study. Br Heart J. 1994 Aug;72(2):161-6.
Gozal Y, Glantz L, Luria MH, Milgalter E, Shimon D, Drenger B. Normothermic continuous blood cardioplegia improves electrophysiologic recovery after open heart surgery. Anesthesiology. 1996 Jun;84(6):1298-306.
Gray RJ, Conklin CM, Sethna DH, Mandel WJ, Matloff JM. Role of intravenous verapamil in supraventricular tachyarrhythmias after open-heart surgery. Am Heart J. 1982 Oct;104(4 Pt 1):799-802.
Gullestad L, Birkeland K, Molstad P, Hoyer MM, Vanberg P, Kjekshus J. The effect of magnesium versus verapamil on supraventricular arrhythmias. Clin Cardiol. 1993 May;16(5):429-34.
Gullov AL, Koefoed BG, Petersen P. The AFASAK 2 study: atrial fibrillation, aspirin and anticoagulant therapy. Proceedings of the 7th Scandinavian Meeting on Cerebrovascular Disease. 1993:34.
Gullov AL, Koefoed BG, Petersen P, Pedersen TS, Andersen ED, Godtfredsen J, Boysen G. Fixed minidose warfarin and aspirin alone and in combination vs. adjusted-dose warfarin for stroke prevention in atrial fibrillation: Second Copenhagen Atrial Fibrillation, Aspirin, and Anticoagulation Study. Arch Intern Med. 1998 Jul 27;158(14):1513-21.
Gullov AL, Koefoed BG, Petersen P. [Bleeding complications in oral anticoagulant treatment]. Nord Med. 1995;110(4):114-8. [pmid: 7724354].
Gullov AL, Koefoed BG, Pedersen TS, Petersen P. Major hemorrhage during antithrombotic treatment in atrial fibrillation:the AFASAK 2 study [abstract]. Thromb Haemost. 1997 Jun;(suppl 1).
Gullov AL, Koefoed BG, Petersen P, Pedersen TS, Boysen G, Godtfredsen J, Andersen ED. Fixed low-dose warfarin alone or combined with aspirin and aspirin alone versus adjusted-dose warfarin for stroke prevention in atrial fibrillation [abstract]. Second Copenhagen Atrial Fibrillation Aspirin and Anticoagulation Study (AFASAK 2). J Neurol. 1997;150.
Guo GB, Ellenbogen KA, Wood MA, Stambler BS. Conversion of atrial flutter by ibutilide is associated with increased atrial cycle length variability. J Am Coll Cardiol. 1996 Apr;27(5):1083-9.
Gurlek A, Erol C, Basesme E. Antiarrhythmic effect of converting enzyme inhibitors in congestive heart failure [see comments]. Int J Cardiol. 1994 Mar 1;43(3):315-8.
Gwilt DJ, Chadwick DE. Should beta-blockers be stopped if myocardial ischaemia occurs?. Cardiology. 1983;70(2):94-101. [pmid: 6135506].
Halinen MO, Huttunen M, Paakkinen S, Tarssanen L. Comparison of sotalol with digoxin-quinidine for conversion of acute atrial fibrillation to sinus rhythm (the Sotalol-Digoxin-Quinidine Trial). Am J Cardiol. 1995 Sept 1;76(7):495-8.
Hannes W, Fasol R, Zajonc H, Schindler M, Schumacher B, Schlosser V, Holubarsch CH, Seitelberger R. Diltiazem provides anti-ischemic and anti-arrhythmic protection in patients undergoing coronary bypass grafting. Eur J Cardiothorac Surg. 1993;7(5):239-45. [pmid: 8517952].
Hansson L, Hedner T, Blom P, Dahlof B, De FU, Karlberg BE, Kjeldsen SE, Lanke J, Lemne C, Lindholm L, Lund-Johansen P, Ronn O, Syvertsen JO, Asplund K, Erhardt L, Haugland H, Omvik P, Hansson BG, Samuelsson O, Wedel H. The Nordic Diltiazem Study (NORDIL). A prospective intervention trial of calcium antagonist therapy in hypertension. Blood Press. 1993 Dec;2(4):312-21.
Harenberg J, Huhle G, Piazolo L, Giese C, Heene DL. Long-term anticoagulation of outpatients with adverse events to oral anticoagulants using low-molecular-weight heparin. Semin Thromb Hemost. 1997;23:167-72. [pmid: 9200342].
Harenberg J, Weuster B, Pfitzer M, Dempfle CE, Stehle G, Kubler W, Schlierf G. Prophylaxis of embolic events in patients with atrial fibrillation using low molecular weight heparin. Semin Thromb Hemost. 1993;19(Suppl 1):116-21. [pmid: 8395713].
Harenberg J, Weuster B, Stehle G, Schlierf G, Heene DL. Embolism prophylaxis by low molecular heparin in patients with atrial fibrillation. Klin Wochenschr. 1991;69.
Harrison DC, Sprouse H, Morrow AG. The antiarrhythmic Properties of Lidocaine and Procaine Amide. Circulation. 1963 Oct;284:86-491.
Hart R. Stroke Prevention in Atrial Fibrillation (SPAF III) [abstract]. Stroke. 1994;25.
Hart RG. A differential effect of aspirin in the Stroke Prevention in Atrial Fibrillation Study. Cerebrovasc Dis. 1992;2.
Hartel G, Louhija A, Halonen PI. Investigations on the value of quinidine therapy after electrical rhythmization of atrial fibrillation. Med Welt. 1969;20.
Hartel G, Louhija A, Halonen PI. The value of quinidine therapy in order to maintain sinus rhythm after electrical rhythmization of atrial fibrillation. Klin Wochenschr. 1969;47.
Hartel G, Louhija A, Konttinen A. Disopyramide in the prevention of recurrence of atrial fibrillation after electroconversion. Clin Pharmacol Ther. 1974 Jun;15(6):551-5.
Hays JV, Gilman JK, Rubal BJ. Effect of magnesium sulfate on ventricular rate control in atrial fibrillation. Ann Emerg Med. 1994 Jul;24(1):61-4.
Heidbuchel H, Tack J, Vanneste L, Ballet A, Ector H, Van de Werf F. Significance of arrhythmias during the first 24 hours of acute myocardial infarction treated with alteplase and effect of early administration of a beta-blocker or a bradycardiac agent on their incidence. Circulation. 1994 Mar;89(3):1051-9.
Heisel A, Jung J, Stopp M, Schieffer H. Facilitating influence of procainamide on conversion of atrial flutter by rapid atrial pacing. Eur Heart J. 1997 May;18(5):866-9.
Heldal M, Orning OM. Effects of flecainide on termination of atrial flutter by rapid atrial pacing. Eur Heart J. 1993 Mar;14(3):421-4.
Helgason CM, Hoff JA, Kondos GT, Brace LD. Platelet aggregation in patients with atrial fibrillation taking aspirin or warfarin. Stroke. 1993 Oct;24(10):1458-61.
Hellemons BS, Langenberg M, Lodder J, Vermeer F, Schouten HJA, Van Ree JW, Knottnerus JA. Primary prevention of arterial thromboembolism in patients with nonrheumatic atrial fibrillation in general practice (The PATAF Study). Cerebrovasc Dis. 1997;7.
Henthorn RW, Waldo AL, Anderson JL, Gilbert EM, Alpert BL, Bhandari AK, Hawkinson RW, Pritchett EL. Flecainide acetate prevents recurrence of symptomatic paroxysmal supraventricular tachycardia. The Flecainide Supraventricular Tachycardia Study Group [see comments]. Circulation. 1991 Jan;83(1):119-25.
Hermida JS, Mabo P, Rouesnel P, Scheck F, Canler A, Barthelemy M, Wanszelbaum H. [Comparative study of the efficacy and tolerability of 2 modalities of intravenous cibenzoline administration in the reduction of recent spontaneous atrial arrhythmia]. Ann Cardiol Angeiol (Paris). 1995 Jan;44(1):49-55.
Hii JT, Mitchell LB, Duff HJ, Wyse DG, Gillis AM. Comparison of atrial overdrive pacing with and without extrastimuli for termination of atrial flutter. Am J Cardiol. 1992 Aug 15;70(4):463-7.
Hillestad L, Bjerkelund C, Dale J, Maltau J, Storstein O. Quinidine in maintenance of sinus rhythm after electroconversion of chronic atrial fibrillation. A controlled study. Br Heart J. 1971 Jul;33(4):518-21.
Hillner BE, Smith TJ, Desch CE. Efficacy and cost-effectiveness of autologous bone marrow transplantation in metastatic breast cancer: estimates using decision analysis while awaiting clinical trial results. J Am Med Assoc. 1992 Apr 15;267(15):2055-61.
Hjelms E. Procainamide conversion of acute atrial fibrillation after open-heart surgery compared with digoxin treatment. Scand J Thorac Cardiovasc Surg. 1992;26(3):193-6. [pmid: 1287833].
Hnatkova K, Murgatroyd FD, Camm AJ, Malik M. Effect of digoxin on the ventricular rate variability during paroxysmal atrial fibrillation. Pacing Clin Electrophysiol. 1996 Nov;19(11 Pt 2):1968-71.
Hohnloser SH, Kuck KH. Atrial fibrillation: maintaining stability of sinus rhythm or ventricular rate control? The need for prospective data: the PIAF trial. Pacing Clin Electrophysiol. 1997 Aug;20(8 Pt 1):1989-92.
Hohnloser SH, Li YG. Drug treatment of atrial fibrillation: what have we learned?. Curr Opin Cardiol. 1997 Jan;12(1):24-32.
Hohnloser SH, Meinertz T, Dammbacher T, Steiert K, Jahnchen E, Zehender M, Fraedrich G, Just H. Electrocardiographic and antiarrhythmic effects of intravenous amiodarone: results of a prospective placebo-controlled study. Am Heart J. 1991 Jan;121(1 Pt 1):89-95.
Hohnloser SH, van de Loo A, Baedeker F. Efficacy and proarrhythmic hazards of pharmacologic cardioversion of atrial fibrillation: prospective comparison of sotalol versus quinidine. J Am Coll Cardiol. 1995 Oct;26(4):852-8.
Hood MA, Smith WM. Twice daily diltiazem in rate control of atrial fibrillation. Aust N Z J Med. 1988;18.
Hou ZY, Chang MS, Chen CY, Tu MS, Lin SL, Chiang HT, Woosley RL. Acute treatment of recent-onset atrial fibrillation and flutter with a tailored dosing regimen of intravenous amiodarone. A randomized, digoxin-controlled study [see comments]. Eur Heart J. 1995 Apr;16(4):521-8.
Hughes RA. Study design for Boston Area Anticoagulation Trial for Atrial Fibrillation. Stroke. 1990;21(8):I-91.
Hwang JJ, Li YH, Lin JM, Wang TL, Shyu KG, Ko YL, Lin JL, Chen JJ, Kuan P, Lien WP. Left atrial appendage function determined by transesophageal echocardiography in patients with rheumatic mitral valve disease. Cardiology. 1994;85(2):121-8. [pmid: 7954563].
Hwang MH, Danoviz J, Pacold I, Rad N, Loeb HS, Gunnar RM. Double-blind crossover randomized trial of intravenously administered verapamil. Its use for atrial fibrillation and flutter following open heart surgery. Arch Intern Med. 1984 Mar;144(3):491-4.
[No authors listed]. Ibopamine versus hydrochlorothiazide/amiloride in patients with mild congestive heart failure. SK & F Ibopamine Working Group. Cardiovasc Drugs Ther. 1989 Dec;3(6):897-902.
Ingall TJ for the SPAF Investigators. Transesophageal echocardiographic correlates of thromboembolism in high-risk patients with atrial fibrillation. Stroke Society of Australasia Annual Scientific Meeting, 1997.
Innes GD, Vertesi L, Dillon EC, Metcalfe C. Effectiveness of verapamil-quinidine versus digoxin-quinidine in the emergency department treatment of paroxysmal atrial fibrillation. Ann Emerg Med. 1997 Jan;29(1):126-34.
[No authors listed]. Intravenous digoxin in acute atrial fibrillation. Results of a randomized, placebo-controlled multicentre trial in 239 patients. The Digitalis in Acute Atrial Fibrillation (DAAF) Trial Group. Eur Heart J. 1997 Apr;18(4):649-54.
Ioannidis JP, Lau J. Can quality of clinical trials and meta-analyses be quantified?. Lancet. 1998 Aug 22;352(9128):590-1.
Ioannidis JP, Lau J. The impact of high-risk patients on the results of clinical trials. J Clin Epidemiol. 1997 Oct;50(10):1089-98.
Is hospitalisation necessary for recent-onset atrial fibrillation?. S Afr Med J. 1997 Jun;87(Suppl 3).
Ishibashi K, Inoue D, Sakai R, Inoue M, Shirayama T, Asayama J, Nakagawa M. Effects of disopyramide on the atrial fibrillation threshold in the human atrium. Int J Cardiol. 1995 Nov 24;52(2):177-84.
Jacquet L, Evenepoel M, Marenne F, Evrard P, Verhelst R, Dion R, Goenen M. Hemodynamic effects and safety of sotalol in the prevention of supraventricular arrhythmias after coronary artery bypass surgery. J Cardiothorac Vasc Anesth. 1994 Aug;8(4):431-6.
Jakobsen CJ, Bille S, Ahlburg P, Rybro L, Hjortholm K, Andresen EB. Perioperative metoprolol reduces the frequency of atrial fibrillation after thoracotomy for lung resection. J Cardiothorac Vasc Anesth. 1997 Oct;11(6):746-51.
Jakobsson J, Odmansson I, Nordlander R. Comparison of two different electrodes for the delivery of dc-shocks. Resuscitation. 1990 Aug;20(1):25-9.
James MA, Channer KS, Papouchado M, Rees JR. Improved control of atrial fibrillation with combined pindolol and digoxin therapy. Eur Heart J. 1989 Jan;10(1):83-90.
Jennings G, Jones MS, Besterman EM, Model DG, Turner PP, Kidner PH. Oral disopyramide in prophylaxis of arrhythmias following myocardial infarction. Lancet. 1976 Jan 10;1(7950):51-4.
Jensen BM, Alstrup P, Klitgard NA. Magnesium substitution and postoperative arrhythmias in patients undergoing coronary artery bypass grafting. Scand Cardiovasc J. 1997;31(5):265-9. [pmid: 9406292].
Johnson RG, Goldberger AL, Thurer RL, Schwartz M, Sirois C, Weintraub RM. Lidocaine prophylaxis in coronary revascularization patients: a randomized prospective trial. Ann Thorac Surg. 1993 May;55(5):1180-4.
Jordaens L, de Backer G, Clement DL. Physiologic pacing in the elderly. Effects on exercise capacity and exercise-induced arrhythmias. Jpn Heart J. 1988 Jan;29(1):35-44.
Jordaens L, Missault L, Germonpre E, Callens B, Adang L, Vandenbogaerde J, Clement DL. Delayed restoration of atrial function after conversion of atrial flutter by pacing or electrical cardioversion. Am J Cardiol. 1993 Jan 1;71(1):63-7.
Jordaens L, Trouerbach J, Calle P, Tavernier R, Derycke E, Vertongen P, Bergez B, Vandekerckhove Y. Conversion of atrial fibrillation to sinus rhythm and rate control by digoxin in comparison to placebo [see comments]. Eur Heart J. 1997 Apr;18(4):643-8.
Joshi PP, Deshmukh PK, Salkar RG. Efficacy of intravenous magnesium sulphate in supraventricular tachyarrhythmias [see comments]. J Assoc Physicians India. 1995 Aug;43(8):529-31.
Jung W, Mletzko R, Manz M, Luderitz B. Comparison of two antitachycardia pacing modes in supraventricular tachycardia. Pacing Clin Electrophysiol. 1991 Nov;14(11 Pt 2):1762-6.
Justice AC, Cho MK, Winker MA, Berlin JA, Rennie D. Does masking author identity improve peer view quality? A randomized controlled trial. PEER investigators. J Am Med Assoc. 1998 Jul 15;280(3):240-2.
Juul-Moller S, Edvardsson N, Rehnqvist-Ahlberg N. Sotalol versus quinidine for the maintenance of sinus rhythm after direct current conversion of atrial fibrillation [see comments]. Circulation. 1990 Dec;82(6):1932-9.
Kalusche D, Stockinger J, Betz P, Roskamm H. [Sotalol and quinidine/verapamil (Cordichin) in chronic atrial fibrillation-conversion and 12-month follow-up-a randomized comparison]. Z Kardiol. 1994;83(Suppl 5):109-16. [pmid: 7846939].
Kamalvand K, Tan K, Kotsakis A, Bucknall C, Sulke N. Is mode switching beneficial? A randomized study in patients with paroxysmal atrial tachyarrhythmias. J Am Coll Cardiol. 1997 Aug;30(2):496-504.
Kannel WB, Abbott RD, Savage DD, McNamara PM. Coronary heart disease and atrial fibrillation: the Framingham Study. Am Heart J. 1983 Aug;106(2):389-96.
Kannel WB, Abbott RD, Savage DD, McNamara PM. Epidemiologic features of chronic atrial fibrillation: the Framingham Study. N Engl J Med. 1982 Apr 29;306(17):1018-22.
Kaplan JD, Evans GT Jr, Foster E, Lim D, Schiller NB. Evaluation of electrocardiographic criteria for right atrial enlargement by quantitative two-dimensional echocardiography. J Am Coll Cardiol. 1994 Mar 1;23(3):747-52.
Karlson BW, Torstensson I, Abjorn C, Jansson SO, Peterson LE. Disopyramide in the maintenance of sinus rhythm after electroconversion of atrial fibrillation. A placebo-controlled one-year follow-up study. Eur Heart J. 1988 Mar;9(3):284-90.
Karlson BW, Torstensson I, Abjorn C, Kallryd A, Jonsson J, Jansson SO, Peterson LE. [Preventive disopyramide after electroconversion of atrial fibrillation -- a good alternative]. Lakartidningen. 1991 Jun 12;88(24):2242-5.
Kay GN, Bubien RS, Epstein AE, Plumb VJ. Rate-modulated cardiac pacing based on transthoracic impedance measurements of minute ventilation: correlation with exercise gas exchange. J Am Coll Cardiol. 1989 Nov 1;14(5):1283-9.
Keane D, Boyd E, Anderson D, Robles A, Deverall P, Morris R, Jackson G, Sowton E. Comparison of biphasic and monophasic waveforms in epicardial atrial defibrillation. J Am Coll Cardiol. 1994 Jul;24(1):171-6.
Keilich M, Kulinna C, Seitelberger R, Fasol R. Postoperative follow-up of coronary artery bypass patients receiving calcium antagonist diltiazem. Int J Angiol. 1997;6:8-12.
Kellen JC, Russell ML. Physician specialty is associated with differences in warfarin use for atrial fibrillation. Can J Cardiol. 1998 Mar;14(3):365-8.
Keller F, Schwarz A, Offermann G, Molzahn M, Distler A, Kreutz G, Weinmann J, von Leitner ER, Vohringer HF. [Trial for digitalis withdrawal in hemodialysis patients]. Dtsch Med Wochenschr. 1984 Feb 24;109(8):290-4.
Keller F, Weinmann J, Schwarz A, Andresen D, Haller H, Offermann G, Voehringer HF. Effect of digitoxin on cardiac arrhythmias in hemodialysis patients. Klin Wochenschr. 1987 Nov 16;65(22):1081-6.
Kelly PA, MacAulay-Hunter E, Astridge PS, Lowry PJ, Perrins EJ, Kaye GC. Failure of plasma atrial natriuretic peptide levels to increase during exercise in patients with chronic atrial fibrillation. Pacing Clin Electrophysiol. 1997 Jan;20(1 Pt):10-6.
Kennedy HL, Sprague MK, Redd RM, Wiens RD, Blum RI, Buckingham TA. Serum digoxin concentrations during ethmozine antiarrhythmic therapy. Am Heart J. 1986 Apr;111(4):667-72.
Kerin NZ, Faitel K, Naini M. The efficacy of intravenous amiodarone for the conversion of chronic atrial fibrillation. Amiodarone vs. quinidine for conversion of atrial fibrillation. Arch Intern Med. 1996 Jan 8;156(1):49-53.
Keyes JW, Drake EH, Smith F, Janney. Survival rates after acute myocardial infarction with long-term anticoagulant therapy. Circulation. 1956 Aug;14:254-9.
Khalsa A, Olsson B, Henriksson BA. Effect of oral verapamil on ventricular irregularity in long-standing atrial fibrillation. Acta Med Scand. 1979;205(1-2):39-47. [pmid: 367086].
Kingma JH, Suttorp MJ. Acute pharmacologic conversion of atrial fibrillation and flutter: the role of flecainide, propafenone, and verapamil. Am J Cardiol. 1992 Aug 20;70(5):56A-60A.
Kistler JP, Singer DE, Millenson MM, Bauer KA, Gress DR, Barzegar S, Hughes RA, Sheehan MA, Maraventano SW, Oertel LB, et al. Effect of low-intensity warfarin anticoagulation on level of activity of the hemostatic system in patients with atrial fibrillation. BAATAF Investigators. Stroke. 1993 Sep;24(9):1360-5.
Klein AL, Grimm RA, Black IW, Leung DY, Chung MK, Vaughn SE, Murray RD, Miller DP, Arheart KL. Cardioversion guided by transesophageal echocardiography: the ACUTE Pilot Study. A randomized, controlled trial. Assessment of Cardioversion Using Transesophageal Echocardiography [see comments]. Ann Intern Med. 1997 Feb 1;126(3):200-9.
Klemperer JD, Klein IL, Ojamaa K, Helm RE, Gomez M, Isom OW, Krieger KH. Triiodothyronine therapy lowers the incidence of atrial fibrillation after cardiac operations. Ann Thorac Surg. 1996 May;61(5):1323-7.
Knez A, Haberl R, Steinbeck G. [The use of digitalis glycosides in atrial fibrillation]. Z Kardiol. 1994;83(Suppl 5):71-3. [pmid: 7846948].
Koefoed BG, Feddersen C, Gullov AL, Petersen P. Effect on fixed minidose warfarin conventional dose warfarin and aspirin on INR and prothrombin fragment 1+2 in patients with atrial fibrillation. Thromb Haemost. 1997 May;77(5):845-8.
Koefoed B, Gullov A, Petersen P. Second Copenhagen atrial fibrillation, aspirin and anticoagulant therapy study method and design. Thromb Thrombolysis. 1995;2:125-30.
Koefoed BG, Gullov AL, Petersen P. The AFASAK 2 study. Atrial fibrillation, aspirin and anticoagulant therapy. Second International Conference on Stroke. 1993;1.
Koefoed BG, Gullov AL, Petersen P, Petersen T, Boysen G, Godtfredsen J, Andersen ED. The Second Copenhagen atrial fibrillation, aspirin and anticoagulant therapy study (AFASAK 2). Progress of the study. Twenty-Second International Joint Conference on Stroke and Cerebral Circulation, 1997.
Koefoed BG, Gullov AL, Pedersen TS, Petersen P. Dropout and withdrawal from warfarin and aspirin therapy in patients with atrial fibrillation [abstract]. Thromb Haemost. 1997;(Suppl):83-4. [pmid: 9198133].
Koh KK, Kwon KS, Park HB, Baik SH, Park SJ, Lee KH, Kim EJ, Kim SH, Cho SK, Kim SS. Efficacy and safety of digoxin alone and in combination with low-dose diltiazem or betaxolol to control ventricular rate in chronic atrial fibrillation. Am J Cardiol. 1995 Jan 1;75(1):88-90.
Koh KK, Song JH, Kwon KS, Park HB, Baik SH, Park YS, In HH, Moon TH, Park GS, Cho SK, et al. Comparative study of efficacy and safety of low-dose diltiazem or betaxolol in combination with digoxin to control ventricular rate in chronic atrial fibrillation: randomized crossover study. Int J Cardiol. 1995 Nov 24;52(2):167-74.
Kondili A, Kastrati A, Popa Y. Comparative evaluation of verapamil flecainide and propafenone for the acute conversion of atrial fibrillation to sinus rhythm. Wien Klin Wochenschr. 1990 Sep 14;102(17):510-3.
Kopecky SL, Gersh BJ, McGoon MD, Whisnant JP, Holmes DR Jr, Ilstrup DM, Frye RL. The natural history of lone atrial fibrillation. A population-based study over three decades. N Engl J Med. 1987 Sept 10;317(11):669-74.
Kosowsky BD, Taylor J, Lown B, Ritchie RF. Long-term use of procaine amide following acute myocardial infarction. Circulation. 1973 Jun;47(6):1204-10.
Koudstaal PJ. [Prevention of a brain infarct in patients with non-rheumatic atrial fibrillation]. Ned Tijdschr Geneeskd. 1989 Jul 29;133(30):1485-6. [pmid: 2677767].
Kowey PR, Dalessandro DA, Herbertson R, Briggs B, Wertan MA, Rials SJ, Filart RA, Marinchak RA. Effectiveness of digitalis with or without acebutolol in preventing atrial arrhythmias after coronary artery surgery. Am J Cardiol. 1997 Apr 15;79(8):1114-7.
Krahn AD, Manfreda J, Tate RB, et al. Prognosis of atrial fibrillation in men. Manitoba Follow-up Study. J Am Coll Cardiol. 1993 Mar;21(2).
Krahn AD, Manfreda J, Tate RB, Mathewson FA, Cuddy TE. The natural history of atrial fibrillation: incidence, risk factors, and prognosis in the Manitoba Follow-up Study. Am J Med. 1995 May;98(5):476-84.
Kuhlkamp V, Schmid F, Risler T, Seipel L. Randomized comparison of flecainide and cibenzoline in the conversion of atrial fibrillation. Int J Cardiol. 1991 Apr;31(1):65-9.
Lamaison D, Page E, Aupetit JF, Defaye P, Rozand JY, Mouton E, Salvi R. A comparison between single atrial and dual chamber rate adaptive (AAIR and DDDR) and nonadaptive AAI and DDD cardiac pacing using cardiopulmonary exercise testing in patients with atrial chronotropic incompetence. Eur J Card Pacing Electrophysiol. 1993;3:197-204.
Lamb RK, Prabhakar G, Thorpe JA, Smith S, Norton R, Dyde JA. The use of atenolol in the prevention of supraventricular arrhythmias following coronary artery surgery. Eur Heart J. 1988 Jan;9(1):32-6.
Lanas F, Salvatici R, Castillo G, Montecinos A, Stockins B, Molina E. Comparison between digoxin and atenolol in chronic atrial fibrillation. Rev Med Chil. 1995 Oct;123(10):1252-62.
Landefeld CS, Goldman L. Major bleeding in outpatients treated with warfarin: incidence and prediction by factors known at the start of outpatient therapy. Am J Med. 1989 Aug;87(2):144-52.
Landymore RW, Howell F. Recurrent atrial arrhythmias following treatment for postoperative atrial fibrillation after coronary bypass operations. Eur J Cardiothorac Surg. 1991;5(8):436-9. [pmid: 1910852].
Lang R, Klein HO, Di Segni E, Gefen J, Sareli P, Libhaber C, David D, Weiss E, Guerrero J, Kaplinsky E. Verapamil improves exercise capacity in chronic atrial fibrillation: double-blind crossover study. Am Heart J. 1983 May;105(5):820-5.
Larbuisson R, Venneman I, Stiels B. The efficacy and safety of intravenous propafenone versus intravenous amiodarone in the conversion of atrial fibrillation or flutter after cardiac surgery. J Cardiothorac Vasc Anesthes. 1996 Feb;10(2):229-34.
Lardoux H, Maison Blanche P, Marchand X, Canler A, Rouesnel P, Bleinc D, Peraudeau P, Schedk F. [Cibenzoline versus oral propafenone in the prevention of recurrent atrial arrhythmias: multicentre randomized double-blind study]. Ann Cardiol Angeiol (Paris). 1996 Oct;45(8):469-79.
Lardoux H, Maison-Blanche P, Marchand X, Canler A, Rouesnel P, Bleinc D, Peraudeau P, Scheck F. [Cibenzoline versus propafenone by the oral route for preventing recurrence of atrial arrhythmia: multicenter randomized double-blind study]. Ann Cardiol Angeiol (Paris). 1996 Oct;45(8):469-79.
Lau CP, Leung WH, Wong CK. A randomized double-blind crossover study comparing the efficacy and tolerability of flecainide and quinidine in the control of patients with symptomatic paroxysmal atrial fibrillation. Am Heart J. 1992 Sept;124(3):645-50.
Lau CP, Tai YT, Lee PW. The effects of radiofrequency ablation versus medical therapy on the quality-of-life and exercise capacity in patients with accessory pathway-mediated supraventricular tachycardia: a treatment comparison study. Pacing Clin Electrophysiol. 1995 Mar;18(3 Pt 1):424-32.
Lau CP, Tai YT, Leung WH, Wong CK, Lee P, Chung FL. Rate adaptive pacing in sick sinus syndrome: effects of pacing modes and intrinsic conduction on physiological responses, arrhythmias, symptomatology and quality of life. Eur Heart J. 1994 Nov;15(11):1445-55.
Laub GW, Janeira L, Muralidharan S, Riebman JB, Chen C, Neary M, Fernandez J, Adkins MS, McGrath LB. Prophylactic procainamide for prevention of atrial fibrillation after coronary artery bypass grafting: a prospective double-blind randomized placebo-controlled pilot study. Crit Care Med. 1993 Oct;21(10):1474-8.
Laupacis A, Albers G, Dunn M, Feinberg W. Antithrombotic therapy in atrial fibrillation. Chest. 1992 Oct;102(4 Suppl):426S-33S.
Laupacis A, Connolly SJ, Gent M, Roberts RS, Cairns J, Joyner C. How should results from completed studies influence ongoing clinical trials? The CAFA Study experience [see comments]. Ann Intern Med. 1991 Nov 15;115(10):818-22.
Laupacis A, Sullivan K. Canadian atrial fibrillation anticoagulation study: were the patients subsequently treated with warfarin? Canadian Atrial Fibrillation Anticoagulation Study Group. Can Med Assoc J. 1996 Jun 1;154(11):1669-74.
Lawson-Matthew PJ, McLean KA, Dent M, Austin CA, Channer KS. Improved heart rate control and effort tolerance using xamoterol in atrial fibrillation. Age Ageing. 1995 Jul;24(4).
Lawson-Matthew PJ, McLean KA, Dent M, Austin CA, Channer KS. Xamoterol improves the control of chronic atrial fibrillation in elderly patients. Age Ageing. 1995 Jul;24(4):321-5.
Lazar HL, Philippides G, Fitzgerald C, Lancaster D, Shemin RJ, Apstein C. Glucose-insulin-potassium solutions enhance recovery after urgent coronary artery bypass grafting. J Thorac Cardiovasc Surg. 1997 Feb;113(2):354-60.
Ledwich JR. A trial of propranolol in myocardial infarction. Can Med Assoc J. 1968 May 25;98 (21):988-94. [pmid: 4174139].
Lee AJ, Huber J, Stason WB. Poststroke rehabilitation in older Americans. The Medicare experience. Med Care. 1996 Aug;34(8):811-25.
Lee DC, Johnson RA, Bingham JB, Leahy M, Dinsmore RE, Goroll AH, Newell JB, Strauss HW, Haber E. Heart failure in outpatients: a randomized trial of digoxin versus placebo. N Engl J Med. 1982 Mar 25;306(12):699-705.
Lee SH, Chen SA, Chiang CE, Tai CT, Wen ZC, Wang SP, Chang MS. Comparisons of oral propafenone and quinidine as an initial treatment option in patients with symptomatic paroxysmal atrial fibrillation: a double-blind, randomized trial. J Intern Med. 1996 Mar;239(3):253-60.
Lee SH, Chen SA, Tai CT, Chiang CE, Wen ZC, Chen YJ, Yu WC, Huang JL, Fong AN, Cheng JJ, Chang MS. Comparisons of oral propafenone and sotalol as an initial treatment in patients with symptomatic paroxysmal atrial fibrillation. Am J Cardiol. 1997 Apr 1;79(7):905-8.
Leung SK, Lau CP, Wu CW, Leung WH, Tai YT, Lee I, Chow YH. Quantitative comparison of rate response and oxygen uptake kinetics between different sensor modes in multisensor rate adaptive pacing. Pacing Clin Electrophysiol. 1994 Nov;17(11 Pt 2):1920-7.
Levi G, Proto C, Rovetta A. Double-blind evaluation of practolol and quinidine in the treatment of chronic atrial fibrillation. Cardiology. 1973;58(6):364-8. [pmid: 4608474].
Levinson DC, Griffith GC. Evaluation of anticoagulant therapy in congestive heart failure. Circulation. 1951 Sep;4:416-9.
Levy S. Amiodarone as a first-line drug in the treatment of atrial fibrillation: the protagonist viewpoint. Cardiovasc Drugs Ther. 1994 Oct;8(5):769-71. [pmid: 7873475].
Levy S, Lauribe P, Dolla E, Kou W, Kadish A, Calkins H, Pagannelli F, Moyal C, Bremondy M, Schork A, et al. A randomized comparison of external and internal cardioversion of chronic atrial fibrillation [see comments]. Circulation. 1992 Nov;86(5):1415-20.
Levy S, Ricard P, Gueunoun M, Yapo F, Trigano J, Mansouri C, Paganelli F. Low-energy cardioversion of spontaneous atrial fibrillation. Immediate and long-term results. Circulation. 1997 Jul 1;96(1):253-9.
Lewis R, Lakhani M, Moreland TA, McDevitt DG. A comparison of verapamil and digoxin in the treatment of atrial fibrillation. Eur Heart J. 1987 Feb;8(2):148-53.
Lewis RV, Irvine N, McDevitt DG. Relationships between heart rate, exercise tolerance and cardiac output in atrial fibrillation: the effects of treatment with digoxin, verapamil and diltiazem. Eur Heart J. 1988 Jul;9(7):777-81.
Lewis RV, Laing E, Moreland TA, Service E, McDevitt DG. A comparison of digoxin, diltiazem and their combination in the treatment of atrial fibrillation. Eur Heart J. 1988 Mar;9(3):279-83.
Lewis RV, McDevitt DG. Factors affecting the clinical response to treatment with digoxin and two calcium antagonists in patients with atrial fibrillation. Br J Clin Pharmacol. 1988 May;25(5):603-6.
Lewis RV, McMurray J, McDevitt DG. Effects of atenolol, verapamil, and xamoterol on heart rate and exercise tolerance in digitalised patients with chronic atrial fibrillation. J Cardiovasc Pharmacol. 1989 Jan;13(1):1-6.
Ley H, Ohlen J, Richthofen W von. [The treatment of tachycardial disturbances of the cardiac rhythm with a beta-adrenergic blocking agent (Visken)]. Munch Med Wochenschr. 1970 Nov 27;112(48):2183-6.
Likoff MJ, Weber KT, Andrews V, Janicki JS, Wilson H, Rocci ML Jr. Milrinone in the treatment of chronic cardiac failure: a controlled trial. Am Heart J. 1985 Nov;110(5):1035-42.
Lima JJ, Wenzke SC, Boudoulas H, Schaal SF. Antiarrhythmic activity and unbound concentrations of disopyramide enantiomers in patients. Ther Drug Monit. 1990 Jan;12(1):23-8.
Lin SK, Morganroth J, Heng M, Rubler S, Baird W, Atwood JE, Mostow N, Scarse OM, Yu P, Caruso FS, et al. Effect of orally administered celiprolol in patients with chronic atrial fibrillation. J Cardiovasc Pharmacol. 1986;8(Suppl 4):S112-5.
Lip GH, Lip PL, Zarifis J, Watson RD, Bareford D, Lowe GD, Beevers DG. Fibrin D-dimer and beta-thromboglobulin as markers of thrombogenesis and platelet activation in atrial fibrillation: effects of introducing ultra-low dose warfarin and aspirin. Circulation. 1996 Aug 1;94 (3):425-31.
Lip GY, Lowe GD, Rumley A, Dunn FG. Increased markers of thrombogenesis in chronic atrial fibrillation: effects of warfarin treatment. Br Heart J. 1995 Jun;73(6):527-33.
Lok NS, Lau CP. Oxygen uptake kinetics and cardiopulmonary performance in lone atrial fibrillation and the effects of sotalol. Chest. 1997 Apr;111(4):934-40.
Loogen F, Risler T, Seipel L. [Prevention of embolism in mitral-valve lesions with anticoagulants. (Long-term observations on patients with and without discoumarol treatment)]. Dtsch Med Wochenschr. 1972 Dec 1;97(48):1845-9.
Lown B, Perlroth MG, Kaidbey S, Abe T, Harken DE. "Cardioversion" of atrial fibrillation. A report on the treatment of 65 episodes in 50 patients. N Engl J Med. 1963 Aug 15;269:325-31.
Luciardi H, Berman S, Santana M, Monteros L. [Intravenous diltiazem in the reversion to sinus rhythm in supraventricular tachyarrhythmias]. Arch Inst Cardiol Mex. 1996 Nov-Dec;66(6):505-9.
Lundstrom T, Moor E, Ryden L. Differential effects of xamoterol and verapamil on ventricular rate regulation in patients with chronic atrial fibrillation. Am Heart J. 1992 Oct;124(4):917-23.
Lundstrom T, Ryden L. Ventricular rate control and exercise performance in chronic atrial fibrillation: effects of diltiazem and verapamil. J Am Coll Cardiol. 1990 Jul;16(1):86-90.
Madrid AH, Moro C, Marin-Huerta E, Mestre JL, Novo L, Costa A. Comparison of flecainide and procainamide in cardioversion of atrial fibrillation. Eur Heart J. 1993 Aug;14(8):1127-31.
Mahaffey KW, Granger CB, Sloan MA, Thompson TD, Gore JM, Weaver WD, White HD, Simoons ML, Barbash GI, Topol EJ, Califf RM. Risk factors for in-hospital nonhemorrhagic stroke in patients with acute myocardial infarction treated with thrombolysis: results from GUSTO I. Circulation. 1998 Mar 3;97(8):757-64.
Maisel WH, Kuntz KM, Reimold SC, Lee TH, Antman EM, Friedman PL, Stevenson WG. Risk of initiating antiarrhythmic drug therapy for atrial fibrillation in patients admitted to a university hospital. Ann Intern Med. 1997 Aug 15;127(4):281-4.
Maison-Blanche P, Brembilla-Perrot B, Fauchier JP, Babuty D, Garnier LF, Rouesnel P, Breuillac JC, Funck F, Scheck F, Peraudeau P, Medvedowsky JL. [Comparative study of cibenzoline and flecainide by oral route for preventing recurrence of paroxysmal atrial tachyarrhythmias]. Ann Cardiol Angeiol (Paris). 1997 Feb;46(2):109-16.
Mak KH, Moliterno DJ, Granger CB, Miller DP, White HD, Wilcox RG, Califf RM, Topol EJ. Influence of diabetes mellitus on clinical outcome in the thrombolytic era of acute myocardial infarction. GUSTO-I Investigators. Global Utilization of Streptokinase and Tissue Plasminogen Activator for Occluded Coronary Arteries. J Am Coll Cardiol. 1997 Jul;30(1):171-9.
Makynen PJ, Koskinen PJ, Saaristo TE, Liisanantti RK. Comparison of encainide and quinidine for supraventricular tachyarrhythmias. Am J Cardiol. 1988 Dec 20;Suppl 62(19):55L-59L.
Malhotra R, Mishra M, Kler TS, Kohli VM, Mehta Y, Trehan N. Cardioprotective effects of diltiazem infusion in the perioperative period. Eur J Cardiothorac Surg. 1997 Sep;12(3):420-7.
Man-Son-Hing M, Laupacis A, O'Connor A, Wells G, Lemelin J, Wood W, Dermer M. Warfarin for atrial fibrillation. The patient's perspective. Arch Intern Med. 1996 Sep 9;156(16):1841-8.
Manning WJ, Silverman DI, Keighley CS, Oettgen P, Douglas PS. Transesophageal echocardiographically facilitated early cardioversion from atrial fibrillation using short-term anticoagulation: final results of a prospective 4.5 year study. J Am Coll Cardiol. 1995 May;25(6):1354-61.
Manning WJ, Weintraub RM, Waksmonski CA, Haering JM, Rooney PS, Maslow AD, Johnson RD, Douglas PS. Accuracy of transesophageal echocardiography for identifying left atrial thrombi: a prospective, intraoperative study. Ann Intern Med. 1995 Dec 1;123(11):817-22.
Manolio TA, Furberg CD, Rautaharju PM, Siscovick D, Newman AB, Borhani NO, Gardin JM, Tabatznik B, for the Cardiovascular Health Study (CHS) Collaborative Research Group. Cardiac arrhythmia on 24-h ambulatory electrocardiography in older women and men: the Cardiovascular Health Study. J Am Coll Cardiol. 1994 March 15;23(4):916-25.
Marshall J. Rebound phenomena after anticoagulant therapy in cerebrovascular disease. Circulation. 1963 Sep;28:329-32. [pmid: 14059451].
Martin A, Benbow LJ, Leach C, Bailey RJ. Comparison of amiodarone and disopyramide in the control of paroxysmal atrial fibrillation and atrial flutter (interim report). Br J Clin Pract Symp Suppl. 1986 Apr;44:52-60. [pmid: 3089263].
Mas JL. [Thromboembolic complications in the course of non-valvular atrial fibrillation]. Rev Prat. 1995 Apr 15;45(8):935-41. [pmid: 7761775].
Masini M, Ieri A, Lorenzoni R, Bartoli P, Lencioni G, Zipoli A, Masini G. [Comparison of lidoflazine and quinidine in the conversion to sinusal rhythm in atrial fibrillation of recent onset]. G Ital Cardiol. 1990 Mar;20(3):202-6.
Massie BM, Shah NB, Pitt B, Packer M. Importance of assessing changes in ventricular response to atrial fibrillation during evaluation of new heart failure therapies: experience from trials of flosequinan. Am Heart J. 1996 Jul;132 (1 Pt 1):130-6.
Matangi MF, Strickland J, Garbe GJ, Habib N, Basu AK, Burgess JJ, Maitland A, Busse EF. Atenolol for the prevention of arrhythmias following coronary artery bypass grafting. Can J Cardiol. 1989 May;5(4):229-34.
Materne P, Larbuisson R, Collignon P, Limet R, Kulbertus H. Prevention by acebutolol of rhythm disorders following coronary bypass surgery. Int J Cardiol. 1985 Jul;8(3):275-86.
Matsumoto N, Whisnant JP, Kurland LT, Okazaki H. Natural history of stroke in Rochester, Minnesota, 1955 through 1969: an extension of a previous study, 1945 through 1954. Stroke. 1973 Jan-Feb;4(1):20-9.
Matthew PJ, McLean KA, et al. Xamoterol improves control of atrial fibrillation in the elderly [abstract]. Clin Sci. 1994;87(Suppl).
Mattioli AV, Castellani ET, Vivoli D, Sgura FA, Mattioli G. Prevalence of atrial fibrillation and stroke in paced patients without prior atrial fibrillation: a prospective study. Clin Cardiol. 1998 Feb;21(2):117-22.
Mayumi H, Matsuzaki K, Kohno H, Matsui K, Kawachi Y, Yasui H. Effectiveness and limitations of the fallback I algorithm for transient supraventricular tachyarrhythmias in DDD pacing. Artif Organs. 1996 Jul;20(7):810-4.
McAlister HF, Luke RA, Smith WM. Amiodarone versus quinidine reversion of atrial fibrillation post-cardiac surgery. Aust N Z J Med. 1986;16.
McAlister HF, Luke RA, Whitlock RM, Smith WM. Intravenous amiodarone bolus versus oral quinidine for atrial flutter and fibrillation after cardiac operations [see comments]. J Thorac Cardiovasc Surg. 1990 May;99(5):911-8.
McCarty RJ, Jahnke EJ, Walker WJ. Ineffectiveness of quinidine in preventing atrial fibrillation following mitral valvotomy. Circulation. 1966 Nov;34(5):792-4.
McCollam PL, Crouch MA, Watson JE. Altered protein binding of quinidine in patients with atrial fibrillation and flutter. Pharmacotherapy. 1997 Jul-Aug;17(4):753-9.
McMahan DA, Smith DM, Carey MA, Zhou XH. Risk of major hemorrhage for outpatients treated with warfarin. J Gen Intern Med. 1998 May;13(5):311-6.
Mertens DJ, Kavanagh T. Exercise training for patients with chronic atrial fibrillation. J Cardpulm Rehabil. 1996 May-Jun;16(3):193-6.
Miller VT, Pearce LA, Feinberg WM, Rothrock JF, Anderson DC, Hart RG. Differential effect of aspirin versus warfarin on clinical stroke types in patients with atrial fibrillation. Neurology. 1996 Jan;46(1):238-40.
Misiani R, Bellavita P, Fenili D, Vicari O, Marchesi D, Sironi PL, Zilio P, Vernocchi A, Massazza M, Vendramin G, et al. Interferon alfa-2a therapy in cryoglobulinemia associated with hepatitis C virus [see comments]. N Engl J Med. 1994 Mar 17;330(11):751-6.
Mitusch R, Siemens HJ, Garbe M, Wagner T, Sheikhzadeh A, Diederich KW. Detection of a hypercoagulable state in nonvalvular atrial fibrillation and the effect of anticoagulant therapy. Thromb Haemost. 1996 Feb;75(2):219-23.
Morady F, Calkins H, Langberg JJ, Armstrong WF, de Buitleir M, el-Atassi R, Kalbfleisch SJ. A prospective randomized comparison of direct current and radiofrequency ablation of the atrioventricular junction. J Am Coll Cardiol. 1993 Jan;21(1):102-9.
Moreyra E, Finkelhor RS, Cebul RD. Limitations of transesophageal echocardiography in the risk assessment of patients before nonanticoagulated cardioversion from atrial fibrillation and flutter: an analysis of pooled trials. Am Heart J. 1995 Jan;129(1):71-5.
Morocutti C, Amabile G, Fattapposta F, Nicolosi A, Matteoli S, Trappolini M, Cataldo G, Milanesi G, Lavezzari M, Pamparana F, Coccheri S. Indobufen versus warfarin in the secondary prevention of major vascular events in nonrheumatic atrial fibrillation. SIFA (Studio Italiano Fibrillazione Atriale) Investigators. Stroke. 1997 May;28(5):1015-21.
Morocutti C, Coccheri S. Aspirin and prevention of stroke [letter]. Lancet. 1994 Jan 22;343(8891).
Morocutti C, Matteoli S, Di VD, Fattapposta F, Trappolini M, Milanesi G, Amabile G. Antithrombotic treatment for stroke prevention in nonvalvular atrial fibrillation. Nuova Rivista di-Neurologia. 1995;5:196-200.
Morocutti C, SIFA Steering Committee. Secondary Prevention of Stroke in Patients with Atrial Fibrillation (Studio Italiano Fibrillazione Atriale) (SIFA) [abstract]. Stroke. 1995;26(1).
Moulton AW, Singer DE, Haas JS. Risk factors for stroke in patients with nonrheumatic atrial fibrillation: a case-control study [see comments]. Am J Med. 1991 Aug;91(2):156-61.
[No authors listed]. Multicenter trial of hemodilution in acute ischemic stroke. Results of subgroup analyses. Scandinavian Stroke Study Group. Stroke. 1988 Apr;19(4):464-71.
Munafo A, Buclin T, Tuto D, Biollaz J. The effect of a low dose of quinidine on the disposition of flecainide in healthy volunteers. Eur J Clin Pharmacol. 1992;43(4):441-3. [pmid: 1451729].
Murdock CJ, Davis MJE. A double blind control study of sotalol compared to propranolol and placebo in the treatment of acute atrial fibrillation. Aust N Z J Med. 1988 Dec;18.
Murgatroyd FD, Xie B, Copie X, Blankoff I, Camm AJ, Malik M. Identification of atrial fibrillation episodes in ambulatory electrocardiographic recordings: validation of a method for obtaining labeled R-R interval files. Pacing Clin Electrophysiol. 1995 Jun;18(6):1315-20.
Myers J, Atwood JE, Sullivan M, Forbes S, Friis R, Pewen W, Froelicher V. Perceived exertion and gas exchange after calcium and beta-blockade in atrial fibrillation. J Appl Physiol. 1987 Jul;63(1):97-104.
Naccarelli GV, Dorian P, Hohnloser SH, Coumel P. Prospective comparison of flecainide versus quinidine for the treatment of paroxysmal atrial fibrillation/flutter. The Flecainide Multicenter Atrial Fibrillation Study Group. Am J Cardiol. 1996 Jan 25;77(3):53A-9A.
Nazarian SM, James KE, Ezekowitz MD, SPINAF Investigators. Asymptomatic Stroke in Patients with Chronic Nonrheumatic Atrial Fibrillation (SPINAF). Stroke. 1994;25(1).
Negrini M, Gibelli G, De Ponti C. [Comparison of amiodarone and quinidine in the conversion to sinusal rhythm of atrial fibrillation of recent onset]. G Ital Cardiol. 1990 Mar;20(3):207-14.
Noc M, Stajer D, Horvat M. Intravenous amiodarone versus verapamil for acute conversion of paroxysmal atrial fibrillation to sinus rhythm [see comments]. Am J Cardiol. 1990 Mar 1;65(9):679-80.
Normand JP, Legendre M, Kahn JC, Bourdarias JP, Mathivat A. Comparative efficacy of short-acting and long-acting quinidine for maintenance of sinus rhythm after electrical conversion of atrial fibrillation. Br Heart J. 1976 Apr;38(4):381-7.
Nurozler F, Tokgozoglu L, Pasaoglu I, Boke E, Ersoy U, Bozer AY. Atrial fibrillation after coronary artery bypass surgery: predictors and the role of MgSO4 replacement. J Card Surg. 1996 Nov-Dec;11(6):421-7.
Nystrom U, Edvardsson N, Berggren H, Pizzarelli GP, Radegran K. Oral sotalol reduces the incidence of atrial fibrillation after coronary artery bypass surgery. Thorac Cardiovasc Surg. 1993 Feb;41(1):34-7.
Obel IW. Clinical and experimental experience with 39089 BA (trasicor) as an anti-arrhythmic agent. S Afr Med J. 1969 Dec;6(Suppl):18-23.
Ochs HR, Anda L, Eichelbaum M, Greenblatt DJ. Diltiazem, verapamil, and quinidine in patients with chronic atrial fibrillation. J Clin Pharmacol. 1985 Apr;25(3):204-9.
Ochs HR, Eichelbaum M, Vogelgesang B, Kumm D, et al. Diltiazem, verapamil, and quinidine in chronic atrial fibrillation. Med Welt. 1984;35:383-7.
O'Nunain S, Garratt CJ, Linker NJ, Gill J, Ward DE, Camm AJ. A comparison of intravenous propafenone and flecainide in the treatment of tachycardias associated with the Wolff-Parkinson-White syndrome. Pacing Clin Electrophysiol. 1991 Nov;14(11 Pt 2):2028-34.
Onundarson PT, Thorgeirsson G, Jonmundsson E, Sigfusson N, Hardarson T. Chronic atrial fibrillation-epidemiologic features and 14 year follow-up: a case-control study. Eur Heart J. 1987 May;8(5):521-7.
[No authors listed]. Optimal oral anticoagulant therapy in patients with nonrheumatic atrial fibrillation and recent cerebral ischemia. The European Atrial Fibrillation Trial Study Group [see comments]. N Engl J Med. 1995 Jul 6;333(1):5-10.
Osswald S, Leiggener C, Buser PT, Pfisterer ME, Burckhardt D, Burkart F. Benefits and limitations of rate adaptive pacing under laboratory and daily life conditions in patients with minute ventilation single chamber pacemakers. Pacing Clin Electrophysiol. 1996 Jun;19(6):890-8.
Ostrander LD Jr, Brandt RL, Kjelsberg MO, Epstein FH. Electrocardiograph Ic findings among the adult population of a total natural community. Tecumseh, Michigan. Circulation. 1965 Jun;31:888-98.
Ovrum E, Am Holen E, Tangen G, Ringdal MA. Heparinized cardiopulmonary bypass and full heparin dose marginally improve clinical performance. Ann Thorac Surg. 1996 Oct;62(4):1128-33.
Panidis IP, Morganroth J, Baessler C. Effectiveness and safety of oral verapamil to control exercise-induced tachycardia in patients with atrial fibrillation receiving digitalis. Am J Cardiol. 1983 Dec 1;52(10):1197-201.
Parikka H, Toivonen L, Heikkila L, Virtanen K, Jarvinen A. Comparison of sotalol and metoprolol in the prevention of atrial fibrillation after coronary artery bypass surgery. J Cardiovasc Pharmacol. 1998 Jan;31(1):67-73.
Parikka H, Toivonen L, Pellinen T, Verkkala K, Jarvinen A, Nieminen MS. The influence of intravenous magnesium sulphate on the occurrence of atrial fibrillation after coronary artery by-pass operation. Eur Heart J. 1993 Feb;14(2):251-8.
Pasricha CJ, Fleischer DE, Kalloo AN. Endoscopic perforations of the upper digestive tract: a review of their pathogenesis, prevention, and management. Gastroenterology. 1994 Mar;106(3):787-802. [pmcid: 222984].
Paull DL, Tidwell SL, Guyton SW, Harvey E, Woolf RA, Holmes JR, Anderson RP. Beta blockade to prevent atrial dysrhythmias following coronary bypass surgery. Am J Surg. 1997 May;173(5):419-21.
Pehkonen EJ, Honkonen EL, Makynen PJ, Kataja MJ, Tarkka MR. Conduction disturbances after different blood cardioplegia modes in coronary artery bypass grafting. Including comparison with an earlier patient series. Scand J Thorac Cardiovasc Surg. 1996;30(3-4):149-55. [pmid: 8976035].
Pehkonen EJ, Makynen PJ, Kataja MJ, Tarkka MR. Atrial fibrillation after blood and crystalloid cardioplegia in CABG patients. Thorac Cardiovasc Surg. 1995 Aug;43(4):200-3.
Persson U, Silverberg R, Lindgren B, Norrving B, Jadback G, Johansson B, Puranen BI. Direct costs of stroke for a Swedish population. Int J Technol Assess Health Care. 1990;6(1):125-37. [pmid: 2113889].
Petersen P, Boysen G, Godtfredsen J, Andersen ED, Andersen B. Placebo-controlled, randomised trial of warfarin and aspirin for prevention of thromboembolic complications in chronic atrial fibrillation. The Copenhagen AFASAK study. Lancet. 1989 Jan 28;1(8631):175-9.
Petersen P, Kastrup J, Helweg Larsen S, Boysen G, Godtfredsen J. Risk factors for thromboembolic complications in chronic atrial fibrillation. The Copenhagen AFASAK study. Arch Intern Med. 1990 Apr;150(4):819-21.
Peverill RE, Harper RW, Gelman J, Gan TE, Harris G, Smolich JJ. Determinants of increased regional left atrial coagulation activity in patients with mitral stenosis. Circulation. 1996 Aug 1;94(3):331-9.
Pfisterer ME, Kloter-Weber UC, Huber M, Osswald S, Buser PT, Skarvan K, Stulz PM. Prevention of supraventricular tachyarrhythmias after open heart operation by low-dose sotalol: a prospective double-blind randomized placebo-controlled study. Ann Thorac Surg. 1997 Oct;64 (4):1113-9.
Phillips BG, Gandhi AJ, Sanoski CA, Just VL, Bauman JL. Comparison of intravenous diltiazem and verapamil for the acute treatment of atrial fibrillation and atrial flutter. Pharmacotherapy. 1997 Nov-Dec;17(6):1238-45.
Pietersen AH, Hellemann H. Usefulness of flecainide for prevention of paroxysmal atrial fibrillation and flutter. Danish-Norwegian Flecainide Multicenter Study Group. Am J Cardiol. 1991 Apr 1;67(8):713-7.
The Planning and Steering Committees of the AFFIRM study for the NHLBI AFFIRM investigators. Atrial fibrillation follow-up investigation of rhythm management-the AFFIRM study design. Am J Cardiol. 1997 May 1;79(9):1198-202.
Platia EV, Michelson EL, Porterfield JK, Das G. Esmolol versus verapamil in the acute treatment of atrial fibrillation or atrial flutter. Am J Cardiol. 1989 Apr 15;63(13):925-9.
Podesser B, Schwarzacher S, Zwolfer W, Binder TM, Spatt J, Peschl F, Huber S, Seitelberger R. Combined perioperative infusion of nifedipine and metoprolol provides antiischemic and antiarrhythmic protection in patients undergoing elective aortocoronary bypass surgery. Thorac Cardiovasc Surg. 1993 Jun;41(3):173-9.
Podesser B, Schwarzacher S, Zwolfer W, Binder TM, Spatt J, Peschl F, Huber S, Wolner E, Seitelberger R. Perioperative infusion of nifedipine and metoprolol provides antiischemic and antiarrhythmic protection in patients undergoing elective aortocoronary by-pass surgery. J Cardiovasc Surg (Torino). 1994 Dec;35(6 Suppl 1):233-5.
Podesser BK, Schwarzacher S, Zwoelfer W, Binder TM, Wolner E, Seitelberger R. Comparison of perioperative myocardial protection with nifedipine versus nifedipine and metoprolol in patients undergoing elective coronary artery bypass grafting. J Thorac Cardiovasc Surg. 1995 Nov;110(5):1461-9.
Polic S, Naranca M, Rumboldt Z, Bagatin J, Lukin A, Miric D. A prospective study on amiloride. II. Amiloride does not change the effect of digoxin in patients with heart failure. Pharmaca. 1995;33:203-12.
Polic S, Naranca M, Rumboldt Z, Lukin A, Bagatin J. A prospective study on amiloride. I. Does amiloride decrease the incidence of digoxin intoxication?. Pharmaca. 1995;33:191-201.
Polic S, Rumboldt Z, Dujic Z, Bagatin J, Deletis O, Rozga A. Role of digoxin in right ventricular failure due to chronic cor pulmonale. Int J Clin Pharmacol Res. 1990;10(3):153-62. [pmid: 2228340].
Pollak A, Falk RH. Aggravation of postcardioversion atrial dysfunction by sotalol. J Am Coll Cardiol. 1995 Mar 1;25(3):665-71.
Pomfret SM, Beasley CR, Challenor V, Holgate ST. Relative efficacy of oral verapamil and digoxin alone and in combination for the treatment of patients with chronic atrial fibrillation. Clin Sci. 1988 Apr;74(4):351-7.
Posada IS, Puebla V, Barriales V, Solar FG, Cubero GI, Suarez C, Pachon N, Moller I, Cortina A. Low quantities of acetylsalicylic acid in atrial fibrillation. Results of alternate day dosing. Eur Heart J. 1996;17.
Post WS, Larson MG, Levy D. Hemodynamic predictors of incident hypertension. The Framingham Heart Study. Hypertension. 1994 Nov;24(5):585-90.
Poungvarin N, Opartkiattikul N, Chaithiraphan S, Viriyavejakul A. A comparative study of coumadin and aspirin for primary cardioembolic stroke and thromboembolic preventions of chronic rheumatic mitral stenosis with atrial fibrillation. J Med Assoc Thai. 1994 Jan;77(1):1-6.
Pouwels MJ, Hooymans PM, van der Aa GC, Gribnau FW. Comparison of steady-state serum concentrations of digoxin in tablets (Lanoxin) and capsules (Lanoxicaps) in the elderly. DICP. 1991 Oct;25(10):1043-6.
[No authors listed]. Predictors of thromboembolism in atrial fibrillation: I. Clinical features of patients at risk. The Stroke Prevention in Atrial Fibrillation Investigators [see comments]. Ann Intern Med. 1992 Jan 1;116(1):1-5.
[No authors listed]. Predictors of thromboembolism in atrial fibrillation: II. Echocardiographic features of patients at risk. The Stroke Prevention in Atrial Fibrillation Investigators. Ann Intern Med. 1992 Jan 1;116(1):6-12.
Preliminary report of the Stroke Prevention in Atrial Fibrillation Study [see comments]. N Engl J Med. 1990 Mar 22;322(12):863-8.
Pritchett EL, McCarthy EA, Wilkinson WE. Propafenone treatment of symptomatic paroxysmal supraventricular arrhythmias. A randomized, placebo-controlled, crossover trial in patients tolerating oral therapy. Ann Intern Med. 1991 Apr 1;114(7):539-44.
Prystowsky EN, Benson DW Jr, Fuster V, Hart RG, Kay GN, Myerburg RJ, Naccarelli GV, Wyse DG. Management of patients with atrial fibrillation. A statement for healthcare professionals. From the Subcommittee on Electrocardiography and Electrophysiology, American Heart Association. Circulation. 1996 March 15;93(6):1262-77.
Ramsdale DR, Faragher EB, Bennett DH, Bray CL, Ward C, Cruickshank JM, Yusuf S, Sleight P. Ischemic pain relief in patients with acute myocardial infarction by intravenous atenolol. Am Heart J. 1982 Apr;103(4 Pt 1):459-67.
Ramus GV, Veglio F, Bonino ML, Tonda L. [Amiodarone and its infusion velocity in recent-onset atrial fibrillation]. G Ital Cardiol. 1991 Oct;21(10):1083-91.
[No authors listed]. Randomised double-blind comparison of reteplase double-bolus administration with streptokinase in acute myocardial infarction (INJECT): trial to investigate equivalence. International Joint Efficacy Comparison of Thrombolytics [see comments]. Lancet. 1995 Aug 5;346(8971):329-36.
[No authors listed]. A randomized, placebo-controlled trial of propafenone in the prophylaxis of paroxysmal supraventricular tachycardia and paroxysmal atrial fibrillation. UK Propafenone PSVT Study Group. Circulation. 1995 Nov 1;92(9):2550-7.
Rasmussen K, Wang H, Fausa D. Comparative efficiency of quinidine and verapamil in the maintenance of sinus rhythm after DC conversion of atrial fibrillation. A controlled clinical trial. Acta Med Scand Suppl. 1981;645:23-8. [pmid: 7015799].
Redfors A. Digoxin dosage and ventricular rate at rest and exercise in patients with atrial fibrillation. Acta Med Scand. 1971 Oct;190(4):321-33. [pmid: 5124263].
Redfors A. The effect of different digoxin doses on subjective symptoms and physical working capacity in patients with atrial fibrillation. Acta Med Scand. 1971 Oct;190(4):307-20. [pmid: 5124262].
Reimold SC, Cantillon CO, Friedman PL, Antman EM. Propafenone versus sotalol for suppression of recurrent symptomatic atrial fibrillation. Am J Cardiol. 1993 Mar 1;71(7):558-63.
Reimold SC, Lamas GA, Cantillon CO, Antman EM. Risk factors for the development of recurrent atrial fibrillation: role of pacing and clinical variables [see comments]. Am Heart J. 1995 Jun;129(6):1127-32.
Ribeiro LG, Kasdin SL, Snyder DL, Fischer MB, Irvin JD. Beneficial effects of timolol in digitalized patients with atrial fibrillation and a rapid ventricular response. Arq Bras Cardiol. 1986 Mar;46(3):211-5.
Richiardi E, Gaita F, Greco C, Gaschino G, Comba Costa G, Rosettani E, Brusca A. [Propafenone versus hydroquinidine in long-term pharmacological prophylaxis of atrial fibrillation]. Cardiologia. 1992 Feb;37(2):123-7.
Rinkenberger RL, Naccarelli GV, Berns E, Dougherty AH. Efficacy and safety of class IC antiarrhythmic agents for the treatment of coexisting supraventricular and ventricular tachycardia. Am J Cardiol. 1988 Aug 25;62(6):44D-55D.
Ritterman JB, Hossack KF, Bruce RA. Acute and chronic effects of diltiazem on A-V conduction at rest and during exercise. J Electrocardiol. 1982 Jan;15(1):41-6.
Rocca WA, Dorsey FC, Grigoletto F, Gent M, Roberts RS, Walker MD, Easton JD, Bruno R, Carolei A, Sancesario G, et al. Design and baseline results of the monosialoganglioside early stroke trial. The EST Study Group. Stroke. 1992 Apr;23(4):519-26.
Roffe C, Fletcher S, Woods KL. Investigation of the effects of intravenous magnesium sulphate on cardiac rhythm in acute myocardial infarction. Br Heart J. 1994 Feb;71(2):141-5.
Rognoni G, Occhetta E, Perucca A, Magnani A, Francalacci G. Reliability of single-chamber atrial pacing in sick sinus syndrome (SSS). New Trends Arrhythmias. 1993;9(2-4):669-73.
Roth A, Kaluski E, Felner S, Heller K, Laniado S. Clonidine for patients with rapid atrial fibrillation. Ann Intern Med. 1992 Mar 1;116(5):388-90.
Rubin DA, Nieminski KE, Reed GE, Herman MV. Predictors, prevention, and long-term prognosis of atrial fibrillation after coronary artery bypass graft operations. J Thorac Cardiovasc Surg. 1987 Sep;94(3):331-5.
Runsio M, Kallner A, Kallner G, Rosenqvist M, Bergfeldt L. Myocardial injury after electrical therapy for cardiac arrhythmias assessed by troponin-T release. Am J Cardiol. 1997 May 1;79(9):1241-5.
Sacco RL, Foulkes MA, Mohr JP, Wolf PA, Hier DB, Price TR. Determinants of early recurrence of cerebral infarction: The Stroke Data Bank. Stroke. 1989 Aug;20(8):983-9.
Sacco RL, Wolf PA, Kannel WB, McNamara PM. Survival and recurrence following stroke. The Framingham study. Stroke. 1982 May-Jun;13(3):290-5.
Saksena S, An H. Clinical efficacy of dual electrode systems for endocardial cardioversion of ventricular tachycardia: a prospective randomized crossover trial. Am Heart J. 1990 Jan;119(1):15-22.
Saksena S, An H, Mehra R, DeGroot P, Krol RB, Burkhardt E, Mehta D, John T. Prospective comparison of biphasic and monophasic shocks for implantable cardioverter-defibrillators using endocardial leads. Am J Cardiol. 1992 Aug 1;70(3):304-10.
Saksena S, Prakash A, Mangeon L, Varanasi S, Kolettis T, Mathew P, De Groot P, Mehra R, Krol RB. Clinical efficacy and safety of atrial defibrillation using biphasic shocks and current nonthoracotomy endocardial lead configurations. Am J Cardiol. 1995 Nov 1;76(12):913-21.
Salerno DM, Dias VC, Kleiger RE, Tschida VH, Sung RJ, Sami M, Giorgi LV. Efficacy and safety of intravenous diltiazem for treatment of atrial fibrillation and atrial flutter. The Diltiazem-Atrial Fibrillation/Flutter Study Group. Am J Cardiol. 1989 May 1;63(15):1046-51.
Sandercock P, Warlow C, Bamford J, Peto R, Starkey I. Is a controlled trial of long-term oral anticoagulants in patients with stroke and non-rheumatic atrial fibrillation worthwhile?. Lancet. 1986 Apr 5;(8484);1:788-92.
Santini M, Pandozi C, Toscano S, Castro A, Altamura G, Jesi A, Villani M. Changes in intracardiac atrial cardioversion threshold at rest and during exercise. J Am Coll Cardiol. 1997 Mar 1;29(3):576-81.
Satoh Y, Taniguchi K, Koike A, Adachi H, Yajima T, Iizumi T, Shiigai T, Hiroe M, Marumo F. Short-term effects of denopamine on anaerobic threshold and related parameters in patients with chronic heart failure: a double-blind crossover study. Clin Pharmacol Ther. 1993 May;53(5):562-9.
Satullo G, Arrigo F, Cavallaro L, Coglitore A, Fazio F, Saporito F, Sorrenti S, Oreto G. [Propafenone versus quinidine in recent onset atrial fibrillation]. Minerva Cardioangiol. 1996 Mar;44(3):141-4.
Scardi S, Humar F, Pandullo C, Poletti A. Oral clonidine for heart rate control in chronic atrial fibrillation [letter]. Lancet. 1993 May 8;341(8854):1211-2.
Scardi S, Mazzone C. [Anticoagulant prophylaxis: from clinical trials to clinical practice]. G Ital Cardiol. 1998 Feb;28(2):178-86.
Scardino R, Colao G, Didonato F, Sepe V. [Use of ajmaline in the therapy of various heart arrhythmias and comparison with the classic antiarrhythmic drug quinidine]. Minerva Med. 1970 Sep 29;61(78):4289-300.
Scemama M, Fevrier B, Beucler I, Dairou F. Lipid profile and antihypertensive efficacy in hyperlipidemic hypertensive patients: comparison of rilmenidine and captopril. J Cardiovasc Pharmacol. 1995;26(Suppl 2):S34-9.
Schenk KE, Schuren KP, Buschmann HJ, Dennert J, Meyer V, Ramdohr B, Schroder R. [Arrhythmias during digitalis treatment of patients with acute myocardial infarction]. Dtsch Med Wochenschr. 1971 Apr 16;96(16):663-70.
Schreck DM, Rivera AR, Tricarico VJ. Emergency management of atrial fibrillation and flutter: intravenous diltiazem versus intravenous digoxin. Ann Emerg Med. 1997 Jan;29(1):135-40.
Schwartz ML, Haider B, Covino BG, Co RG. Antiarrhythmic effectiveness of alprenolol, a new beta adrenergic receptor blocking agent. J Electrocardiol. 1970;30(4):211-6.
[No authors listed]. Secondary prevention in non-rheumatic atrial fibrillation after transient ischaemic attack or minor stroke. EAFT (European Atrial Fibrillation Trial) Study Group [see comments]. Lancet. 1993 Nov 20;342(8882):1255-62.
Sedgwick ML, Lip G, Rae AP, Cobbe SM. Chemical cardioversion of atrial fibrillation with intravenous dofetilide. Int J Cardiol. 1995 Apr;49(2):159-66.
Sedgwick ML, Rasmussen HS, Cobbe SM. Clinical and electrophysiologic effects of intravenous dofetilide (UK-68,798), a new class III antiarrhythmic drug, in patients with angina pectoris. Am J Cardiol. 1992 Feb 15;69(5):513-7.
Seitelberger R, Hannes W, Gleichauf M, Keilich M, Christoph M, Fasol R. Effects of diltiazem on perioperative ischemia, arrhythmias, and myocardial function in patients undergoing elective coronary bypass grafting. J Thorac Cardiovasc Surg. 1994 Mar;107(3):811-21.
Sellers TD, Kirchhoffer JB, Modesto TA. Adenosine: a clinical experience and comparison with verapamil for the termination of supraventricular tachycardias. Prog Clin Biol Res. 1987;230:283-99. [pmid: 3295883].
Sellevold OF, Berg EM, Levang OW. Procaine is effective for minimizing postischemic ventricular fibrillation in cardiac surgery. Anesth Analg. 1995 Nov;81(5):932-8.
Selzer A, Walter RM. Adequacy of preoperative digitalis therapy in controlling ventricular rate in postoperative atrial fibrillation. Circulation. 1966 Jul;34(1):119-22.
Sermasi S, Marconi M, Libero L, Moracchini PV, Rusconi L, Mininno A, Sigliano R. Italian experience with AutoCapture in conjunction with a membrane lead. Pacesetter Automatic Control of Energy and Membrane Automatic Threshold Evaluation (Pacemate) Study Group. Pacing Clin Electrophysiol. 1996 Nov;19(11 Pt 2):1799-804.
Seto TB, Taira DA, Tsevat J, Manning WJ. Cost-effectiveness of transesophageal echocardiographic-guided cardioversion: a decision analytic model for patients admitted to the hospital with atrial fibrillation. J Am Coll Cardiol. 1997 Jan;29(1):122-30.
Shakerinia T, Ali IM, Sullivan JA. Magnesium in cardioplegia: is it necessary?. Can J Surg. 1996 Oct;39(5):397-400.
Shandling AH, Crump R, Nolasco M, Lorenz LM, Li CK. The effect of chronic atrial overdrive suppression pacing on the incidence of supraventricular tachyarrhythmias. Clin Cardiol. 1992 Dec;15(12):917-22.
[No authors listed]. Silent brain infarction in nonrheumatic atrial fibrillation. EAFT Study Group. European Atrial Fibrillation Trial. Neurology. 1996 Jan;46(1):159-65.
Silvis SE, Nebel O, Rogers G, Sugawa C, Mandelstam P. Endoscopic complications. Results of the 1974 American Society for Gastrointestinal Endoscopy Survey. J Am Med Assoc. 1976 Mar 1;235(9):928-30.
Singer DE. Randomized trials of warfarin for atrial fibrillation [editorial; comment]. N Engl J Med. 1992 Nov 12;327(20):1451-3. [pmid: 1406862].
Singer DE, Hughes RA, Gress DR, Sheehan MA, Oertel LB, Maraventano SW, Blewett DR, Rosner B, Kistler JP. The effect of aspirin on the risk of stroke in patients with non-rheumatic atrial fibrillation: the BAATAF Study. Am Heart J. 1992 Dec;124(6):1567-73.
Singh BN. Antiarrhythmic drugs: a reorientation in light of recent developments in the control of disorders of rhythm. Am J Cardiol. 1998 March 19;81(6A):3D-13D.
Singh S, Saini RK, DiMarco J, Kluger J, Gold R, Chen YW. Efficacy and safety of sotalol in digitalized patients with chronic atrial fibrillation. The Sotalol Study Group. Am J Cardiol. 1991 Nov 1;68(11):1227-30.
Sloan MA, Price TR, Terrin ML, Forman S, Gore JM, Chaitman BR, Hodges M, Mueller H, Rogers WJ, Knatterud GL, Braunwald E. Ischemic cerebral infarction after rt-PA and heparin therapy for acute myocardial infarction. The TIMI-II pilot and randomized clinical trial combined experience. Stroke. 1997 Jun;28(6):1107-14.
Smedgard P, Kristensson BE, Kruse I, Ryden L. Rate-responsive pacing by means of activity sensing versus single rate ventricular pacing: a double-blind cross-over study. Pacing Clin Electrophysiol. 1987 Jul;10(4 Pt 1):902-15.
Smit AJ, Scaf AH, van Essen LH, Lie KI, Wesseling H. Digoxin infusion versus bolus injection in rapid atrial fibrillation: relation between serum level and response. Eur J Clin Pharmacol. 1990;38(4):335-41. [pmid: 2344857].
Smith EE, Shore DF, Monro JL, Ross JK. Oral verapamil fails to prevent supraventricular tachycardia following coronary artery surgery. Int J Cardiol. 1985 Sep;9(1):37-44.
Sodermark T, Jonsson B, Olsson A, Oro L, Wallin H, Edhag O, Sjogren A, Danielsson M, Rosenhamer G. Effect of quinidine on maintaining sinus rhythm after conversion of atrial fibrillation or flutter. A multicentre study from Stockholm. Br Heart J. 1975 May;37(5):486-92.
Solomon NA, Glick HA, Russo CJ, Lee J, Schulman KA. Patient preferences for stroke outcomes. Stroke. 1994 Sept;25(9):1721-5.
Sopher SM, Camm AJ. Atrial fibrillation: maintenance of sinus rhythm versus rate control. A Symposium: Supraventricular Arrhythmia: Update 1995. Am J Cardiol. 1996 Jan 25;77(3):24A-37A.
Soto Pedre E, Castro Beiras A, Cuna Estevez B. [The use of digitalis: a prospective study on the posology of digoxin with weekly interruption]. Rev Esp Cardiol. 1990 Aug-Sep;43(7):438-43.
Sramek JJ, Anand R, Wardle TS, Irwin P, Hartman RD, Cutler NR. Safety/tolerability trial of SDZ ENA 713 in patients with probable Alzheimer's disease. Life Sci. 1996;58(15):1201-7. [pmid: 8614273].
Stajduhar KC, Ott GY, Kron J, McAnulty JH, Oliver RP, Reynolds BT, Adler SW, Halperin BD. Optimal electrode position for transvenous defibrillation: a prospective randomized study. J Am Coll Cardiol. 1996 Jan;27(1):90-4.
Stambler BS, Beckman KJ, Kadish AH, Camm JA, Ellenbogen KA, Perry KT, VanderLugt JT. Acute hemodynamic effects of intravenous ibutilide in patients with or without reduced left ventricular function. Am J Cardiol. 1997 Aug 15;80(4):458-63.
Stambler BS, Wood MA, Ellenbogen KA. Comparative efficacy of intravenous ibutilide versus procainamide for enhancing termination of atrial flutter by atrial overdrive pacing. Am J Cardiol. 1996 May 1;77(11):960-6.
Stambler BS, Wood MA, Ellenbogen KA, Perry KT, Wakefield LK, VanderLugt JT. Efficacy and safety of repeated intravenous doses of ibutilide for rapid conversion of atrial flutter or fibrillation. Ibutilide Repeat Dose Study Investigators [see comments]. Circulation. 1996 Oct 1;94(7):1613-21.
Steering and Publications Committees of the ACUTE Study, for the ACUTE Investigators. Design of a clinical trial for the assessment of cardioversion using transesophageal echocardiography (The ACUTE Multicenter Study). Am J Cardiol. 1998 Apr 1;81(7):877-83.
Steinbeck G, Doliwa R, Bach P. [Therapy of paroxysmal atrial fibrillation. Cardiac glycosides alone or combined with anti-arrhythmia agents?]. Dtsch Med Wochenschr. 1988 Dec 2;113(48):1867-71.
Stephenson LW, MacVaugh H 3d, Tomasello DN, Josephson ME. Propranolol for prevention of postoperative cardiac arrhythmias: a randomized study. Ann Thorac Surg. 1980 Feb;29(2):113-6.
Stern EH, Pitchon R, King BD, Guerrero J, Schneider RR, Wiener I. Clinical use of oral verapamil in chronic and paroxysmal atrial fibrillation. Chest. 1982 Mar;81(3):308-11.
Stevens SK, Haffajee CI, Naccarelli GV, Schwartz KM, Luceri RM, Packer DL, Rubin AM, Kowey PR. Effects of oral propafenone on defibrillation and pacing thresholds in patients receiving implantable cardioverter-defibrillators. Propafenone Defibrillation Threshold Investigators. J Am Coll Cardiol. 1996 Aug;28(2):418-22.
Stone S, Holden A, Knapic N, Ansell J. Comparison between videotape and personalized patient education for anticoagulant therapy. J Fam Pract. 1989 Jul;29(1):55-7.
Storz H. [On the quantitative effectiveness of k-strophanthin-alpha (Cymarin) in intravenous and oral administration]. Dtsch Med Wochenschr. 1969 May 30;94(22):1166-9. [pmid: 5768542].
[No authors listed]. Stroke Prevention in Atrial Fibrillation Study. Final results [see comments]. Circulation. 1991 Aug;84(2):527-39.
Stroke Prevention in Atrial Fibrillation II Study [see comments]. Warfarin versus aspirin for prevention of thromboembolism in atrial fibrillation. Lancet. 1994 Mar 19;343(8899):687-91.
Stroke Prevention in Atrial Fibrillation III randomised clinical trial. Adjusted-dose warfarin versus low-intensity, fixed-dose warfarin plus aspirin for high-risk patients with atrial fibrillation. Lancet. 1996 Sept 7;348(9028):633-8.
Stroke Prevention in Atrial Fibrillation Investigators. A differential effect of aspirin on prevention of stroke in atrial fibrillation. J Stroke Cerebrovasc Dis. 1993;3:181-8.
Stroke Prevention in Atrial Fibrillation Investigators. The Stroke Prevention in Atrial Fibrillation III Study: Rationale, design, and patient features. J Stroke Cerebrovasc Dis. 1997;6(5):341-53. [pmid: 17895032].
Stroke Prevention in Atrial Fibrillation Investigators. Warfarin compared to aspirin for prevention of arterial thromboembolism in atrial fibrillation: design and patient characteristics of the SPAF II Study. Cerebrovasc Dis. 1992;2:332-41.
Stroke Prevention in Atrial Fibrillation Study Group Investigators. Preliminary report of the Stroke Prevention in Atrial Fibrillation Study. N Engl J Med. 1990 Mar 22;322(12):863-8.
Stroobandt R, Stiels B, Hoebrechts R. Propafenone for conversion and prophylaxis of atrial fibrillation. Propafenone Atrial Fibrillation Trial Investigators. Am J Cardiol. 1997 Feb 15;79(4):418-23.
Sulke N, Dritsas A, Bostock J, Wells A, Morris R, Sowton E. "Subclinical" pacemaker syndrome: a randomised study of symptom free patients with ventricular demand (VVI) pacemakers upgraded to dual chamber devices. Br Heart J. 1992 Jan;67(1):57-64.
Sulke N, Tan K, Kamalvand K, Bostock J, Bucknall C. Dual sensor VVIR mode pacing: is it worth it?. Pacing Clin Electrophysiol. 1996 Nov;19(11 Pt 1):1560-7.
Sullivan JM, Harken DE, Gorlin R. Pharmacologic control of thromboembolic complications of cardiac-valve replacement. A preliminary report. N Engl J Med. 1968 Sep 12;279(11):576-80.
Sun LS, Adams DC, Delphin E, Graham J, Meltzer E, Rose EA, Heyer EJ. Sympathetic response during cardiopulmonary bypass: mild versus moderate hypothermia. Crit Care Med. 1997 Dec;25(12):1990-3.
Sung RJ. Low-dose amiodarone should not be the first-line treatment for atrial fibrillation. Cardiovasc Drugs Ther. 1994 Oct;8(5):773-4. [pmid: 7873476].
Sung RJ, Tan HL, Karagounis L, Hanyok JJ, Falk R, Platia E, Das G, Hardy SA. Intravenous sotalol for the termination of supraventricular tachycardia and atrial fibrillation and flutter: a multicenter, randomized, double-blind, placebo-controlled study. Sotalol Multicenter Study Group. Am Heart J. 1995 Apr;129(4):739-48.
Supplemental figures, atrial fibrillation evidence report. Publication No. 00-R001. 1999. Available from the AHCPR Publications Clearinghouse, P.O. Box 8547, Silver Spring MD 20907 (1-800-358-9295).
Suttorp MJ, Kingma JH, Jessurun ER, Lie-A-Huen L, van Hemel NM, Lie KI. The value of class IC antiarrhythmic drugs for acute conversion of paroxysmal atrial fibrillation or flutter to sinus rhythm. J Am Coll Cardiol. 1990 Dec;16(7):1722-7.
Suttorp MJ, Kingma JH, Lie-A-Huen L, Mast EG. Intravenous flecainide versus verapamil for acute conversion of paroxysmal atrial fibrillation or flutter to sinus rhythm. Am J Cardiol. 1989 Mar 15;63(11):693-6.
Suttorp MJ, Kingma JH, Peels HO, Koomen EM, Tijssen JG, van Hemel NM, Defauw JA, Ernst SM. Effectiveness of sotalol in preventing supraventricular tachyarrhythmias shortly after coronary artery bypass grafting. Am J Cardiol. 1991 Nov 1;68(11):1163-9.
Sweany AE, Moncloa F, Vickers FF, Zupkis RV. Antiarrhythmic effects of intravenous timolol in supraventricular arrhythmia. Clin Pharmacol Ther. 1985 Feb;37(2):124-7.
Sweeney KG, Gray DP, Evans P, Steele R. Anticoagulation therapy: bleeding and thromboembolic complications. Lancet. 1996 Nov 23;348(9039):1456-7.
Sykes D, Dewar R, Mohanaruban K, Donovan K, Nicklason F, Thomas DM, Fisher D. Measuring blood pressure in the elderly: does atrial fibrillation increase observer variability? [see comments]. Br Med J. 1990 Jan 20;300(6718):162-3.
Szyszka A, Wachowiak Baszynska H, Kaczmarek J, Brocki Z, Ponizynski A. [Magnesium protects myocardium during electric cardioversion but does not increase effectiveness]. Kardiol Pol. 1993 Feb;38(2):98-101.
Szyszka A, Wachowiak Baszynska H, Paluszkiewicz L, Skorupski W, Brocki Z. [Preventive pharmacological treatment after cardiac electroversion for atrial fibrillation following surgical treatment of heart defects]. Kardiol Pol. 1992 Aug;37(8):74-8.
Tatarchenko IP, Ermolaeva NN, Oleinikov VE, Perevarin AV, Rakhmatullov FK. [Comparative study of the effectiveness of Bonnecor and ethacizine in various disorders of cardiac rhythm]. Klin Med (Mosk). 1991 Aug;69(8):60-2. [pmcid: 358319].
Teger-Nilsson AC, Dahlof C, Haglund E, Hedman C, Olsson G, Ablad B. Influence of metoprolol CR/ZOK on plasminogen activator inhibitor (PAI-1) in man: a pilot study. J Clin Pharmacol. 1990 Feb;30(2 Suppl):S132-7.
Teo KK. Evaluation of therapeutic modalities in patients with life threatening arrhythmias. Can J Cardiol. 1994 Apr;10(3):333-8. [pmid: 8162531].
Terent A, Marke LA, Asplund K, Norrving B, Jonsson E, Wester PO. Costs of stroke in Sweden. A national perspective. Stroke. 1994 Dec;25(12):2363-9.
Terzi A, Furlan G, Chiavacci P, Dal-Corso B, Luzzani A, Dalla Volta S. Prevention of atrial tachyarrhythmias after non-cardiac thoracic surgery by infusion of magnesium sulfate. Thorac Cardiovasc Surg. 1996 Dec;44(6):300-3.
Tezcan H, Okucu M, Fak AS, Oktay A. Efficacy and safety of intravenous diltiazem vs. verapamil in the acute treatment of atrial fibrillation. Turk Kardiyoloji Dernegi Arsivi. 1996 Sep;24(3):36-42+6.
Toivonen LK, Nieminen MS, Manninen V, Frick MH. Conversion of paroxysmal atrial fibrillation to sinus rhythm by intravenous pirmenol. A placebo controlled study. Br Heart J. 1986 Feb;55(2):176-80.
Toivonen LK, Nieminen MS, Manninen V, Frick H. Conversion of paroxysmal atrial fibrillation to sinus rhythm by intravenous pirmenol. Am J Cardiol. 1987 Jun 15;59(16):39H-42H.
Tomassoni G, Newby KH, Kearney MM, Brandon MJ, Barold H, Natale A. Testing different biphasic waveforms and capacitances: effect on atrial defibrillation threshold and pain perception. J Am Coll Cardiol. 1996 Sep;28(3):695-9.
Tommaso C, McDonough T, Parker M, Talano JV. Atrial fibrillation and flutter. Immediate control and conversion with intravenously administered verapamil. Arch Intern Med. 1983 May;143(5):877-81.
Touboul P, Brembilla-Perrot B, Scheck F, Gabriel A, Lardoux H, Marchand X, Levy S. [Randomized double-blind comparative study of the effects of cibenzoline and hydroquinidine in the prevention of atrial fibrillation]. Ann Cardiol Angeiol (Paris). 1995 Nov;44(9):525-31.
[No authors listed]. Treatment of atrial fibrillation and paroxysmal supraventricular tachycardia with bidisomide. The Atrial Fibrillation Investigation with Bidisomide (AFIB) Investigators. Circulation. 1997 Oct 21;96(8):2625-32.
Treglia A, Alfano C, Rossini E. [A comparison between propafenone and amiodarone in the conversion to sinus rhythm of atrial fibrillation of recent onset]. Minerva Cardioangiol. 1994 Jun;42(6):293-7.
Tucker KJ, Wilson C. A comparison of transoesophageal atrial pacing and direct current cardioversion for the termination of atrial flutter: a prospective randomised clinical trial. Br Heart J. 1993 Jun;69(6):530-5.
Turpie AG, Gent M, Laupacis A, Latour Y, Gunstensen J, Basile F, Klimek M, Hirsh J. A comparison of aspirin with placebo in patients treated with warfarin after heart-valve replacement [see comments]. N Engl J Med. 1993 Aug 19;329(8):524-9.
Turpie AG, Gunstensen J, Hirsh J, Nelson H, Gent M. Randomised comparison of two intensities of oral anticoagulant therapy after tissue heart valve replacement. Lancet. 1988 Jun 4;1(8597):1242-5.
UK Propafenone PSVT Study Group. A randomized, placebo-controlled trial of propafenone in the prophylaxis of paroxysmal supraventricular tachycardia and paroxysmal atrial fibrillation. Circulation. 1995 Nov 1;92(9):2550-7.
Ulvenstam G, Aberg A, Pennert K, Vedin A, Wedel H, Wilhelmsen L, Wilhelmsson C. Recurrent myocardial infarction: 2. Possibilities of prediction. Eur Heart J. 1985 Apr;6(4):303-11.
Urban and Vogel Workshop. [Atrial fibrillation-decision aids for ambulatory therapy]. Herz. 1995 Dec;20(Suppl 3):1-16.
U.S. Agency for Health Care Policy and Research. Post-Stroke Rehabilitation. Clinical Practice Guideline, No. 16. Rockville, MD: U.S. Department of Health and Human Services, Public Health Service. AHCPR publication No. 95-0062. May 1995.
Vaage-Nilsen M, Hansen JF, Mellemgaard K, Hagerup L, Sigurd B, Steinmetz E. Effect of verapamil on the prognosis of patients with early postinfarction electrical or mechanical complications. The Danish Verapamil Infarction Trial II (DAVIT II). Int J Cardiol. 1995 Mar 3;48(3):255-8.
Vaage-Nilsen M, Hansen JF, Mellemgaard K, Hagerup L, Sigurd B, Steinmetz E. Short- and long-term prognostic implications of in-hospital postinfarction arrhythmias. DAVIT II Study Group. Cardiology. 1995;86(1):49-55. [pmid: 7728788].
Valtonen M, Kanto J, Klossner J. Anaesthesia for cardioversion: a comparison of propofol and thiopentone. Can J Anaesth. 1988 Sep;35(5):479-83.
[No authors listed]. The value of quinidine therapy in order to maintain sinus rhythm after electrical rhythmization of atrial fibrillation. Klin Wochenschr. 1969;47.
Van Gelder IC, Brugemann J, Crijns HJ. Current treatment recommendations in antiarrhythmic therapy. Drugs. 1998 Mar;55(3):331-46.
Van Gelder IC, Crijns HJ. Cardioversion of atrial fibrillation and subsequent maintenance of sinus rhythm. Pacing Clin Electrophysiol. 1997 Oct;20(10 Pt. 2):2675-83.
Van Gelder IC, Crijns HJ, Van Gilst WH, Van Wijk LM, Hamer HP, Lie KI. Efficacy and safety of flecainide acetate in the maintenance of sinus rhythm after electrical cardioversion of chronic atrial fibrillation or atrial flutter. Am J Cardiol. 1989 Dec 1;64(19):1317-21.
van Latum JC. The European atrial fibrillation study: secondary prevention of thromboembolic complications with oral anticoagulants or acetylsalicylic acid in patients with non-rheumatic atrial fibrillation. Ned Tijdschr Geneeskd. 1994;138(5):1025-31.
van Latum JC, Koudstaal PJ, Venables GS, van Gijn J, Kappelle LJ, Algra A. Predictors of major vascular events in patients with a transient ischemic attack or minor ischemic stroke and with nonrheumatic atrial fibrillation. European Atrial Fibrillation Trial (EAFT) Study Group. Stroke. 1995 May;26(5):801-6.
Van Mieghem W, Coolen L, Malysse I, Lacquet LM, Deneffe GJ, Demedts MG. Amiodarone and the development of ARDS after lung surgery [see comments]. Chest. 1994 Jun;105(6):1642-5.
Van Mieghem W, Tits G, Demuynck K, Lacquet L, Deneffe G, Tjandra Maga T, Demedts M. Verapamil as prophylactic treatment for atrial fibrillation after lung operations. Ann Thorac Surg. 1996 Apr;61(4):1083-5.
van Wijk LM, den Heijer P, Crijns HJ, van Gilst WH, Lie KI. Flecainide versus quinidine in the prevention of paroxysms of atrial fibrillation. J Cardiovasc Pharmacol. 1989 Jan;13(1):32-6.
Vaughan-Williams EM. Classification of antiarrhythmic drugs. In: Sandoe E, Flenstedt-Jensen E, Olesen KH, eds. Symposium on Cardiac Arrhythmia. Sodertalje, Sweden: AB Astra. 1970, pp. 440-69.
Vaughan-Williams EM. A classification of antiarrhythmic actions reassessed after a decade of new drugs. J Clin Pharmacol. 1984 Apr;24(4):129-147. [pmid: 6144698].
Vaziri SM, Larson MG, Benjamin EJ, Levy D. Echocardiographic predictors of nonrheumatic atrial fibrillation [abstract]. J Am Coll Cardiol. 1993 Feb;21(2).
Venables G. Anticoagulation and stroke [letter]. Br Med J (Clin Res Ed). 1988 Jun 18;296(6638).
Vester EG. [Clinico-electrophysiologic effects of magnesium, especially in supraventricular tachycardia]. Herz. 1997 Jun;22(Suppl 1):40-50. [pmid: 9333591].
Villani GQ, Rosi A, Piepoli M, Gandolfini A, Groppi F, Groppi M, Arruzzoli S, Dieci G, Gazzola U. The efficacy of oral treatment with flecainide for paroxysmal atrial fibrillation: correlation with plasma concentration. G Ital Cardiol. 1990 Jun;20(6):564-8.
Villani R, Zoletti F, Veniani M, Locati F, Nava S. [A comparison between amiodarone and disopyramide in a delayed-release formulation in the prevention of recurrences of symptomatic atrial fibrillation]. Clin Ter. 1992 Jan;140(1 Pt 2):35-9.
Vitale P, Auricchio A, De Stefano R, Agretto A, De Simone R, Vitale N, Barbato F, Iacono A. Effectiveness of diltiazem in controlling ventricular response and improving exercise capacity in chronic atrial fibrillation. Double-blind, cross-over study. Cardiologia. 1989 Jan;34(1):73-81.
Wafa SS, Ward DE, Parker DJ, Camm AJ. Efficacy of flecainide acetate for atrial arrhythmias following coronary artery bypass grafting. Am J Cardiol. 1989 May 1;63(15):1058-64.
Waktare JE, Camm AJ. Acute treatment of atrial fibrillation: why and when to maintain sinus rhythm. Am J Cardiol. 1998 March 12;81(5A):3C-15C.
Waldo AL, Prystowsky EN. Drug treatment of atrial fibrillation in the managed care era. Am J Cardiol. 1998 Mar 12;81(5A):23C-9C.
Waller DG, Webster J, Sykes CA, Bhalla KK, Wray R. Clinical efficacy of xamoterol, a beta 1-adrenoceptor partial agonist, in mild to moderate heart failure. UK Xamoterol Study Group. Eur Heart J. 1989 Nov;10(11):1003-10.
Wandschneider W, Winter S, Thalmann M, Howanietz N, Deutsch M. Crystalloid versus blood cardioplegia in coronary by-pass surgery. A prospective randomized controlled study in 100 consecutive adults. J Cardiovasc Surg (Torino). 1994 Dec;35(6 Suppl 1):85-9.
Wang JA, Lau CP, Tai YT, Wu BZ. Effects of flecainide on exercise hemodynamics and electrocardiography in patients without structural heart disease. Clin Cardiol. 1995 Mar;18(3):140-4.
Wanless RS, Anderson K, Joy M, Joseph SP. Multicenter comparative study of the efficacy and safety of sotalol in the prophylactic treatment of patients with paroxysmal supraventricular tachyarrhythmias. Am Heart J. 1997 Apr;133(4):441-6.
[No authors listed]. Warfarin versus aspirin for prevention of thromboembolism in atrial fibrillation: Stroke Prevention in Atrial Fibrillation II Study [see comments]. Lancet. 1994 Mar 19;343(8899):687-91.
Waxman HL, Myerburg RJ, Appel R, Sung RJ. Verapamil for control of ventricular rate in paroxysmal supraventricular tachycardia and atrial fibrillation or flutter: a double-blind randomized cross-over study. Ann Intern Med. 1981 Jan;94(1):1-6.
Wen ZC, Chen SA, Tai CT, Chiang CE, Lee SH, Chen YJ, Yu WC, Huang JL, Chang MS. Temperature monitoring in radiofrequency catheter ablation of atrial flutter using the linear ablation technique. J Cardiovasc Electrophysiol. 1996 Nov;7(11):1050-7.
Whisnant JP, Fitzgibbons JP, Kurland LT, Sayre GP. Natural history of stroke in Rochester, Minnesota, 1945 through 1954. Stroke. 1971 Jan-Feb;2(1):11-22.
White HD, Antman EM, Glynn MA, Collins JJ, Cohn LH, Shemin RJ, Friedman PL. Efficacy and safety of timolol for prevention of supraventricular tachyarrhythmias after coronary artery bypass surgery. Circulation. 1984 Sep;70(3):479-84.
Wikner J, Larsen FF, Nordlander R, Pehrsson K, Astrom H. Exercise performance and beta-adrenergic blockade in patients with complete heart block treated with ventricular inhibited pacing. Clin Cardiol. 1991 Sep;14(9):749-52.
Wilhelmsson C, Vedin JA, Elmfeldt D, Tibblin G, Wilhelmsen L. Smoking and myocardial infarction. Lancet. 1975 Feb 22;1(7904):415-20.
Williams DO, Tatelbaum R, Most AS. Effective treatment of supraventricular arrhythmias with acebutolol. Am J Cardiol. 1979 Sep;44(3):521-5.
Winkle RA, Bach SM Jr, Mead RH, Gaudiani VA, Stinson EB, Fain ES, Schmidt P. Comparison of defibrillation efficacy in humans using a new catheter and superior vena cava spring-left ventricular patch electrodes. J Am Coll Cardiol. 1988 Feb;11(2):365-70.
Wiseman RA. Practolol -- analysis of clinical trials in cardiac dysrhythmias. Acta Cardiol. 1972;(Suppl 16):19-28. [pmid: 4119921].
Wistbacka JO, Kaukoranta PK, Nuutinen LS. Prebypass glucose-insulin-potassium infusion in elective nondiabetic coronary artery surgery patients [see comments]. J Cardiothorac Vasc Anesth. 1992 Oct;6(5):521-7.
Wistbacka JO, Koistinen J, Karlqvist KE, Lepojarvi MV, Hanhela R, Laurila J, Nissinen J, Pokela R, Salmela E, Ruokonen A, et al. Magnesium substitution in elective coronary artery surgery: a double-blind clinical study. J Cardiothorac Vasc Anesth. 1995 Apr;9(2):140-6.
Wolf PA, Abbott RD, Kannel WB. Atrial fibrillation: a major contributor to stroke in the elderly. The Framingham Study. Arch Intern Med. 1987 Sep;147(9):1561-4.
Wolf PA, Abbott, RD, Kannel WB. Atrial fibrillation as an independent risk factor for stroke: the Framingham Study. Stroke. 1991 Aug;22(8):983-8.
Wolf PA, D'Agostino RB, Belanger AJ, Kannel WB. Probability of stroke: a risk profile from the Framingham Study. Stroke. 1991 Mar;22(3):312-8.
Wolf PA, Dawber TR, Thomas HE Jr, Kannel WB. Epidemiologic assessment of chronic atrial fibrillation and risk of stroke: the Framingham Study. Neurology. 1978 Oct;28(10):973-7. [pmcid: 331413].
Wollert HG, Grossmann H, Eckel L. Magnesium sulfate prevents atrial tachyarrhythmias after cardiac and non-cardiac surgery-what is the common mechanism? [letter]. Thorac Cardiovasc Surg. 1997 Aug;45(4):213-4.
Wong CK, Lau CP, Leung WH, Cheng CH. Usefulness of labetalol in chronic atrial fibrillation. Am J Cardiol. 1990 Nov 15;66(17):1212-5.
Yamanouchi H, Mizutani T, Matsushita S, Esaki Y. Paroxysmal atrial fibrillation: high frequency of embolic brain infarction in elderly autopsy patients. Neurology. 1997 Dec;49(6):1691-4.
Yilmaz AT, Demirkilic U, Arslan M, Kurulay E, Ozal E, Tatar H, Ozturk O. Long-term prevention of atrial fibrillation after coronary artery bypass surgery: comparison of quinidine, verapamil, and amiodarone in maintaining sinus rhythm. J Card Surg. 1996 Jan-Feb;11(1):61-4.
Zasso A, Barbero F, Biasiolo A, Brocco T, Rampazzo P, Nante G, Pengo V. A trial of fixed "minidose" warfarin in non-rheumatic atrial fibrillation: MIWAF [abstract]. Thromb Haemost. 1997;Suppl 1:84-84.
Zehender M, Hohnloser S, Muller B, Meinertz T, Just H. Effects of amiodarone versus quinidine and verapamil in patients with chronic atrial fibrillation: results of a comparative study and a 2-year follow-up. J Am Coll Cardiol. 1992 Apr;19(5):1054-9.
Zehender M, Meinertz T, Just H. [Amiodarone and verapamil/quinidine in treatment of patients with chronic atrial fibrillation]. Z Kardiol. 1994;83(Suppl 5):101-8. [pmid: 7846938].
Zoble RG, Brewington J, Olukotun AY, Gore R. Comparative effects of nadolol-digoxin combination therapy and digoxin monotherapy for chronic atrial fibrillation. Am J Cardiol. 1987 Aug 31;60(6):39D-45D.