# References

Aberg H. Procaine amide as a prophylactic drug against atrial fibrillation. A controlled study. Nord Med. 1969 Aug 14;82(33):1011-3. [pmid: 5808590].
Aberg H, Cullhed I. Procaine amide quinidine as prophylactic drugs against relapse of atrial fibrillation. Nord Med. 1968 Jun 13;79(24):781-2.
Ahuja RC, Sinha N, Saran RK, Jain AK, Hasan M. Digoxin or verapamil or metoprolol for heart rate control in patients with mitral stenosis@@@151@@@a randomised cross-over study. Int J Cardiol. 1989 Dec;25(3):325-31.
Aliot E, Denjoy I. Comparison of the safety and efficacy of flecainide versus propafenone in hospital out-patients with symptomatic paroxysmal atrial fibrillation/flutter. The Flecainide AF French Study Group. Am J Cardiol. 1996 Jan 25;77(3):66A-71A.
Anderson JL, Gilbert EM, Alpert BL, Henthorn RW, Waldo AL, Bhandari AK, Hawkinson RW, Pritchett EL. Prevention of symptomatic recurrences of paroxysmal atrial fibrillation in patients initially tolerating antiarrhythmic therapy. A multi-center, double-blind, crossover study of flecainide and placebo with transtelephonic monitoring. Flecainide Supraventricular Tachycardia Study Group. Circulation. 1989;80:1557-70. [pmid: 2513143].
Ang EL, Chan WL, Cleland JG, Moore D, Krikler SJ, Alexander ND, Oakley CM. Placebo controlled trial of xamoterol versus digoxin in chronic atrial fibrillation. Br Heart J. 1990 Oct;64(4):256-60.
Ashraf T, Hay JW, Pitt B, Wittels E, Crouse J, Davidson M, Furbert CD, Radican L. Cost-effectiveness of pravastatin in secondary prevention of coronary heart disease. Am J Cardiol. 1996 Aug 15;78(4):409-14.
Assessment of Cardioversion Using Transesophageal Echocardiography. Design of a clinical trial for the Assessment of Cardioversion Using Transesophageal Echocardiography (The ACUTE Multicenter Study). The Steering and Publications Committees of the ACUTE Study, for the ACUTE Investigators. Am J Cardiol. 1998 Apr 1;81(7):877-83.
Atarashi H, Inoue H, Hiejima K, Hayakawa H. Conversion of recent-onset atrial fibrillation by a single oral dose of pilsicainide (Pilsicainide Suppression Trial on atrial fibrillation). The PSTAF Investigators. Am J Cardiol. 1996 Sept 15;78(6):694-7.
Atrial Fibrillation Follow-up Investigation of Rhythm Management the AFFIRM study design. The Planning and Steering Committees of the AFFIRM study for the NHLBI AFFIRM investigators. Am J Cardiol. 1997 May 1;79(9):1198-202.
The Atrial Fibrillation Investigation with Bidisomide (AFIB) Investigators. Treatment of atrial fibrillation and paroxysmal supraventricular tachycardia with bidisomide. Circulation. 1997 Oct 21;96(8):2625-32.
Atrial Fibrillation Investigators. Risk factors for stroke and efficacy of antithrombotic therapy in atrial fibrillation. Analysis of pooled data from five randomized controlled trials. Arch Intern Med. 1994 Jul 11;154(13):1449-57.
Atrial Fibrillation Investigators. Echocardiographic predictors of stroke in patients with atrial fibrillation. A prospective study of 1066 patients from 3 clinical trials. Arch Intern Med. 1998 June 22;158(12):1316-20.
Azpitarte J, Alvarez M, Baun O, Garcia R, Moreno E, Martin F, Tercedor L, Fernandez R. Value of single oral loading dose of propafenone in converting recent-onset atrial fibrillation. Results of a randomized, double-blind, controlled study. Eur Heart J. 1997 Oct;18(10):1649-54.
Babuty D, D'Hautefeuille B, Scheck F, Mycinsky C, Pruvost P, Peraudeau P. Cibenzoline versus flecainide in the prevention of paroxysmal atrial arrhythmias: a double-blind randomized study. J Clin Pharmacol. 1995 May;35(5):471-7.
Baldi N, Russo VA, Lenti V, Marasco G, Polimeni G, Conserva R, Tripaldi R, Montervino C. Relation between plasma levels and efficacy of flecainide and propafenone for treatment of atrial fibrillation of recent onset. New Trends Arrhythmias. 1993;9(2-4):899-906.
Baroffio R, Tisi G, Guzzini F, Milvio E, Annoni P. A randomised study comparing digoxin and propafenone in the treatment of recent onset atrial fibrillation. Clin Drug Invest. 1995;9(5):277-83.
Barranco F, Sanchez M, Rodriguez J, Guerrero M. Efficacy of flecainide in patients with supraventricular arrhythmia and respiratory insufficiency. Intensive Care Med. 1994;20:42-4. [pmid: 8163757].
Beck OA, Gunther R, Hochrein H. Conversion of chronic atrial fibrillation or flutter with disopyramide and a verapamil-quinidine combination: a comparative study. Dtsch Med Wochenschr. 1982 Sep 24;107(38):1419-23.
Beevers DG. Ultra low dose anticoagulation in atrial fibrillation. National Research Register 1995.
Bellandi F, Cantini F, Pedone T, Palchetti R, Bamoshmoosh M, Dabizzi RP. Effectiveness of intravenous propafenone for conversion of recent-onset atrial fibrillation: a placebo-controlled study. Clin Cardiol. 1995 Nov;18(11):631-4.
Bellandi F, Dabizzi RP, Cantini F, Natale MD, Niccoli L. Intravenous propafenone: efficacy and safety in the conversion to sinus rhythm of recent onset atrial fibrillation-a single-blind placebo-controlled study. Cardiovasc Drugs Ther. 1996 May;10(2):153-7.
Bellandi F, Dabizzi RP, Niccoli L, Cantini F. Propafenone and sotalol in the prevention of paroxysmal atrial fibrillation: long-term safety and efficacy study. Curr Ther Res. 1995 Nov;56(11):1154-68.
Bertini G, Conti A, Fradella G, Francardelli L, Giglioli C, Mangialavori G, Margheri M, Moschi G. Propafenone versus amiodarone in field treatment of primary atrial tachydysrhythmias. J Emerg Med. 1990 Jan-Feb;8(1):15-20.
Besson G, Bogousslavsky J. European Atrial Fibrillation Trial (EAFT). Secondary prevention with anticoagulants and aspirin in patients with non-valvular atrial fibrillation having suffered a transient ischemic attack or a regressive vascular accident. Rev Med Suisse Romande. 1991 Jan;111(1):49-55.
Bialy D, Lehmann MH, Schumacher DN, Steinman RT, Meissner MD. Hospitalization for arrhythmias in the United States: importance of atrial fibrillation [abstract]. J Am Coll Cardiol. 1992 March 1;19(3).
Bianconi L, Mennuni M, Lukic V, Castro A, Chieffi M, Santini M. Effects of oral propafenone administration before electrical cardioversion of chronic atrial fibrillation: a placebo-controlled study. J Am Coll Cardiol. 1996 Sept;28(3):700-6.
Bianconi L, Mennuni M, Lukic V, Tassoni G, Santini M. Pretreatment with oral propafenone in electrical cardioversion of chronic atrial fibrillation. New Trends Arrhythmias. 1993;9(2-4):1017-20.
Bjerkelund C, Orning OM. Kinidin-duetter and quinidine sulphate in the prevention of atrial fibrillation. A comparison. Nord Med. 1967 Mar 30;77(13):405-7.
Blackshear JL. Relative risk of atrial thrombus one month after randomization to therapy is similar to thromboembolic outcome after 1.1 years in nonrheumatic fibrillation. Cerebrovasc Dis. 1997;7.
Bloch TPE, Andersen HR. The first prospective randomised trial of atrial versus ventricular pacing in sick sinus syndrome-at last. Eur J Card Pacing Electrophysiol. 1995;5:124-5.
Boriani G, Biff M, Capucci A, Botto GL, Broffoni T, Rubino I, Della-Casa S, Sanguinetti M, Magnani B. Oral propafenone to convert recent-onset atrial fibrillation in patients with and without underlying heart disease. A randomized, controlled trial. Ann Intern Med. 1997 Apr 15;126(8):621-5.
Boriani G, Capucci A, Lenzi T, Sanguinetti M, Magnani B. Propafenone for conversion of recent-onset atrial fibrillation. A controlled comparison between oral loading dose and intravenous administration. Chest. 1995 Aug;108(2):355-8.
[No authors listed]. The Boston Area Anticoagulation Trial for Atrial Fibrillation Investigators [see comments]. The effect of low-dose warfarin on the risk of stroke in patients with nonrheumatic atrial fibrillation. N Engl J Med. 1990 Nov 29;323(22):1505-11.
Botto GL, Capucci A, Bonini W, Boriani G, Broffoni T, Barone P, Espureo M, Lombardi R, Molteni S, Ferrari G. Conversion of recent onset atrial fibrillation to sinus rhythm using a single oral loading dose of propafenone: comparison of two regimens. Int J Cardiol. 1997 Jan 3;58(1):55-61.
Boudonas G, Lefkos N, Efthymiadis AP, Styliadis IG, Tsapas G. Intravenous administration of diltiazem in the treatment of supraventricular tachyarrhythmias. Acta Cardiol. 1995;50(2):125-34. [pmid: 7610735].
Bowen J, Yaste C. Effect of a stroke protocol on hospital costs of stroke patients. Neurology. 1994 Oct;44(10):1961-4. [pmcid: 153508].
Brand FN, Abbott RD, Kannel WB, Wolf PA. Characteristics and prognosis of lone atrial fibrillation: 30-year follow-up in the Framingham Study. JAMA. 1985 Dec 27;254(24):3449-53.
Brodsky MA, Orlov MV, Capparelli EV, Allen BJ, Iseri LT, Ginkel M, Orlov YS. Magnesium therapy in new-onset atrial fibrillation. Am J Cardiol. 1994 June 15;73(16):1227-9.
Brodsky M, Saini R, Bellinger R, Zoble R, Weiss R, Powers L. Comparative effects of the combination of digoxin and dl-sotalol therapy versus digoxin monotherapy for control of ventricular response in chronic atrial fibrillation. dl-Sotalol Atrial Fibrillation Study Group. Am Heart J. 1994 Mar;127(3):572-7.
Byrne-Quinn E, Wing A J. Maintenance of sinus rhythm after DC reversion of atrial fibrillation. A double-blind controlled trial of long-acting quinidine bisulphate. Br Heart J. 1970 May;32(3):370-6.
Camm AJ, Bashir Y. Clinical trials of flecainide acetate in the management of supraventricular arrhythmias [editorial]. Cardiologia. 1990 Mar;35(3):193-7.
Capucci A, Boriani G, Rubino I, Della Casa S, Sanguinetti M, Magnani B. A controlled study on oral propafenone versus digoxin plus quinidine in converting recent onset atrial fibrillation to sinus rhythm. Int J Cardiol. 1994 Mar 1;43(3):305-13.
Capucci A, Lenzi T, Boriani G, Trisolino G, Binetti N, Cavazza M, Fontana G, Magnani B. Effectiveness of loading oral flecainide for converting recent-onset atrial fibrillation to sinus rhythm in patients without organic heart disease or with only systemic hypertension [see comments]. Am J Cardiol. 1992 July 1;70(1):69-72.
The Cardiac Arrhythmia Suppression Trial (CAST) Investigators. Preliminary report: effect of encainide and flecainide on mortality in a randomized trial of arrhythmia suppression after myocardial infarction. N Engl J Med. 1989 Aug 10;321(6):406-12.
Cardinale V, editor. Drug Topics Red Book. Oradell, NJ: Medical Economics; 1997.
Carunchio A, Fera MS, Mazza A, Burattini M, Grego G, Galati A, Ceci V. A comparison between flecainide and sotalol in the prevention of recurrences of paroxysmal atrial fibrillation. G Ital Cardiol. 1995;25:51-68. [pmid: 7642012].
César LA, Serrano CV, Pamplona D, D'Avila AL, Ferreira JoFM, Amato RV, Pfeferman E, Scanavacca MC, Sosa EA, Bellotti G. Fibrilaçäo atrial aguda na unidade de emergência: qual a droga ideal para rápida reversäo ao ritmo sinusal? Acute atrial fibrillation: which is the best drug for sinus rhythm conversion in the emergency room?. Arq Bras Cardiol. 1994;63:481-4. [pmid: 7605232].
Channer KS, James MA, MacConnell T, Rees JR. Beta-adrenoceptor blockers in atrial fibrillation: the importance of partial agonist activity [see comments]. Br J Clin Pharmacol. 1994 Jan;37(1):53-7.
Channer KS, Papouchado M, James MA, Pitcher DW, Rees JR. Towards improved control of atrial fibrillation. Eur Heart J. 1987 Feb;8(2):141-7.
Chiquette E, Amato MG, Bussey HI. Comparison of an anticoagulation clinic with usual medical care: anticoagulation control, patient outcomes, and health care costs. Arch Intern Med. 1998 Aug 10-24;158(15):1641-7.
Chung MK, Schweikert RA, Wilkoff BL, Niebauer MJ, Pinski SL, Trohman RG, Kidwell GA, Jaeger FJ, Morant VA, Miller DP, Tchou PJ. Is hospital admission for initiation of antiarrhythmic therapy with sotalol for atrial arrhythmias required? Yield of in-hospital monitoring and predicting of risk for significant arrhythmia complications. J Am Coll Cardiol. 1998 Jul;32(1):169-76.
Cobbe SM. Using the right drug. A treatment algorithm for AF. Eur Heart J. 1997 May;18(Suppl C):C33-9. [pmid: 9152673].
Connolly SJ, Hoffert DL. Usefulness of propafenone for recurrent paroxysmal atrial fibrillation. Am J Cardiol. 1989 Apr 1;63(2):817-9.
Connolly SJ, Laupacis A, Gent M, Roberts RS, Cairns JA, Joyner C. Canadian Atrial Fibrillation Anticoagulation (CAFA) Study. J Am Coll Cardiol. 1991 Aug;18(2):349-55.
Coplen SE, Antman EM, Berlin JA, Hewitt P, Chalmers TC. Efficacy and safety of quinidine therapy for maintenance of sinus rhythm after cardioversion. A meta-analysis of randomized control trials. Circulation. 1990 Oct;82(4):1106-16.
Cowan JC, Gardiner P, Reid DS, Newell DJ, Campbell RW. A comparison of amiodarone and digoxin in the treatment of atrial fibrillation complicating suspected acute myocardial infarction. J Cardiovasc Pharmacol. 1986 Mar-Apr;8(2):252-6.
Cramer G. Arrhythmia. 8. Quinidine for the maintenance of the sinus rhythm after regularization. Lakartidningen. 1971 Jan 14;Suppl II.
Crijns HJ, Gosselink AT, Lie KI. Propafenone versus disopyramide for maintenance of sinus rhythm after electrical cardioversion of chronic atrial fibrillation: a randomized, double-blind study. PRODIS Study Group. Cardiovasc Drugs Ther. 1996 May;10(2):145-52.
Crijns HJ, van Wijk LM, van Gilst WH, Kingma JH, van Gelder IC, Lie KI. Acute conversion of atrial fibrillation to sinus rhythm: clinical efficacy of flecainide acetate. Comparison of two regimens. Eur Heart J. 1988 Jun;9(6):634-8.
Dahlstrom CG, Edvardsson N, Nasheng C, Olsson SB. Effects of diltiazem, propranolol, and their combination in the control of atrial fibrillation. Clin Cardiol. 1992 Apr;15(4):280-4.
Dawson J, Cockel R. Oesophageal perforation at fibreoptic gastroscopy. Br Med J. 1981 Aug;283(6291):583-5.
De Vil C, Bruyneel K. Cardioversion and treatment of chronic atrial dysrhythmias with guinidine or lidoflazine: a comparative study. Acta Cardiol. 1974;29(5):383-98. [pmid: 4615536].
Dennis MS, Burn JPS, Sandercock PA, Bamford JM, Wade DT, Warlow CP. Long-term survival after first-ever stroke: the Oxfordshire Community stroke project. Stroke. 1993 Jun;24(6):796-800.
Detsky AS, Naylor CD, O'Rourke K, McGeer AJ, L'Abbe KA. Incorporating variations in the quality of individual randomized trials into meta-analysis. J Clin Epidemiol. 1992 Mar;45(3):255-65.
DiBianco R, Morganroth J, Freitag JA, Ronan JA Jr, Lindgren KM, Donohue DJ, Larca LJ, Chadda KD, Olukotun AY. Effects of nadolol on the spontaneous and exercise-provoked heart rate of patients with chronic atrial fibrillation receiving stable dosages of digoxin. Am Heart J. 1984 Oct;108(4 pt 2):1121-7.
The Digitalis in Acute Atrial Fibrillation (DAAF) Trial Group. Intravenous digoxin in acute atrial fibrillation. Results of a randomized, placebo-controlled multicentre trial in 239 patients. Eur Heart J. 1997Apr;18(4):649-54.
Donovan KD, Dobb GJ, Coombs LJ, Lee KY, Weekes JN, Murdock CJ, Clarke GM. Efficacy of flecainide for the reversion of acute onset atrial fibrillation. Am J Cardiol. 1992 Aug 20;70(5):50A-54A.
EAFT (European Atrial Fibrillation Trial) Study Group [see comments]. Secondary prevention in non-rheumatic atrial fibrillation after transient ischaemic attack or minor stroke. Lancet. 1993 Nov 20;342(8882):1255-62.
Eckman MH, Levine HJ. Pauker SG. Decision analytic and cost-effectiveness issues concerning anticoagulant prophylaxis in heart disease. Chest. 1992 Oct;102(4 suppl):538S-49S.
Effert S, Merx W. [On the treatment of atrial fibrillation following surgery of mitral stenosis]. Dtsch Med Wochenschr. 1967 Apr 14;92(15):691-5.
Ellenbogen KA, Dias VC, Plumb VJ, Heywood JT, Mirvis DM. A placebo-controlled trial of continuous intravenous diltiazem infusion for 24-hour heart rate control during atrial fibrillation and atrial flutter: a multi center study. J Am Coll Cardiol. 1991 Oct;18(4):891-7.
Ellenbogen KA, Stambler BS, Wood MA, Sager PT, Wesley RC Jr, Meissner MC, Zoble RG, Wakefield LK, Perry KT, Vanderlugt JT. Efficacy of intravenous ibutilide for rapid termination of atrial fibrillation and atrial flutter: a dose-response study. J Am Coll Cardiol. 1996 Jul;28(1):130-6.
Embolic complications in atrial fibrillation. [Data of the Studio Italiano Fibrillazione Atriale (SIFA)]. G Chir. 1995 Mar;16(13):137-9.
Ezekowitz MD, Bridgers SL, James KE, Carliner NH, Colling CL, Gornick CC, Krause-Steinrauf H, Kurtzke JF, Nazarian SM, Radford MJ, et al. Warfarin in the prevention of stroke associated with nonrheumatic atrial fibrillation. Veterans Affairs Stroke Prevention in Nonrheumatic Atrial Fibrillation Investigators [see comments]. N Engl J Med. 1992 Nov 12;327(20):1406-12.
Falk RH. Proarrhythmia in patients treated for atrial fibrillation or flutter. Ann Intern Med. 1992 Jul 15;117(2):141-50. [pmid: 1605429].
Falk RH, Knowlton AA, Bernard SA, Gotlieb NE, Battinelli NJ. Digoxin for converting recent-onset atrial fibrillation to sinus rhythm. A randomized, double-blinded trial. Ann Intern Med. 1987 Apr;106(4):503-6.
Falk RH, Pollak A, Singh SN, Friedrich T. Intravenous dofetilide, a class III antiarrhythmic agent, for the termination of sustained atrial fibrillation or flutter. Intravenous Dofetilide Investigators [see comments]. J Am Coll Cardiol. 1997 Feb;29(2):385-90.
Feinberg WM, Bovill EG, Nightingale SD, Cornell ES, Koehler JL. Assessing optimal intensity of anticoagulation in patients with atrial fibrillation: prothrombin fragment F1.2 levels compared to Inr. Twenty-first International Joint Conference on Stroke and Cerebral Circulation, 1997.
Feld GK, Nademanee K, Noll E, Singh BN. Oral N-acetylprocainamide compared to quinidine plus digoxin in the chronic suppression of atrial flutter in humans. Cardiovasc Drugs Ther. 1989 Apr;3(2):191-8.
Fihn SD, McDonell M, Martin D, Henikoff J, Vermes D, Kent D, White RH, for the Warfarin Optimized Outpatient Follow-up Study Group. Risk factors for complications of chronic anticoagulation. A multicenter study. Ann Intern Med. 1993 Apr 1;118(7):511-20.
Flegel KM, Shipley MJ, Rose G. Risk of stroke in non-rheumatic atrial fibrillation. Lancet. 1987 Mar 7;1(8532):526-29.
Frances Y, Luccioni R, Delaage M, Donnarel G, Medvedowsky JL, Quiret JC. [Long-term prevention of the recurrence of auricular fibrillation using cibenzoline. Multicenter study apropos of 89 case reports]. Arch Mal Coeur Vaiss. 1985 Oct;78(Spec No):99-103. [pmid: 3938266].
Fresco C, Proclemer A, Pavan A, Buia G, Vicentini A, Pavan D, Morgera T. Intravenous propafenone in paroxysmal atrial fibrillation: a randomized, placebo-controlled, double-blind, multicenter clinical trial. Paroxysmal Atrial Fibrillation Italian Trial (PAFIT)-2 Investigators. Clin Cardiol. 1996 May;19(5):409-12.
Furberg CD, Psaty BM, Manolio TA, Gardin JM, Smith VE, Rautaharju PM, for the CHS Collaborative Research Group. Prevalence of atrial fibrillation in elderly subjects (the Cardiovascular Health Study). Am J Cardiol. 1994 Aug 1;74(3):236-41.
Gage BF, Cardinalli AB, Albers GW, Owens DK. Cost-effectiveness of warfarin and aspirin for prophylaxis of stroke in patients with nonvalvular atrial fibrillation. J Am Med Assoc. 1995 Dec 20;274(23):1839-45.
Gage BF, Cardinalli AB, Owens DK. The effect of stroke and stroke prophylaxis with aspirin or warfarin on quality of life. Arch Intern Med. 1996 Sep 9;156(16):1829-36.
Gage BF, Cardinalli AB, Owens DK. Cost-effectiveness of preference-based antithrombotic therapy for patients with nonvalvular atrial fibrillation. Stroke. 1998 Jun;29(6):1083-91.
Garner TI, Dardis R. Cost-effectiveness analysis of end-stage renal disease treatments. Med Care. 1987;25(1):25-34. [pmid: 3100878].
Gold MR, Siegel JE, Russell LB, Weinstein MD, eds. Cost-Effectiveness in Health and Medicine. New York: Oxford Univ Press; 1996.
Goldenberg IF, Lewis WR, Dias VC, Heywood JT, Pedersen WR. Intravenous diltiazem for the treatment of patients with atrial fibrillation or flutter and moderate to severe congestive heart failure [see comments]. Am J Cardiol. 1994 Nov 1;74(9):884-9.
Gullestad L, Birkeland K, Molstad P, Hoyer MM, Vanberg P, Kjekshus J. The effect of magnesium versus verapamil on supraventricular arrhythmias. Clin Cardiol. 1993 May;16(5):429-34.
Gullov AL, Koefoed BG, Petersen P. The AFASAK 2 study: atrial fibrillation, aspirin and anticoagulant therapy. Proceedings of the 7 ^ th ^ Scandinavian Meeting on Cerebrovascular Disease. 1993:34.
Gullov AL, Koefoed BG, Petersen P, Pedersen TS, Andersen ED, Godtfredsen J, Boysen G. Fixed minidose warfarin and aspirin alone and in combination vs. adjusted-dose warfarin for stroke prevention in atrial fibrillation. Second Copenhagen Atrial Fibrillation, Aspirin, and Anticoagulation Study. Arch Intern Med. 1998;158:1513-21. [pmid: 9679792].
Guo GB, Ellenbogen KA, Wood MA, Stambler BS. Conversion of atrial flutter by ibutilide is associated with increased atrial cycle length variability. J Am Coll Cardiol. 1996 Apr;27(5):1083-9.
Halinen MO, Huttunen M, Paakkinen S, Tarssanen L. Comparison of sotalol with digoxin-quinidine for conversion of acute atrial fibrillation to sinus rhythm (the Sotalol-Digoxin-Quinidine Trial). Am J Cardiol. 1995 Sept 1;76(7):495-8.
Harenberg J, Weuster B, Pfitzer M, Dempfle CE, Stehle G, Kubler W, Schlierf G. Prophylaxis of embolic events in patients with atrial fibrillation using low molecular weight heparin. Semin Thromb Hemost. 1993;19 Suppl (1):116-21. [pmid: 8395713].
Hart RG. A differential effect of aspirin in the Stroke Prevention in Atrial Fibrillation Study. Cerebrovasc Dis. 1992;2.
Hartel G, Louhija A, Halonen PI. Investigations on the value of quinidine therapy after electrical rhythmization of atrial fibrillation. Med Welt. 1969;20.
Hartel G, Louhija A, Konttinen A. Disopyramide in the prevention of recurrence of atrial fibrillation after electroconversion. Clin Pharmacol Ther. 1974 Jun;15(6):551-5.
Hays JV, Gilman JK, Rubal BJ. Effect of magnesium sulfate on ventricular rate control in atrial fibrillation. Ann Emerg Med. 1994 Jul;24(1):61-4.
Hillestad L, Bjerkelund C, Dale J, Maltau J, Storstein O. Quinidine in maintenance of sinus rhythm after electroconversion of chronic atrial fibrillation. A controlled study. Br Heart J. 1971 Jul;33(4):518-21.
Hilner BE, Smith TJ, Desch CE. Efficacy and cost-effectiveness of autologous bone marrow transplantation in metastatic breast cancer: estimates using decision analysis while awaiting clinical trial results. J Am Med Assoc. 1992 Apr 15;267(15):2055-61.
Hohnloser SH, Kuck KH. Atrial fibrillation: maintaining stability of sinus rhythm or ventricular rate control? The need for prospective data: the PIAF trial. Pacing Clin Electrophysiol. 1997 Aug;20(8 Pt 1):1989-92.
Hohnloser SH, Li YG. Drug treatment of atrial fibrillation: what have we learned?. Curr Opin Cardiol. 1997 Jan;12(1):24-32.
Hohnloser SH, van de Loo A, Baedeker F. Efficacy and proarrhythmic hazards of pharmacologic cardioversion of atrial fibrillation: prospective comparison of sotalol versus quinidine. J Am Coll Cardiol. 1995 Oct;26(4):852-8.
Hou ZY, Chang MS, Chen CY, Tu MS, Lin SL, Chiang HT, Woosley RL. Acute treatment of recent-onset atrial fibrillation and flutter with a tailored dosing regimen of intravenous amiodarone. A randomized, digoxin-controlled study [see comments]. Eur Heart J. 1995 Apr;16(4):521-8.
Ingall TJ and the SPAF Investigators. Transesophageal echocardiographic correlates of thromboembolism in high-risk patients with atrial fibrillation. Stroke Society of Australasia Annual Scientific Meeting, 1997.
Innes GD, Vertesi L, Dillon EC, Metcalfe C. Effectiveness of verapamil-quinidine versus digoxin-quinidine in the emergency department treatment of paroxysmal atrial fibrillation. Ann Emerg Med. 1997 Jan;29(1):126-34.
Ioannidis JP, Lau J. The impact of high-risk patients on the results of clinical trials. J Clin Epidemiol. 1997 Oct;50(10):1089-98.
Is hospitalisation necessary for recent-onset atrial fibrillation?. S Afr Med J. 1997 Jun;87(Suppl 3).
James MA, Channer KS, Papouchado M, Rees JR. Improved control of atrial fibrillation with combined pindolol and digoxin therapy. Eur Heart J. 1989 Jan;10(1):83-90.
Jordaens L, Trouerbach J, Calle P, Tavernier R, Derycke E, Vertongen P, Bergez B, Vandekerckhove Y. Conversion of atrial fibrillation to sinus rhythm and rate control by digoxin in comparison to placebo [see comments]. Eur Heart J. 1997 Apr;18(4):643-8.
Joshi PP, Deshmukh PK, Salkar RG. Efficacy of intravenous magnesium sulphate in supraventricular tachyarrhythmias [see comments]. J Assoc Physicians India. 1995 Aug;43(8):529-31.
Justice AC, Cho MK, Winker MA, Berlin JA, Rennie D. Does masking author identity improve peer view quality? A randomized controlled trial. PEER investigators. J Am Med Assoc. 1998 Jul 15;280(3):240-2.
Juul-Moller S, Edvardsson N, Rehnqvist-Ahlberg N. Sotalol versus quinidine for the maintenance of sinus rhythm after direct current conversion of atrial fibrillation [see comments]. Circulation. 1990 Dec;82:1932-9. [pmid: 2242519].
Kannel WB, Abbott RD, Savage DD, McNamara PM. Epidemiologic features of chronic atrial fibrillation: the Framingham Study. N Engl J Med. 1982 Apr 29;306(17):1018-22.
Kannel WB, Abbott RD, Savage DD, McNamara PM. Coronary heart disease and atrial fibrillation: the Framingham Study. Am Heart J. 1983 Aug;106(2):389-96.
Karlson BW, Torstensson I, Abjorn C, Jansson SO, Peterson LE. Disopyramide in the maintenance of sinus rhythm after electroconversion of atrial fibrillation. A placebo-controlled one-year follow-up study. Eur Heart J. 1988 Mar;9(3):284-90.
Karlson BW, Torstensson I, Abjorn C, Kallryd A, Jonsson SO, Peterson LE. [Preventive disopyramide after electroconversion of atrial fibrillation-a good alternative]. Lakartidningen. 1991 Jun 12;88(24):2242-5.
Kingma JH, Suttorp MJ. Acute pharmacologic conversion of atrial fibrillation and flutter: the role of flecainide, propafenone, and verapamil. Am J Cardiol. 1992 Aug 20;70(5):56A-60A.
Klein AL, Grimm RA, Black IW, Leung DY, Chung MK, Vaughn SE, Murray RD, Miller DP, Arheart KL. Cardioversion guided by transesophageal echocardiography: the ACUTE Pilot Study. A randomized, controlled trial. Assessment of Cardioversion Using Transesophageal Echocardiography [see comments]. Ann Intern Med. 1997 Feb 1;126(3):200-9.
Koefoed BG, Gullov AL, Petersen P. The AFASAK 2 study. Atrial fibrillation, aspirin and anticoagulant therapy. Second International Conference on Stroke. 1993;1.
Koefoed B, Gullov A, Petersen P. Second Copenhagen atrial fibrillation, aspirin and anticoagulant therapy study method and design. Thrombo and Thrombolysis. 1995;2:125-30.
Koefoed BG, Gullov AL, Petersen P, Petersen T, Boysen G, Godtfredsen J, Andersen ED. The Second Copenhagen Atrial fibrillation, aspirin and anticoagulant therapy study (AFASAK 2). Progress of the Study. Twenty-Second International Joint Conference on Stroke and Cerebral Circulation, 1997.
Koh KK, Kwon KS, Park HB, Baik SH, Park SJ, Lee KH, Kim EJ, Kim SH, Cho SK, Kim SS. Efficacy and safety of digoxin alone and in combination with low-dose diltiazem or betaxolol to control ventricular rate in chronic atrial fibrillation. Am J Cardiol. 1995 Jan;75(1):88-90.
Koh KK, Song JH, Kwon KS, Park HB, Baik SH, Park YS, In HH, Moon TH, Park GS, Cho SK, et al. Comparative study of efficacy and safety of low-dose diltiazem or betaxolol in combination with digoxin to control ventricular rate in chronic atrial fibrillation: randomized crossover study. Int J Cardiol. 1995 Nov 24;52(2):167-74.
Kondili A, Kastrati A, Popa Y. Comparative evaluation of verapamil, flecainide and propafenone for the acute conversion of atrial fibrillation to sinus rhythm. Wien Klin Wochenschr. 1990;102(17):510-3. [pmid: 2124756].
Kopecky SL, Gersh BJ, McGoon MD, Whisnant JP, Holmes DR Jr, Ilstrup DM, Frye RL. The natural history of lone atrial fibrillation. A population-based study over three decades. N Engl J Med. 1987 Sept 10;317(11):669-74.
Koudstaal PJ. [Prevention of a brain infarct in patients with non-rheumatic atrial fibrillation]. Ned Tijdschr Geneeskd. 1989 Jul 29;133(30):1485-6. [pmid: 2677767].
Krahn AD, Manfreda J, Tate RB, Mathewson FA, Cuddy TE. The natural history of atrial fibrillation: incidence, risk factors, and prognosis in the Manitoba Follow-up Study. Am J Med. 1995 May;98:476-84. [pmid: 7733127].
Kuhlkamp V, Schmid F, Risler T, Seipel L. Randomized comparison of flecainide and cibenzoline in the conversion of atrial fibrillation. Int J Cardiol. 1991 Apr;31(1):65-9.
Lanas F, Salvatici R, Castillo G, Montecinos A, Stockins B, Molina E. Comparison between digoxin and atenolol in chronic atrial fibrillation. Rev Med Chil. 1995 Oct;123(10):1252-62.
Landefeld CS, Goldman L. Major bleeding in outpatients treated with warfarin: incidence and prediction by factors known at the start of outpatient therapy. Am J Med. 1989 Aug;87(2):144-52.
Lang R, Klein HO, Di Segni E, Gefen J, Sareli P, Libhaber C, David D, Weiss E, Guerrero J, Kaplinsky E. Verapamil improves exercise capacity in chronic atrial fibrillation: double-blind crossover study. Am Heart J. 1983 May;105(5):820-5.
Lardoux H, Maison Blanche P, Marchand X, Canler A, Rouesnel P, Bleinc D, Peraudeau P, Schedk F. [Cibenzoline versus oral propafenone in the prevention of recurrent atrial arrhythmias: multicentre randomized double-blind study]. Ann Cardiol Angeiol (Paris). 1996 Oct;45(8):469-79.
Lau CP, Leung WH, Wong CK. A randomized double-blind crossover study comparing the efficacy and tolerability of flecainide and quinidine in the control of patients with symptomatic paroxysmal atrial fibrillation. Am Heart J. 1992 Sept;124(3):645-50.
Laupacis A, Albers G, Dunn M, Feinberg W. Antithrombotic therapy in atrial fibrillation. Chest. 1992 Oct;102(4 Suppl):426S-33S.
Lawson-Matthew PJ, McLean KA, Dent M, Austin CA, Channer KS. Xamoterol improves the control of chronic atrial fibrillation in elderly patients. Age Ageing. 1995 Jul;24(4):321-5.
Lee AJ, Huber J, Stason WB. Poststroke rehabilitation in older Americans. The Medicare experience. Med Care. 1996 Aug;34(8):811-25.
Lee SH, Chen SA, Chiang CE, Tai CT, Wen ZC, Wang SP, Chang MS. Comparisons of oral propafenone and quinidine as an initial treatment option in patients with symptomatic paroxysmal atrial fibrillation: a double-blind, randomized trial. J Intern Med. 1996 Mar;239(3):253-60.
Lee SH, Chen SA, Tai CT, Chiang CE, Wen ZC, Chen YJ, Yu WC, Huang JL, Fong AN, Cheng JJ, Chang MS. Comparisons of oral propafenone and sotalol as an initial treatment in patients with symptomatic paroxysmal atrial fibrillation. Am J Cardiol. 1997 Apr 1;79(7):905-8.
Levi G, Proto C, Rovetta A. Double-blind evaluation of practolol and quinidine in the treatment of chronic atrial fibrillation. Cardiology. 1973;58(6):364-8. [pmid: 4608474].
Lewis RV, Irvine N, McDevitt DG. Relationships between heart rate, exercise tolerance and cardiac output in atrial fibrillation: the effects of treatment with digoxin, verapamil and diltiazem. Eur Heart J. 1988 Jul;9(7):777-81.
Lewis RV, Laing E, Moreland TA, Service E, McDevitt DG. A comparison of digoxin, diltiazem and their combination in the treatment of atrial fibrillation. Eur Heart J. 1988 Mar;9(3):279-83.
Lewis RV, McMurray J, McDevitt DG. Effects of atenolol, verapamil, and xamoterol on heart rate and exercise tolerance in digitalised patients with chronic atrial fibrillation. J Cardiovasc Pharmacol. 1989 Jan;13(1):1-6.
Lin SK, Morganroth J, Heng M, Rubler S, Baird W, Atwood JE, Mostow N, Scarse OM, Yu P, Caruso FS, et al. Effect of orally administered celiprolol in patients with chronic atrial fibrillation. J Cardiovasc Pharmacol. 1986;8 Suppl (4):S112-5.
Lok NS, Lau CP. Oxygen uptake kinetics and cardiopulmonary performance in lone atrial fibrillation and the effects of sotalol. Chest. 1997 Apr;111(4):934-40.
Loogen F, Risler T, Seipel L. [Prevention of embolism in mitral-valve lesions with anticoagulants. (Long-term observations on patients with and without discoumarol treatment)]. Dtsch Med Wochenschr. 1972 Dec 1;97(48):1845-9.
Lown B, Perlroth MG, Kaidbey S, Abe T, Harken DE. "Cardioversion" of atrial fibrillation. A report on the treatment of 65 episodes in 50 patients. N Engl J Med. 1963 Aug 15;269:325-31.
Luciardi H, Berman S, Santana M, Monteros L. [Intravenous diltiazem in the reversion to sinus rhythm in supraventricular tachyarrhythmias]. Arch Inst Cardiol Mex. 1996 Nov-Dec;66(6):505-9.
Lundstrom T, Moor E, Ryden L. Differential effects of xamoterol and verapamil on ventricular rate regulation in patients with chronic atrial fibrillation. Am Heart J. 1992 Oct;124(4):917-23.
Lundstrom T, Ryden L. Ventricular rate control and exercise performance in chronic atrial fibrillation: effects of diltiazem and verapamil. J Am Coll Cardiol. 1990 Jul;16(1):86-90.
Madrid AH, Moro C, Marin-Huerta E, Mestre JL, Novo L, Costa A. Comparison of flecainide and procainamide in cardioversion of atrial fibrillation. Eur Heart J. 1993 Aug;14(8):1127-31.
Maisel WH, Kuntz KM, Reimold SC, Lee TH, Antman EM, Friedman PL, Stevenson WG. Risk of initiating antiarrhythmic drug therapy for atrial fibrillation in patients admitted to a university hospital. Ann Intern Med. 1997 Aug 15;127(4):281-4.
Maison-Blanche P, Brembilla-Perrot B, Fauchier JP, Babuty D, Garnier LF, Rouesnel P, Breuillac JC, Funck F, Scheck F, Peraudeau P, Medvedowsky JL. [Comparative study of cibenzoline and flecainide by oral route for preventing recurrence of paroxysmal atrial tachyarrhythmias]. Ann Cardiol Angeiol. 1997 Feb;46(2):109-16.
Manning WJ, Silverman DI, Keighley CS, Oettgen P, Douglas PS. Transesophageal echocardiographically facilitated early cardioversion from atrial fibrillation using short-term anticoagulation: final results of a prospective 4.5 year study. J Am Coll Cardiol. 1995 May;25(6):1354-61.
Manning WJ, Weintraub RM, Waksmonski CA, Haering JM, Rooney PS, Maslow AD, Johnson RD, Douglas PS. Accuracy of transesophageal echocardiography for identifying left atrial thrombi: a prospective, intraoperative study. Ann Intern Med. 1995 Dec 1;123(11):817-22.
Martin A, Benbow LJ, Leach C, Bailey RJ. Comparison of amiodarone and disopyramide in the control of paroxysmal atrial fibrillation and atrial flutter (interim report). Br J Clin Pract Symp Suppl. 1986 Apr;44:52-60. [pmid: 3089263].
Mas JL. [Thromboembolic complications in the course of non-valvular atrial fibrillation]. Rev Prat. 1995 Apr 15;45(8):935-41. [pmid: 7761775].
Matsumoto N, Whisnant JP, Kurland LT, Okazaki H. Natural history of stroke in Rochester, Minnesota, 1955 through 1969: an extension of a previous study, 1945 through 1954. Stroke. 1973 Jan-Feb;4(1):20-9.
McMahan DA, Smith DM, Carey MA, Zhou XH. Risk of major hemorrhage for outpatients treated with warfarin. J Gen Intern Med. 1998 May;13(5):311-6.
Moreyra E, Finkelhor RS, Cebul RD. Limitations of transesophageal echocardiography in the risk assessment of patients before nonanticoagulated cardioversion from atrial fibrillation and flutter: an analysis of pooled trials. Am Heart J. 1995 Jan;129(1):71-5.
Morocutti C, Amabile G, Fattapposta F, Nicolosi A, Matteoli S, Trappolini M, Cataldo G, Milanesi G, Lavezzari M, Pamparana F, Coccheri S. Indobufen versus warfarin in the secondary prevention of major vascular events in nonrheumatic atrial fibrillation. SIFA (Studio Italiano Fibrillazione Atriale) Investigators. Stroke. 1997 May;28(5):1015-21.
Myers J, Atwood JE, Sullivan M, Forbes S, Friis R, Pewen W, Froelicher V. Perceived exertion and gas exchange after calcium and beta-blockade in atrial fibrillation. J Appl Physiol. 1987 Jul;63(1):97-104.
Naccarelli GV, Dorian P, Hohnloser SH, Coumel P. Prospective comparison of flecainide versus quinidine for the treatment of paroxysmal atrial fibrillation/flutter. The Flecainide Multicenter Atrial Fibrillation Study Group. Am J Cardiol. 1996 Jan 25;77(3):53A-9A.
Noc M, Stajer D, Horvat M. Intravenous amiodarone versus verapamil for acute conversion of paroxysmal atrial fibrillation to sinus rhythm [see comments]. Am J Cardiol. 1990 Mar 1;65(9):679-80.
Normand JP, Legendre M, Kahn JC, Bourdarias JP, Mathivat A. Comparative efficacy of short-acting and long-acting quinidine for maintenance of sinus rhythm after electrical conversion of atrial fibrillation. Br Heart J. 1976 Apr;38(4):381-7.
Obel IW. Clinical and experimental experience with 39089 BA (trasicor) as an anti-arrhythmic agent. S Afr Med J. 1969 Dec 6;(Suppl):18-23.
Ochs HR, Anda L, Eichelbaum M, Greenblatt DJ. Diltiazem, verapamil, and quinidine in patients with chronic atrial fibrillation. J Clin Pharmacol. 1985 Apr;25(3):204-9.
Ochs HR, Eichelbaum M, Vogelgesang B, Kumm D, et al. Diltiazem, verapamil, and quinidine in chronic atrial fibrillation. Med Welt. 1984;35:383-7.
[No authors listed]. Optimal oral anticoagulant therapy in patients with nonrheumatic atrial fibrillation and recent cerebral ischemia. The European Atrial Fibrillation Trial Study Group. N Engl J Med. 1995 Jul 6;333(1):5-10.
Ostrander LD Jr, Brandt RL, Kjelsberg MO, Epstein FH. Electrocardiograph Ic findings among the adult population of a total natural community. Tecumseh, Michigan. Circulation. 1965 Jun;31:888-98.
Panidis IP, Morganroth J, Baessler C. Effectiveness and safety of oral verapamil to control exercise-induced tachycardia in patients with atrial fibrillation receiving digitalis. Am J Cardiol. 1983 Dec 1;52(10):1197-201.
Pasricha CJ, Fleischer DE, Kalloo AN. Endoscopic perforations of the upper digestive tract: a review of their pathogenesis, prevention, and management. Gastroenterology. 1994 Mar;106(3):787-802. [pmcid: 222984].
Persson U, Silverberg R, Lindgren B, Norrving B, Jadback G, Johansson B, Puranen BI. Direct costs of stroke for a Swedish population. Int J Technol Assess Health Care. 1990;6(1):125-37. [pmid: 2113889].
Petersen P, Boysen G, Godtfredsen J, Andersen ED, Andersen B. Placebo-controlled, randomised trial of warfarin and aspirin for prevention of thromboembolic complications in chronic atrial fibrillation. The Copenhagen AFASAK Study. Lancet. 1989 Jan 28;1(8631):175-9.
Peverill RE, Harper RW, Gelman J, Gan TE, Harris G, Smolich JJ. Determinants of increased regional left atrial coagulation activity in patients with mitral stenosis. Circulation. 1996 Aug 1;94(3):331-9.
Pietersen AH, Hellemann H. Usefulness of flecainide for prevention of paroxysmal atrial fibrillation and flutter. Danish-Norwegian Flecainide Multicenter Study Group. Am J Cardiol. 1991 Apr 1;67(8):713-7.
The Planning and Steering Committees of the AFFIRM study for the NHLBI AFFIRM investigators. Atrial fibrillation follow-up investigation of rhythm management -- the AFFIRM study design. Am J Cardiol. 1997 May 1;79(9):1198-202.
Pomfret SM, Beasley CR, Challenor V, Holgate ST. Relative efficacy of oral verapamil and digoxin alone and in combination for the treatment of patients with chronic atrial fibrillation. Clin Sci. 1988 Apr;74(4):351-7.
Prystowsky EN, Benson DW Jr., Fuster V, Hart RG, Kay GN, Myerburg RJ, Naccarelli GV, Wyse DG. Management of patients with atrial fibrillation. A statement for healthcare professionals. From the Subcommittee on Electrocardiography and Electrophysiology, American Heart Association. Circulation. 1996 March 15;93(6):1262-77.
Rasmussen K, Wang H, Fausa D. Comparative efficiency of quinidine and verapamil in the maintenance of sinus rhythm after DC conversion of atrial fibrillation. A controlled clinical trial. Acta Med Scand Suppl. 1981;645:23-8. [pmid: 7015799].
Richiardi E, Gaita F, Greco C, Gaschino G, Comba Costa G, Rosettani E, Brusca A. [Propafenone versus hydroquinidine in long-term pharmacological prophylaxis of atrial fibrillation]. Cardiologia. 1992 Feb;37(2):123-7.
Roth A, Kaluski E, Felner S, Heller K, Laniado S. Clonidine for patients with rapid atrial fibrillation. Ann Intern Med. 1992 Mar 1;116(5):388-90.
Sacco RL, Foulkes MA, Mohr JP, Wolf PA, Hier DB, Price TR. Determinants of early recurrence of cerebral infarction: The Stroke Data Bank. Stroke. 1989 Aug;20(8):983-9.
Sacco RL, Wolf PA, Kannel WB, McNamara PM. Survival and recurrence following stroke. The Framingham study. Stroke. 1982 May-Jun;13(3):290-5.
Salerno DM, Dias VC, Kleiger RE, Tschida VH, Sung RJ, Sami M, Giorgi LV. Efficacy and safety of intravenous diltiazem for treatment of atrial fibrillation and atrial flutter. The Diltiazem-Atrial Fibrillation/Flutter Study Group. Am J Cardiol. 1989 May 1;63(15):1046-51.
Satullo G, Arrigo F, Cavallaro L, Coglitore A, Fazio F, Saporito F, Sorrento S, Oreto G. [Propafenone versus quinidine in recent onset atrial fibrillation]. Minerva Cardioangiol. 1996 Mar;44(3):141-4.
Scardi S, Humar F, Pandullo C, Poletti A. Oral clonidine for heart rate control in chronic atrial fibrillation [letter]. Lancet. 1993 May 8;341(8854):1211-2.
Scardino R, Colao G, Didonato F, Sepe V. [Use of ajmaline in the therapy of various heart arrhythmias and comparison with the classic antiarrhythmic drug quinidine]. Minerva Med. 1970 Sep 29;61(78):4289-300.
Schenk KE, Schuren KP, Buschmann HJ, Dennert J, Meyer V, Ramdohr B, Schroder R. [Arrhythmias during digitalis treatment of patients with acute myocardial infarction]. Dtsch Med Wochenschr. 1971 Apr 16;96:663-70.
Schreck DM, Rivera AR, Tricarico VJ. Emergency management of atrial fibrillation and flutter: intravenous diltiazem versus intravenous digoxin. Ann Emerg Med. 1997 Jan;29(1):135-40.
Selzer A, Walter RM. Adequacy of preoperative digitalis therapy in controlling ventricular rate in postoperative atrial fibrillation. Circulation. 1966 Jul;34(1):119-22.
Seto TB, Taira DA, Tsevat J, Manning WJ. Cost-effectiveness of transesophageal echocardiographic-guided cardioversion: a decision analytic model for patients admitted to the hospital with atrial fibrillation. J Am Coll Cardiol. 1997 Jan;29(1):122-30.
Silvis SE, Nebel O, Rogers G, Sugawa C, Mandelstam P. Endoscopic complications. Results of the 1974 American Society for Gastrointestinal Endoscopy Survey. J Am Med Assoc. 1976 Mar 1;235(9):928-30.
Singh BN. Antiarrhythmic drugs: a reorientation in light of recent developments in the control of disorders of rhythm. Am J Cardiol. 1998 March 19;81(6A):3D-13D.
Singh S, Saini RK, DiMarco J, Kluger J, Gold R, Chen YW. Efficacy and safety of sotalol in digitalized patients with chronic atrial fibrillation. The Sotalol Study Group. Am J Cardiol. 1991 Nov 1;68(11):1227-30.
Smit AJ, Scaf AH, van Essen LH, Lie KI, Wesseling H. Digoxin infusion versus bolus injection in rapid atrial fibrillation: relation between serum level and response. Eur J Clin Pharmacol. 1990;38(4):335-41. [pmid: 2344857].
Sodermark T, Jonsson B, Olsson A, Oro L, Wallin H, Edhag O, Sjogren A, Danielsson M, Rosenhamer G. Effect of quinidine on maintaining sinus rhythm after conversion of atrial fibrillation or flutter. A multicentre study from Stockholm. Br Heart J. 1975 May;37(5):486-92.
Solomon NA, Glick HA, Russo CJ, Lee J, Schulman KA. Patient preferences for stroke outcomes. Stroke. 1994 Sept;25(9):1721-5.
Sopher SM, Camm AJ. Atrial fibrillation: maintenance of sinus rhythm versus rate control. A Symposium: Supraventricular Arrhythmia: Update 1995. Am J Cardiol. 1996 Jan 25;77(3):24A-37A.
Soto Pedre E, Castro Beiras A, Cuna Estevez B. [The use of digitalis: a prospective study on the posology of digoxin with weekly interruption]. Rev Esp Cardiol. 1990 Aug-Sep;43(7):438-43.
Stambler BS, Wood MA, Ellenbogen KA, Perry KT, Wakefield LK, VanderLugt JT. Efficacy and safety of repeated intravenous doses of ibutilide for rapid conversion of atrial flutter or fibrillation. Ibutilide Repeat Dose Study Investigators [see comments]. Circulation. 1996 Oct 1;94(7):1613-21.
Stern EH, Pitchon R, King BD, Guerrero J, Schneider RR, Wiener I. Clinical use of oral verapamil in chronic and paroxysmal atrial fibrillation. Chest. 1982 Mar;81(3):308-11.
Storz H. [On the quantitative effectiveness of k-strophanthin-alpha (cymarin) in intravenous and oral administration]. Dtsch Med Wochenschr. 1969 Mar 22;94(12):1166-9. [pmid: 5768542].
[No authors listed]. Stroke Prevention in Atrial Fibrillation Study. Final results [see comments]. Circulation. 1991 Aug;84(2):527-39.
Stroke Prevention in Atrial Fibrillation II Study [see comments]. Warfarin versus aspirin for prevention of thromboembolism in atrial fibrillation. Lancet. 1994 Mar 19;343(8899):687-91.
Stroke Prevention in Atrial Fibrillation III randomised clinical trial. Adjusted-dose warfarin versus low-intensity, fixed-dose warfarin plus aspirin for high-risk patients with atrial fibrillation. Lancet. 1996 Sept 7;348(9028):633-8.
Stroobandt R, Stiels B, Hoebrechts R. Propafenone for conversion and prophylaxis of atrial fibrillation. Propafenone Atrial Fibrillation Trial Investigators. Am J Cardiol. 1997 Feb 15;79(4):418-23.
Supplemental figures, atrial fibrillation evidence report. Publication No. 00-R001. 1999. Available from the AHRQ Publications Clearinghouse, P.O. Box 8547, Silver Spring MD 20907 (1-800-358-9295).
Suttorp MJ, Kingma JH, Jessurun ER, Lie-A-Huen L, van Hemel NM, Lie KI. The value of class IC antiarrhythmic drugs for acute conversion of paroxysmal atrial fibrillation or flutter to sinus rhythm. J Am Coll Cardiol. 1990 Dec;16(7):1722-7.
Suttorp MJ, Kingma JH, Lie-A-Huen L, Mast EG. Intravenous flecainide versus verapamil for acute conversion of paroxysmal atrial fibrillation or flutter to sinus rhythm. Am J Cardiol. 1989 Mar 15;63(11):693-6.
Sweany AE, Moncloa F, Vickers FF, Zupkis RV. Antiarrhythmic effects of intravenous timolol in supraventricular arrhythmia. Clin Pharmacol Ther. 1985 Feb;37(2):124-7.
Sweeney KG, Gray DP, Evans P, Steele R. Anticoagulation therapy: bleeding and thromboembolic complications. Lancet. 1996 Nov 23;348(9039):1456-7.
Terent A, Marke LA, Asplund K, Norrving B, Jonsson E, Wester PO. Costs of stroke in Sweden: a national perspective. Stroke. 1994 Dec;25(12):2363-9.
Tezcan H, Okucu M, Fak AS, Oktay A. Efficacy and safety of intravenous diltiazem vs. verapamil in the acute treatment of atrial fibrillation. Turk Kardiyoloji Dernegi Arsivi. 1996;24:36-42+6.
Toivonen LK, Nieminen MS, Manninen V, Frick MH. Conversion of paroxysmal atrial fibrillation to sinus rhythm by intravenous pirmenol. A placebo controlled study. Br Heart J. 1986 Feb;55(2):176-80.
Tommaso C, McDonough T, Parker M, Talano JV. Atrial fibrillation and flutter. Immediate control and conversion with intravenously administered verapamil. Arch Intern Med. 1983 May;143(5):877-81.
Touboul P, Brembilla-Perrot B, Scheck F, Gabried A, Lardoux H, Marchand S, Levy S. [Randomized double-blind comparative study of the effects of cibenzoline and hydroquinidine in the prevention of atrial fibrillation]. Ann Cardiol Angeiol (Paris). 1995 Nov;44(9):525-31.
Treglia A, Alfano C, Rossini E. [A comparison between propafenone and amiodarone in the conversion to sinus rhythm of atrial fibrillation of recent onset]. Minerva Cardiol. 1994 Jun;42(6):293-7.
UK Propafenone PSVT Study Group. A randomized, placebo-controlled trial of propafenone in the prophylaxis of paroxysmal supraventricular tachycardia and paroxysmal atrial fibrillation. Circulation. 1995 Nov 1;92(9):2550-7.
Urban and Vogel Workshop. [Atrial fibrillation-decision aids for ambulatory therapy]. Herz. 1995 Dec;20(Suppl 3):1-16.
U.S. Agency for Health Care Policy and Research. Post-Stroke Rehabilitation. Clinical Practice Guideline, No. 16. Rockville, MD: U.S. Department of Health and Human Services, Public Health Service. AHCPR Publication No. 95-0062. May 1995.
The value of quinidine therapy in order to maintain sinus rhythm after electrical rhythmization of atrial fibrillation. Klin Wochenschr. 1969;47.
Van Gelder IC, Crijns HJ. Cardioversion of atrial fibrillation and subsequent maintenance of sinus rhythm. Pacing Clin Electrophysiol. 1997 Oct;20(10 Pt. 2):2675-83.
Van Gelder IC, Crijns HJ, Van Gilst WH, Van Wijk LM, Hamer HP, Lie KI. Efficacy and safety of flecainide acetate in the maintenance of sinus rhythm after electrical cardioversion of chronic atrial fibrillation or atrial flutter. Am J Cardiol. 1989 Dec 1;64(19):1317-21.
van Latum JC, Koudstaal PJ, Venables GS, van Gijn J, Kappelle LJ, Algra A. Predictors of major vascular events in patients with a transient ischemic attack or minor ischemic stroke and with nonrheumatic atrial fibrillation. European Atrial Fibrillation Trial (EAFT) Study Group. Stroke. 1995 May;26(5):801-6.
van Wijk LM, den Heijer P, Crijns HJ, van Gilst WH, Lie KI. Flecainide versus quinidine in the prevention of paroxysms of atrial fibrillation. J Cardiovasc Pharmacol. 1989 Jan;13(1):32-6.
Vaughan-Williams EM. Classification of antiarrhythmic drugs. In: Sandoe E, Flenstedt-Jensen E, Olesen KH, eds. Symposium on Cardiac Arrhythmia. Sodertalje, Sweden: AB Astra. 1970, pp 440-69.
Vaughan-Williams EM. A classification of antiarrhythmic actions reassessed after a decade of new drugs. J Clin Pharmacol. 1984 Apr;24(4):129-47. [pmid: 6144698].
Vaziri SM, Larson MG, Benjamin EJ, Levy D. Echocardiographic predictors of nonrheumatic atrial fibrillation [abstract]. J Am Coll Cardiol. 1993 February;21(2).
Venables G. Anticoagulation and stroke [letter]. Br Med J (Clin Res Ed). 1988 Jun 18;296(6638).
Villani R, Zoletti F, Veniani M, Locati F, Nava S. [A comparison between amiodarone and disopyramide in a delayed-release formulation in the prevention of recurrences of symptomatic atrial fibrillation]. Clin Ter. 1992 Jan;140(1 Pt 2):35-9.
Vitale P, Auricchio A, De Stefano R, Agretto A, De Simone R, Vitale N, Barbato F, Iacono A. Effectiveness of diltiazem in controlling ventricular response and improving exercise capacity in chronic atrial fibrillation. Double-blind, cross-over study. Cardiologia. 1989 Jan;34(1):73-81.
Waktare JE, Camm AJ. Acute treatment of atrial fibrillation: why and when to maintain sinus rhythm. Am J Cardiol. 1998 March 12;81(5A):3C-15C.
Waldo AL, Prystowsky EN. Drug treatment of atrial fibrillation in the managed care era. Am J Cardiol. 1998 Mar 12;81(5A):23C-9C.
Whisnant JP Fitzgibbons JP, Kurland LT, Sayre GP. Natural history of stroke in Rochester, Minnesota, 1945 through 1954. Stroke. 1971 Jan-Feb;2:11-22. [pmid: 5112001].
Wiseman RA. Practolol-an analysis of clinical trials in cardiac dysrhythmias. Acta Cardiol. 1972;(Suppl 16):19-28. [pmid: 4119921].
Wolf PA, Abbott RD, Kannel WB. Atrial fibrillation: a major contributor to stroke in the elderly. The Framingham Study. Arch Intern Med. 1987 Sep;147(9):1561-4.
Wolf PA, Abbott, RD, Kannel WB. Atrial fibrillation as an independent risk factor for stroke: the Framingham study. Stroke. 1991 Aug;22(8):983-8.
Wolf PA, Dawber TR, Thomas HE Jr, Kannel WB. Epidemiologic assessment of chronic atrial fibrillation and risk of stroke: the Framingham study. Neurology. 1978 Oct;28(10):973-7. [pmcid: 331413].
Wollert HG, Grossmann H, Eckel L. Magnesium sulfate prevents atrial tachyarrhythmias after cardiac and non-cardiac surgery-what is the common mechanism? [letter]. Thorac Cardiovasc Surg. 1997 Aug;45(4):213-4.
Wong CK, Lau CP, Leung WH, Cheng CH. Usefulness of labetalol in chronic atrial fibrillation. Am J Cardiol. 1990 Nov 15;66(17):1212-5.
Yamanouchi H, Mizutani T, Matsushita S, Esaki Y. Paroxysmal atrial fibrillation: high frequency of embolic brain infarction in elderly autopsy patients. Neurology. 1997 Dec;49(6):1691-4.
Zehender M, Hohnloser S, Muller B, Meinertz T, Just H. Effects of amiodarone versus quinidine and verapamil in patients with chronic atrial fibrillation: results of a comparative study and a 2-year follow-up. J Am Coll Cardiol. 1992 Apr;19(5):1054-9.
Zoble RG, Brewington J, Olukotun AY, Gore R. Comparative effects of nadolol-digoxin combination therapy and digoxin monotherapy for chronic atrial fibrillation. Am J Cardiol. 1987 Aug 31;60(6):39D-45D.