# Decision Analysis

## Methods

### Objective

The main objective of the decision analysis was to address those questions not directly or fully addressed in the clinical trial literature. The decisions to be addressed included:

1 The overall decision regarding whether to attempt cardioversion or to treat conservatively with rate control and antithrombotic agents (key question 1).
2 If cardioversion is to be attempted, what combination of electrical or pharmacological intervention is best for cardioversion and subsequent maintenance of sinus rhythm? (key questions 2 and 3).
3 If cardioversion is not to be attempted, what antithrombotic agent should be used? (supplementary question 2).
4 The question regarding outpatient initiation of antiarrhythmic therapy (key question 4), although only the cost implications of this decision could be evaluated because of limitations in the literature.
5 Decisions regarding the use of transesophageal echocardiography and transthoracic echocardiography in the evaluation of patients with AF (key question 5) to help guide decisions about antithrombotic therapy.

Because the data in the randomized clinical trial literature regarding rate control were not presented readily translatable to a decision analytic format, rate control issues were not evaluated in the model.

The target population was patients with new onset AF. Because age and risk factors for thromboembolism are important clinical characteristics that influence the decisions we evaluated, the base case was analyzed in six subgroups based on these characteristics. The six groups were patients who were 55, 65, and 75 years old, with and without risk factors for thromboembolism. The questions were addressed in the decision analysis by estimating the cost-effectiveness of alternative strategies from the perspective of society.

### Design

#### Strategies

A Monte Carlo multistate transition model was constructed using a commercially available computer program (DATA by TreeAge, Williamstown, Mass.). One large tree was constructed to encompass all of the above decisions, with decision nodes embedded within other decision nodes (Figure 60). For instance, the decision about which pharmacological agent is most cost-effective for maintenance of sinus rhythm must be addressed before determining if cardioversion is preferable to conservative therapy with rate control and antithrombotic therapy.

Figure 60. Strategies for atrial fibrillation

First, to address the question of what combination of electrical or pharmacological intervention is most cost-effective for cardioversion and subsequent maintenance of sinus rhythm (key questions 2 and 3), 17 strategies were evaluated (strategies A-G in Figure 60).

(A) Electrical cardioversion without subsequent pharmacological therapy.

(B-G) Pharmacological conversion using either quinidine, flecainide, propafenone, amiodarone, sotalol, or ibutilide without subsequent pharmacological therapy.

(H-L) Pharmacological conversion with continued therapy using either quinidine, flecainide, propafenone, amiodarone, or sotalol (ibutilide cannot be used for continued therapy).

(M-Q) Electrical cardioversion with subsequent maintenance of sinus rhythm using one of the five agents listed above.

Second, to address the question of which antithrombotic therapy is most cost-effective for the prevention of stroke (supplementary question 2), strategies employing aspirin and warfarin were evaluated.

Third, by comparing the most cost-effective strategies from each of the above two analyses, the overall question of whether to attempt cardioversion or to treat conservatively with antithrombotic therapy (key question 1) was addressed.

Fourth, the implications of the costs of inpatient versus outpatient initiation of antiarrhythmic therapy on the cost-effectiveness of the strategies for cardioversion and subsequent maintenance of sinus rhythm (key question 4) were evaluated.

Finally, the question regarding the use of echocardiography to guide antithrombotic therapy (key question 5) was addressed. Strategies employing transesophageal echocardiography or transthoracic echocardiography to guide decisions about antithrombotic therapy were compared with the strategy employing either aspirin in all patients or warfarin in all patients.

#### Multistate Transition Model

Each of the strategies outlined above was incorporated into a decision model by linking the decision nodes to a Monte Carlo multistate transition model. In this simulation model, patients are followed through monthly cycles for events that cause transition from one health state to another. The cost and utility (which is a numeric estimate of quality of life) associated with each health state for each cycle is calculated. The final estimated average cost and utility for each strategy are based on the average sum of the costs and utilities for 5,000 patients.

The model was designed for Monte Carlo simulation. Monte Carlo simulation tracks individual patients through the model. Another common method, conventional multiplicative simulation, tracks each of the probabilities of each event through the model. For example, assume a model is constructed to assess a strategy employing an operation with a 5 percent mortality and a postoperative utility for survivors of 1.0. In conventional multiplicative simulations, the final utility of this simple model would be 0.95 (0.95 times 1.0 plus 0.05 times 0). In Monte Carlo simulation, for each trial the final utility would be either 1.0 if the patient survived or 0 if the patient did not. If a large number of trials (i.e., individual patients) are run, 95 percent of the trials likely would result in a utility of 1.0 and 5 percent in a utility of 0, with the mean utility approaching 0.95. Thus, in simple models, little is gained from Monte Carlo simulations.

However, in models of complex clinical problems such as ours, Monte Carlo simulations enable memory of previous health states. For instance, if a patient transitions through one health state and then back to the baseline state, the assumed therapy can be changed. In conventional multiplicative simulations, a separate health state would need to be created to account for the proportion that changes therapy. With a complex model, the number of health states necessary to account for all potential changes in health status and therapy would be cumbersome. The major disadvantage of Monte Carlo models is the time required to run each simulation because thousands of trials typically are necessary to achieve mean stable estimates of mean costs and mean utilities. In particular, the number of parameters evaluated in sensitivity analysis makes Monte Carlo models very time consuming. Overall, Monte Carlo models enable more complex clinical scenarios than other models but require more time to run.

The health state outcomes in our model (Figure 61) included a baseline health state, five temporary health states that may transition back to the baseline health state (temporary bleed, transient ischemic attack, ventricular arrhythmia, acute stroke, and acute central nervous system bleed), two chronic health states (post-stroke and post-central nervous system bleed), and death.

Figure 61. Multi-state transition model

The Monte Carlo model enabled simulation of changes in rhythm status and therapy within and between health states. Within each health state, two cardiac rhythms-sinus rhythm or atrial fibrillation-and two antithrombotic therapies-aspirin or warfarin-were possible. For example, if a patient began the simulation in sinus rhythm, each month brings a probability of converting back to atrial fibrillation. Also, if a patient being treated with warfarin experienced a temporary bleed, the therapy would be changed permanently to aspirin.

### Decision Analysis Assumptions

Several assumptions were necessary to implement the decision model. The major assumptions are listed below.

#### Patient Characteristics

Patients were assumed to have:

- Persistent atrial fibrillation.
- No previous trials on any of the medications. Information from previous trials can influence probabilities of success. This assumption is consistent with our decision to focus on a target population of patients with new onset atrial fibrillation.
- No indication for any of the medications other than for atrial fibrillation.
- No contraindication to any of the medications.
- No recent transthoracic echocardiography or transesophageal echocardiography.
- No indication for transthoracic echocardiography or transesophageal echocardiography other than atrial fibrillation.
- No contraindication to transesophageal echocardiography.

#### Model Characteristics

Our model assumed that:

- The two available antithrombotic treatment options for patients with persistent AF are warfarin and aspirin. The evidence was against the use of placebo or a combination of warfarin and aspirin, and the evidence evaluating low molecular weight heparin and indobufen was inconclusive (in Chapter 3, see Efficacy of Anticoagulants and Antiplatelet Agents in Management of AF and Meta-Analysis of Results).
- The six available antiarrhythmic options are quinidine, flecainide, propafenone, amiodarone, sotalol, and ibutilide. (Ibutilide is available for acute conversion only.)
- Once AF recurs or if initial cardioversion did not occur, patients stay in AF (i.e., only one attempt of rhythm control). To construct a model that incorporates multiple attempts at cardioversion would be too cumbersome and involve multiple additional assumptions.
- The only events that are counted are temporary bleeds, transient ischemic attacks, ventricular arrhythmia, hemorrhagic stroke, ischemic stroke, or death.
- Temporary bleeds, transient ischemic attacks, and ventricular arrhythmia affect utility for only one cycle (1 month).
- Temporary bleeds, transient ischemic attacks, and ventricular arrhythmia can occur multiple times.
- Ischemic strokes and central nervous system bleeds can result in death or a permanently decreased utility. If a patient is on warfarin when a central nervous system bleed occurs, treatment changes to aspirin. If a patient is on aspirin when an ischemic stroke occurs, treatment changes to warfarin. Amiodarone can safely be started as an outpatient. The other antiarrhythmic agents require 1 hospital day to start safely for acute conversion only and 4 days to start for maintenance therapy.
- Transesophageal echocardiography and electrical cardioversion can be done on an outpatient basis.

#### Risk

Our model assumed that:

- Risk of recurrent AF after successful conversion and risk of ventricular arrhythmia differ by medication but not by any other risk status. For example, patients on quinidine have recurrent AF at a different rate from those on amiodarone, but the rates are similar for those <65 years old and for those >75 years old.
- Initial rates of recurrent AF after conversion are higher than subsequent rates (the rate for each month is less than that for previous month). For example, the rate of recurrent AF for the first month is twice that for the second month. This rate was determined by assessing the rates of recurrence of AF in the control arms of the clinical trials identified for the meta-analysis.
- Ischemic strokes and central nervous system bleeds permanently increase the risk of death.
- Relative reduction in ischemic stroke risk with treatment is uniform across baseline stroke risks. For example, warfarin reduces stroke risk by 67 percent regardless of baseline stroke risk.
- Risk of stroke decreases once converted to sinus rhythm (e.g., to one-third in base case analysis) (Krahn, Manfreda, Tate et al., 1995).
- Transesophageal echocardiography is considered only for patients with additional (other than AF) known risk factors for ischemic stroke (previous embolic stroke, systolic hypertension, diabetes). Available literature does not include transesophageal echocardiography in low-risk patients.
- Stroke risk for those with abnormalities on transesophageal echocardiography depends upon the abnormality rather than other patient characteristics (e.g., age, hypertension); the differing prevalences of these abnormalities reflect the differing stroke risk in the overall population. For example, a patient with a left-atrial abnormality on transesophageal echocardiography has a stroke risk of 7.8 percent per year. The higher stroke risk of an older patient compared with a younger patient will be accounted for by a higher prevalence of abnormalities on transesophageal echocardiography.
- Stroke risk for those with abnormal left-ventricular function on transthoracic echocardiography is proportionally greater than the risk if left-ventricular function were not known. For instance, the risk for those 75 years old without other risk factors increases 11-fold if it is known that left-ventricular function is abnormal.

### Input Parameters

The probability of each event, mortality rates, costs, and utilities used in the decision analysis are presented in Table 4. Wherever possible, we used the results of our meta-analysis of the clinical trial literature because these data represented the strongest level of evidence. The rate of successful conversion without pharmacologic therapy was estimated from the mean of conversion proportions in the control arms of our identified studies. The rates of successful conversion for patients receiving each of the pharmacological agents were assumed to be proportional to this rate and were estimated from the relative risks from the trials.

Table 4. Input Variables

Category | Description | Best Estimate ^1^ | Low | High | Source
Prevalence % | Abnormal LV on TTE | 1) 6.0 2) 9.7 3) 10.8 4) 18.3 5) 11.3 6) 17.1 | 2.9 5.8 4.8 13.1 8.1 10.8 | 10.7 15.1 20.2 24.4 15.2 25.2 | Atrial Fibrillation Investigators, Arch Intern Med, 1998.
| Left-atrial abnormality on TEE | 28.0 | 21.6 | 35.3 | SPAF III, Lancet,1996.
| Aortic plaque on TEE | 17.4 | 12.2 | 23.8 | SPAF III, Lancet,1996.
| Left-atrial abnormality and aortic plaque on TEE | 20.2 | 14.9 | 26.9 | SPAF III, Lancet,1996.
| Thrombus on initial TEE | 7 | 3.5 | 14 | Manning, Silverman, Keighley et al., J Am Coll Cardiol,1995.
| Thrombus on repeat TEE after 4 weeks anticoagulation | 15 | 7.5 | 30
| Esophageal tear during TEE | 0.02 | 0.01 | 0.03 | Dawson and Cockel, BMJ 1981; Silvis, Nebel, Rogers etal., JAMA 1976.
Stroke and CNS Bleed Rates % or %/yr | Stroke off medications | 1) 0.8 2) 3.9 3) 0.9 4) 5.2 5) 5.6 6) 10.7 | 0.2 2.2 0.1 3.2 3.9 6.8 | 3.0 7.1 6.7 8.7 8.0 16.7 | Atrial Fibrillation Investigators, Arch Intern Med, 1998.
| Cerebral bleed on aspirin | 0.15/yr | 0 | 0.8 | Meta-analysis from EPC Report
| Cerebral bleed on warfarin | 0.5/yr | 0 | 1.8
| Stroke with left-atrial abnormality on TEE | 7.8/yr | 2.9 | 21.0 | SPAF III, Lancet, 1996.
| Stroke with aortic plaque on TEE | 12.0/yr | 4.5 | 32.0
| Stroke with both left-atrial abnormality and aortic plaqueon TEE | 20.5/yr | 9.8 | 43
| Stroke after cardioversion | 0.33 | 0.1 | 0.8 | Moreyra, Finkelhor, and Cebul, Am Heart J, 1995.
Stroke and CNS Bleed Relative Risks (Compared with Baseline Rates) | Number of Transient ischemic attacks compared with the number of strokes | 0.25 | 0.125 | 0.5 | Meta-analysis from EPC Report
| Number of temporary bleeds compared with the number of CNS bleeds | 4 | 2 | 8
| Stroke on aspirin | 0.67 | 0.43 | 0.99
| Stroke on warfarin | 0.33 | 0.19 | 0.48
| Stroke with abnormal LV on TTE | 1) 11.6 2) 2.2 3) 12.1 4) 1.9 5) 2.1 6) 1.8 | 1.6 0.5 1.6 0.8 0.9 0.7 | 82.5 8.5 86.7 4.4 4.6 4.9 | Atrial Fibrillation Investigators, Arch Intern Med, 1998.
| Relative rate of stroke with persistent thrombus | 10 | 5 | 20 | Klein, Grimm, Black et al., Ann Intern Med, 1997;estimated
| Relative rate of stroke with resolved thrombus | 5 | 2.5 | 10 | Estimated
| Stroke in sinus rhythm | 0.33 | 0.2 | 0.5 | Krahn, Manfreda, Tate et al., Am J Med, 1995; Wolf, Abbott, and Kannel, Stroke, 1991.
| Relative rate of CNS bleed in the first month | 2 | 1 | 10 | Fihn, McDonell, Martin et al., Ann Intern Med, 1993.
Acute Cardioversion Rates and Relative Risks | Direct current cardioversion (DCCV) | 80% | 70 | 90 | Van Gelder and Crijns, PACE, 1997.
| Spontaneous | 30% | 0 | 75 | Meta-analysis from EPC Report
| Quinidine | 1.34 | 0.98 | 1.85
| Flecainide | 8.02 | 3.55 | 18.14
| Propafenone | 1.88 | 1.67 | 2.13
| Amiodarone | 1.33 | 0.83 | 1.16
| Sotalol | 0.42 | 0.07 | 2.56
| Ibutilide/Dofetilide | 16.8 | 0.38 | 92.23
Relapse Rates* | Baseline | 40% | 20% | 60% | Meta-analysis from EPC Report
| Quinidine | 0.55 | 0.3 | 0.85
| Flecainide | 0.52 | 0.425 | 0.875
| Propafenone | 0.45 | 0.4 | 0.7
| Amiodarone | 0.52 | 0.3 | 0.85
| Sotalol | 0.45 | 0.275 | 0.8
Ventricular rates and relative risks | Baseline | 0 | | | Assumed
| In hospital for all antiarrhythmic agents | 0
| Quinidine - Acute, if initiated in outpatient setting | 1.2% | 0.6 | 2.4 | Falk, Ann Intern Med, 1992
| Quinidine | 1.5%/yr | 0.75 | 3
| Flecainide | 0.5 | 0.25 | 1 | Estimated
| Propafenone | 0.5 | 0.25 | 1
| Amiodarone | 0.33 | 0.1 | 1.0
| Sotalol | 1.0 | 0.5 | 2
| Ibutilide | 1.0 | 0.5 | 2
Mortality Rates %/yr or % | Baseline rate of death for general population | | | | Actuarial Data
| Increase in mortality for atrial fibrillation | 1.31 | 1.08 | 1.59 | Krahn, Manfreda, Tate et al., Am J Med, 1995.
| Increase in mortality for risk factor>1 | 1.77 | 1.36 | 2.17 | Krahn, Manfreda, Tate et al., Am J Med, 1995.
| Acute stroke | 20% | 10 | 30 | Matsumoto, Whisnant, Kurland et al., Stroke, 1973; Sacco RL, Foulkes, Mohr et al., Stroke, 1989; Sacco, Wolf, Kannel et al., Stroke,1982; US Agency for Health Care Policy and Research, 1995; Wolf, Dawber,Thomas et al., Neurology, 1978; Meta-analysis from EPC Report; Dennis, Burn,Sandercock et al., Stroke, 1993.
| Chronic stroke | 15%/yr | 7.5 | 30 | Matsumoto, Whisnant, Kurland et al., Stroke, 1973; Sacco,Wolf, Kannel et al., Stroke, 1982; United States Agency for Health Care Policy and Research, US DHHS, 1995; Wolf, Dawber, Thomas et al., Neurology,1978; Dennis, Burn, Sandercock et al., Stroke, 1993
| Acute cerebral bleed | 70% | 50 | 90 | Landefeld and Goldman, Am J Med, 1989; Matsumoto,Whisnant, Kurland et al., Stroke, 1973; Sacco, Foulkes, Mohr et al., Stroke,1989; Sacco, Wolf, Kannel et al., Stroke, 1982; Wolf, Dawber, Thomas etal., Neurology, 1978; Dennis, Burn, Sandercock et al., Stroke, 1993
| Chronic cerebral bleed | 15%/yr | 7.5 | 30 | Same as stroke
| Ventricular arrhythmia | 50% | 25 | 75 | Falk, Ann Intern Med, 1992.
| Esophageal tear | 8% | 4 | 16 | Pasricha, Fleischer and Kalloo, Gastroenterology, 1994.
Costs | Anticoagulation | 72/mo | 45 | 108 | Gage, Cardinalli, Albers et al., JAMA, 1995.
$ or $/mo | Quinidine | 3 | 0 | 6 | Cardinale, Drug Topics Red Book, 1997.
| Flecainide | 12 | 0 | 870
| Propafenone | 15 | 0 | 870
| Amiodarone | 10 | 0 | 870
| Sotalol | 110 | 0 | 870
| Ibutilide/Dofetilide | 299 | 149 | 449
| Quinidine | 35/mo | 3 | 36
| Flecainide | 119/mo | 47 | 345
| Propafenone | 151/mo | 83 | 202
| Amiodarone | 98/mo | - | -
| Sotalol | 106 | 53 | 213
| TTE | 354 | 177 | 708 | Seto, Taira, Tsevat et al., J Am Coll Cardiol, 1997.
| TEE | 477 | 239 | 954
| Direct current cardioversion | 235 | 118 | 470
| Acute stroke | 9,006 | 4,503 | 18,012 | Ashraf, Hay, Pitt et al., Am J Cardiol, 1996; Bowen and Yaste, Neurology, 1994; Eckman, Levine, and Pauker, Chest, 1992; Lee, Huber, and Stason, Med Care, 1996; Persson, Silverberg, Lindgren et al., Intl J Technol Assess Health Care, 1990; Terent, Marke, Asplund et al., Stroke, 1994.
| Chronic stroke | 677/mo | 338 | 1,354 | Ashraf, Hay, Pitt et al., Am J Cardiol, 1996; Eckman, Levine, and Pauker, Chest, 1992; Lee, Huber, and Stason, Med Care, 1996; Persson, Silverberg, Lindgren et al., Intl J Technol Assess Health Care, 1990.
| Acute cerebral bleed | 14,410 | 7,205 | 28,820 | Ashraf, Hay, Pitt et al., Am J Cardiol, 1996; Bowen and Yaste, Neurology, 1994; Eckman, Levine, and Pauker, Chest, 1992; Lee, Huber, and Stason, Med Care, 1996; Persson, Silverberg, Lindgren et al., Intl J Technol Assess Health Care, 1990; Terent, Marke, Asplund et al., Stroke, 1994.
| Chronic cerebral bleed | 677/mo | 338 | 1,354 | Same as stroke
| Temporary bleed | 6,125 | 3,062 | 12,250 | Landefeld and Goldman, Am J Med, 1989. (GI Bld)
| Transient ischemic attack | 5,735 | 2,862 | 11,470 | Gage, Cardinalli, Albers et al., JAMA, 1995.
| Ventricular arrhythmia | 2,051 | 1,025 | 4,102 | Four hospital days - estimated
| Hospital day | 513 | 262 | 1,026 | Seto, Taira, Tsevat et al., J Am Coll Cardiol, 1997.
| Esophageal tear | 1,770 | 885 | 3,540 | Seto, Taira, Tsevat et al., J Am Coll Cardiol, 1997.
Utilities | Baseline | 1 | | | Assumed
| First stroke | 0.54 | 0.27 | 0.77 | Solomon, Glick, Russo et al., Stroke, 1994; Gage, Cardinalli, Albers et al., JAMA, 1995.
| Recurrent stroke | 0.12 | 0.06 | 0.24 | Gage, Cardinalli, Albers et al., JAMA, 1995.
| Temporary bleed | 0.76 | 0.38 | 0.88 | Gage, Cardinalli, Albers et al., JAMA, 1995.
| TIA | 0.75 | 0.375 | 0.875 | Gage, Cardinalli, Albers et al., JAMA, 1995.
| Ventricular arrhythmia | 0.75 | 0.375 | 0.875 | Assumed
| Death | 0 | | | Assumed
Adjustments | For being on warfarin | 0.988 | 0.92 | 1 | Gage, Cardinalli, Albers et al., JAMA, 1995.
| For being in atrial fibrillation | 0.92 | 0.84 | 1 | Gage, Cardinalli, and Owens, Arch Intern Med, 1996.
Discount | Costs and utilities | 3% | 0 | 7 | Gold, Siegel, Russell et al., Oxford Univ Press, 1996.

1 1) <65 and no risk factors, 2) 65-75 and no risk factors, 3) >75 and no risk factors, 4) <65 risk and > 1 risk factor, 5) 65-75 and > 1 risk factor, and 6) >75 and > 1 risk factor

* Rate is for first month. Subsequent months are calculated via the formula: rate for the Nth month = rate for the first month/N

NOTES: TTE = Transthoracic echocardiography, TEE = Transesophageal echocardiography, CNS = Central Nervous System.

The rate of reversion back to AF for patients not treated with medication could not be obtained directly from the literature because the trials had different followup periods. The rate was estimated from the available data based upon the rates for the control arms from our identified trials with at least 3 months' followup (Bellandi, Dabizzi, Niccoli et al., 1995; Van Gelder and Crijns, 1997; Karlson, Torstensson, Abjorn et al., 1988; Hillestad, Bjerkelund, Dale et al., 1971; Sodermark, Jonsson, Olsson et al., 1975; Stroobandt, Stiels, and Hoebrechts, 1997; Hartel, Louhija, Konttinen, 1974; UK Propafenone PSVT Study Group, 1995; Singh, 1998). In an attempt to best simulate the rate seen in patients, the simplest mathematical model that fit the data reasonably was sought. Upon inspection, neither a constant nor an exponential rate was consistent with the data. The simplest mathematical model that fit the data was: monthly rate = a baseline rate divided by the number of months since conversion. This model captured the initial high rate of failure within the first few months as well as the progressively lower rate of failure in later months. The rate of reversion back to atrial fibrillation for patients treated with antiarrhythmic therapy was assumed to be proportional to the rate in patients not treated with medications and was estimated from the strongest identified literature. Finally, rates of strokes and bleeds on warfarin and aspirin were calculated from the results of the meta-analysis (in Chapter 3, see Efficacy of Anticoagulants and Antiplatelet Agents in Management of AF and Meta-Analysis of Results).

For parameters not available in the clinical trial literature, we performed targeted searches that included the observational literature. The sources for all the parameters are listed in Table 4. All costs are stated in 1997 dollars, using the Medical Economics Index (http://www.hcfa.gov/stats/indicatr/indicatr.htm, Office of National Health Statistics) to estimate costs in 1997 dollars when presented in costs from previous years. We discounted costs and utilities by 3 percent per year, as recommended by the U.S. Public Health Task Force (Gold, Siegel, Russell et al., 1996).

### Analysis

#### General Features

Because the data from the clinical trial literature rarely encompass more than 5 years of followup, a 5-year horizon was used in the decision analysis. The cost-effectiveness was calculated from the perspective of society. A cost of less than $50,000 per quality-adjusted life-year (QALY) was considered cost-effective (Garner and Dardis, 1987; Hilner, Smith, and Desch, 1992).

#### Cardioversion and Antithrombosis

The base case analysis for cardioversion and antithrombotic therapy, using the best available estimates of each parameter, was performed for six different patient profiles based on age and stroke risk factor status (systolic hypertension, diabetes, or previous thromboembolic event): 55 years old with no risk factors, 65 years old with no risk factors, 75 years old with no risk factors, 55 years old with at least one risk factor, 65 years old with at least one risk factor, and 75 years old with at least one risk factor. The base case analysis was performed for the question of which strategy of cardioversion and subsequent maintenance was most cost-effective, for the question of whether aspirin or warfarin was more cost-effective, and for whether a cardioversion attempt was cost-effective.

Sensitivity analysis was performed to assess the robustness of our base case results as well as to identify areas of needed research. All relevant parameters were evaluated over a reasonable range for the patient profile of 75 years old with no risk factors. This age group was chosen because of the importance of AF in this age group. Other selected parameters were varied for the other subgroups as described in the results. In addition, to assess the implications of using a 5-year time frame in the base case analysis, a separate analysis was performed in which the horizon was extended to 20 years.

#### Outpatient Initiation of Antiarrhythmic Therapy

The potential economic savings that could result from outpatient initiation of antiarrhythmic therapy were evaluated by removing the cost of inpatient treatment from those antiarrhythmic agents for which inpatient initiation is currently deemed necessary (all agents except for amiodarone). Unfortunately, data were insufficient to permit assessment of the risks of initiating antiarrhythmic therapy on an outpatient basis.

#### Echocardiography-Guided Antithrombotic Therapy

To assess the cost-effectiveness of using transthoracic echocardiography and transesophageal echocardiography to help guide decisions about antithrombotic therapy, two additional strategies were evaluated for the antithrombotic therapy decision. First, for all six subgroups, the strategy was evaluated that employed warfarin for all patients with abnormal left-ventricular function on transthoracic echocardiography and aspirin for the rest of the patients. Second, for the subgroups with at least one risk factor, a strategy was evaluated that employed warfarin for patients with either left-atrial abnormality or complex aortic plaque on transesophageal echocardiography and aspirin for neither of these abnormalities. Data are not available on stroke rates of patients without risk factors stratified by results of transesophageal echocardiography. Analysis accounting for a decreased quality of life for warfarin therapy as well as one that did not account for such a decrease was evaluated.

## Results of Decision Analysis

### Base Case

The overall decision on whether to attempt cardioversion in a patient with new onset AF (key question 1) was analyzed by first assessing the relative cost-effectiveness of different strategies for attempting cardioversion (key questions 2 and 3) and comparing the preferred strategy with different strategies involving antithrombotic therapy without cardioversion (supplemental question 2). The population was assumed to include patients with new onset AF without a prior cardioversion attempt. This assumed length of followup was 5 years because the data from the clinical trials from which many of the probability inputs were obtained did not justify a longer followup for the base case analyses. The analysis took the perspective of society. A cost-effectiveness ratio under $50,000/QALY was considered cost-effective. For each set of strategies compared in the multistate transition Monte Carlo simulation model, we made 5,000 runs, producing a standard error of the mean for the total cost estimates of approximately $80 and a standard error of the mean for the estimated quality-adjusted survival of about 0.02 QALYs.

#### Cardioversion

For the scenario employing an attempt at cardioversion for a patient with new onset AF, the base case was performed assuming a 75-year-old man or woman without any risk factors for stroke (no systolic hypertension, diabetes mellitus, or previous history of thromboembolism). Seventeen strategies were evaluated. Seven strategies employed cardioversion without subsequent pharmacological maintenance (Strategies A-G in Figure 60)-electrical cardioversion and conversion using one of six antiarrhythmic agents (quinidine, flecainide, propafenone, amiodarone, sotalol, and ibutilide). Five strategies employed pharmacological conversion with subsequent therapy using the same agent for maintenance of sinus rhythm (Strategies H-L). Finally, five strategies employed electrical cardioversion with subsequent pharmacological maintenance therapy (Strategies M-Q).

##### Cost

For the strategies employing cardioversion alone (Table 5A), the strategy employing electrical cardioversion (A) was the least expensive (mean of $4,100 per patient over 5 years), and the one employing amiodarone (E) for acute cardioversion (without maintenance treatment) was the next least expensive. The lower estimated costs of these strategies were partly a result of the assumption that they can be performed in an outpatient setting. In contrast, one hospital day (estimated average cost: $513) was assumed for each of the other strategies employing pharmacological conversion without subsequent maintenance therapy. The remainder of the cost differential among the cardioversion-alone strategies was a result of varying medication costs and downstream event costs.

Table 5A. Results for Base Case for One Cardioversion Attempt Without Pharmacological Maintenance Therapy for Patients with New Onset Non-Postoperative Atrial Fibrillation (75 years old without risk factors^1^)

Strategy | | | Estimated 5-Year Costs | Estimated Quality-Adjusted Life-Years Over 5 Years | Marginal Cost | Marginal Quality-Adjusted Life-Years | Marginal Cost-Effectiveness Ratios
| Cardioversion | Maintenance | ($) | (QALY) | ($) | (QALY) | ($/QALY)
A | Electrical | None | 4,100 | 3.67 | | | Dominates ^2^
E | Amiodarone | None | 4,200 | 3.63 | | | Dominated by A
C | Flecainide | None | 4,420 | 3.66 | | | Dominated by A
B | Quinidine | None | 4,590 | 3.63 | | | Dominated by A
D | Propafenone | None | 4,640 | 3.65 | | | Dominated by A
G | Ibutilide | None | 4,680 | 3.66 | | | Dominated by A
F | Sotalol | None | 4,840 | 3.61 | | | Dominated by A

1 Risk factors include systolic hypertension, diabetes mellitus, and previous history of thromboembolism

2 Electrical cardioversion (A) has lower cost and higher effectiveness than the other strategies

NOTES: QALY = Quality-adjusted life-years. Costs rounded to the nearest $10, and QALYs rounded to the nearest 0.01.

Among the five strategies employing pharmacological conversion with subsequent pharmacological maintenance therapy (Table 5B), the strategy employing amiodarone was the least expensive. Similarly, among the five strategies employing electrical cardioversion with subsequent pharmacological maintenance therapy (Table 5C), the strategy employing amiodarone had the lowest estimated average costs. As mentioned previously, costs were lower predominantly because of the assumption that amiodarone can be started safely in an outpatient setting. The other pharmacological agents were assumed to require an initial 4-day hospital stay when used for maintenance therapy.

Table 5B. Results for Base Case for One Pharmacological Cardioversion Attempt With Pharmacological Maintenance Therapy^1^ for Patients with New Onset Non-Postoperative Atrial Fibrillation (75 years old without risk factors^2^)

Strategy | | | Estimated 5-Year Costs | Estimated Quality-Adjusted Life-Years Over 5 Years | Marginal Cost | Marginal Quality-Adjusted Life-Years | Marginal Cost-Effectiveness Ratios
| Cardioversion | Maintenance | ($) | (QALY) | ($) | (QALY) | ($/QALY)
K | Amiodarone | Amiodarone | 4,740 | 3.66 | * | * | *
H | Quinidine | Quinidine | 6,310 | 3.65 | | | Dominated by K
L | Sotalol | Sotalol | 6,670 | 3.62 | | | Dominated by K
I | Flecainide | Flecainide | 7,250 | 3.73 | 2,510 | 0.07 | 34,410
J | Propafenone | Propafenone | 7,630 | 3.70 | | | Dominated by I

1 Pharmacological maintenance therapy is discontinued if atrial fibrillation recurs

2 Risk factors include systolic hypertension, diabetes mellitus, and previous history of thromboembolism

* Numeric comparisons are with this strategy

QALY = Quality-adjusted life-years. Costs rounded to the nearest $10 and QALYs rounded to the nearest 0.01.

Table 5C. Results for Base Case for One Electrical Cardioversion Attempt With Pharmacological Maintenance Therapy^1^ for Patients with New Onset Non-Postoperative Atrial Fibrillation (75 years old without risk factors^2^)

Strategy | | | Estimated 5-year Costs | Estimated Quality-Adjusted Life-Years Over 5 Years | Marginal Cost | Marginal Quality-Adjusted Life-Years | Marginal Cost-Effectiveness Ratios
| Cardioversion | Maintenance | ($) | (QALY) | ($) | (QALY) | ($/QALY)
A | Electrical | None ^3^ | 4,100 | 3.67 | * | * | *
P | Electrical | Amiodarone | 5,150 | 3.72 | 1,050 | 0.06 | 18,100
M | Electrical | Quinidine | 6,030 | 3.71 | | | Dominated by P
Q | Electrical | Sotalol | 7,290 | 3.73 | 2,140 ^#^ | 0.01 ^#^ | 268,000 ^#^
N | Electrical | Flecainide | 7,470 | 3.72 | | | Dominated by Q
O | Electrical | Propafenone | 8,160 | 3.74 | 3,010 ^#^ | 0.02 ^#^ | 177,350 ^#^

1 Pharmacological maintenance therapy is discontinued if atrial fibrillation recurs

2 Risk factors include systolic hypertension, diabetes mellitus, and previous history of thromboembolism

3 Results for this strategy also appear in Table 2A

* Initial strategy with which subsequent strategies are compared unless otherwise noted

# Compared with electrical cardioversion and amiodarone maintenance (P)

NOTES: QALY= Quality-adjusted life-years. Costs rounded to the nearest $10 and QALYs rounded to the nearest 0.01.

When all of the strategies together were compared (Table 5D), the strategies employing cardioversion without maintenance therapy (A-G), in general, were less expensive than those employing maintenance therapy. For most of the strategies employing a particular antiarrhythmic agent for maintenance therapy, electrical cardioversion was less expensive than its corresponding pharmacological conversion (K vs. P, L vs. Q, I vs. N, and J vs. O).

Table 5D. Results for Base Case for One Cardioversion Attempt for Patients with New Onset Non-Postoperative Atrial Fibrillation (75 years old without risk factors^1^)

Strategy | | | Estimated 5-Year Costs | Estimated Quality-Adjusted Life-Years Over 5 Years | Marginal Cost | Marginal Quality-Adjusted Life-Years | Marginal Cost-Effectiveness Ratios
| Cardioversion | Maintenance | ($) | (QALY) | ($) | (QALY) | ($/QALY)
A | Electrical | None | 4,100 | 3.67 | * | * | *
E | Amiodarone | None | 4,200 | 3.63 | | | Dominated ^2^ by A
C | Flecainide | None | 4,420 | 3.66 | | | Dominated by A
B | Quinidine | None | 4,590 | 3.63 | | | Dominated by A
D | Propafenone | None | 4,640 | 3.65 | | | Dominated by A
G | Ibutilide | None | 4,680 | 3.66 | | | Dominated by A
K | Amiodarone | Amiodarone | 4,740 | 3.66 | | | Dominated by A
F | Sotalol | None | 4,840 | 3.61 | | | Dominated by A
P | Electrical | Amiodarone | 5,150 | 3.72 | 1,050 | 0.06 | 18,100
M | Electrical | Quinidine | 6,030 | 3.71 | | | Dominated by P
H | Quinidine | Quinidine | 6,310 | 3.65 | | | Dominated by P
L | Sotalol | Sotalol | 6,670 | 3.62 | | | Dominated by P
I | Flecainide | Flecainide | 7,250 | 3.73 | 2,100 ^3^ | 0.01 ^3^ | 262,500 ^3^
Q | Electrical | Sotalol | 7,290 | 3.73 | 2,140 ^3^ | 0.01 ^3^ | 268,000 ^3^
N | Electrical | Flecainide | 7,470 | 3.72 | | | Dominated by P
J | Propafenone | Propafenone | 7,630 | 3.70 | | | Dominated by P
O | Electrical | Propafenone | 8,160 | 3.74 | 3,010 ^3^ | 0.02 ^3^ | 177,350 ^3^

1 Risk factors include systolic hypertension, diabetes mellitus, and previous history of thromboembolism

2 Strategy has higher cost and lower effectiveness than comparison strategy

3 Compared with electrical cardioversion with amiodarone maintenance therapy (P)

* Initial strategy with which subsequent strategies are compared unless otherwise noted

NOTES: QALY= Quality-adjusted life-years. Costs rounded to the nearest $10 and QALYs rounded to the nearest 0.01.

##### Effectiveness

Among the strategies employing cardioversion alone (Table 5A), electrical cardioversion (A), flecainide (C), and ibutilide (G) were estimated to have the greatest mean estimated quality-adjusted survival (3.66, 3.66, and 3.67 QALYs, respectively). The effectiveness of these strategies was due primarily to the high efficacy of flecainide and ibutilide found in the meta-analysis of clinical trials, as well as the known high efficacy of electrical cardioversion. The effectiveness of the strategies employing the other pharmacological agents for cardioversion alone reflected the lower efficacy of these agents found in the meta-analysis of clinical trials.

The estimated effectiveness of the five strategies employing pharmacological maintenance therapy of sinus rhythm after successful pharmacological conversion (Table 5B) ranged from 3.62 QALYs for sotalol (L) to 3.73 QALYs for flecainide (I). The difference among these strategies depended more upon the efficacy of cardioversion than upon the efficacy of maintenance of sinus rhythm. The narrow range of estimated QALYs (3.71 to 3.74) among the strategies employing electrical cardioversion with maintenance therapy (Table 5C) also reflects the modest differences between agents in the efficacy of maintenance of sinus rhythm. In other words, the relative differences in efficacy of maintaining sinus rhythm among the various agents had little effect on the model's estimate of effectiveness. In the combined analysis (Table 5D), the strategies employing electrical cardioversion with pharmacological maintenance (M-Q) as well as the strategy employing flecainide conversion with flecainide maintenance therapy (I) had the greatest effectiveness.

##### Cost-effectiveness

The strategy employing electrical cardioversion (A in Table 5A) dominated (i.e., it was the least expensive and the most effective) those strategies attempting pharmacological conversion without maintenance therapy (B-G). Of note, the strategies employing flecainide (C) and ibutilide (G) for conversion were more expensive than electrical cardioversion (A) but were nearly as effective.

Among the strategies employing pharmacological conversion and maintenance therapy (Table 5B), the flecainide strategy (I) was the preferred strategy, costing $34,410/QALY compared with the next best strategy, which was amiodarone (K). Among the strategies employing electrical cardioversion with pharmacological maintenance therapy (Table 5C), the strategy employing amiodarone maintenance therapy (P) was the preferred strategy, dominating the strategy using quinidine and being more cost-effective than the strategies using sotalol, flecainide, or propafenone.

In the combined analysis (Table 5D), the incremental cost-effectiveness ratio for the strategy employing electrical cardioversion with amiodarone maintenance (P) compared with the strategy employing electrical cardioversion without maintenance (A) was $18,100/QALY, within the range of what is typically considered cost-effective care. No other strategy was projected to be cost-effective compared with the strategy employing electrical cardioversion with amiodarone maintenance (P). However, the estimated cost-effectiveness of alternative strategies was driven mainly by estimates of costs of related services (e.g., continuous electrocardiographic monitoring in the hospital). Unfortunately, because of limitations in the published data, the need for these services for the different antiarrhythmic agents was based on assumptions about the safety of outpatient initiation of therapy.

In summary, this part of the analysis suggests that the most cost-effective strategies for attempting cardioversion in patients with new onset AF are those employing electrical cardioversion, or pharmacological conversion using flecainide or ibutilide, followed by pharmacological maintenance therapy that can be started safely in an outpatient setting.

#### Antithrombotic Therapy

The decision about whether to use aspirin or warfarin for the prevention of stroke in patients with atrial fibrillation (supplemental question 2) principally involves a trade-off between the risk of thromboembolism on one side and the risk of hemorrhage and the cost and the inconvenience of taking warfarin on the other side.

The risk of thromboembolism has been shown to be dependent upon the age and risk factor status of the patient (Atrial Fibrillation Investigators, 1998). Thus, decision analysis was performed for each of six groups encompassing three ages (55, 65, and 75 years old), each with and without risk factors for thromboembolism (systolic hypertension, diabetes mellitus, or prior stroke or transient ischemic attack). Based on the data from the pooled analysis of control arms from the Atrial Fibrillation Investigators (Atrial Fibrillation Investigators, 1994), the risk of stroke was lower in the 75-year-old subgroup than in the 65-year-old subgroup without risk factors. Although a physiologic explanation may be contributing (e.g., healthy survivor effect), the lower ischemic stroke risk for the older group likely is the result of the imprecision of the estimate because of the small numbers of events in this analysis. This lower ischemic stroke risk in the older cohort without risk factors influences many of the following comparisons.

Because the inconvenience of taking warfarin is particularly difficult to quantify, the analysis is presented both with and without accounting for any decreased quality of life because of taking warfarin. In addition, presenting the results for each assumption highlights the influence of the quality-of-life effects of warfarin therapy on the preferred therapy for different patient subgroups, as has been demonstrated by Gage et al. (Gage, Cardinalli, and Owens, 1998).

In the analysis, that does not account for any decreased quality of life because of taking warfarin (Table 6A).

Table 6A. Results for Analysis Assuming No Decrease in Quality of Life on Warfarin Therapy: Comparison of Antithrombotic Therapy Strategies Without Cardioversion Attempt for Patients with New Onset Non-Postoperative Atrial Fibrillation

Strategy | Estimated 5-Year Costs | Estimated Quality-Adjusted Life-Years Over 5 Years | Marginal Cost | Marginal Quality-Adjusted Life-Years | Marginal Cost-Effectiveness Ratios
| ($) | (QALY) | ($) | (QALY) | ($/QALY)
55 years old, no risk factors^1^
Aspirin | 950 | 4.18
Warfarin | 4,970 | 4.14 | | | Dominated ^2^ by aspirin
65 years old, no risk factors
Aspirin | 3,150 | 3.87 | * | * | *
Warfarin | 5,900 | 3.93 | 2,750 | 0.06 | 48,250
75 years old, no risk factors
Aspirin | 1,020 | 3.68
Warfarin | 4,490 | 3.65 | | | Dominated ^2^ by aspirin
55 years old, one risk factor
Aspirin | 3,990 | 3.90 | * | * | *
Warfarin | 6,360 | 3.99 | 2,370 | 0.09 | 28,230
65 years old, one risk factor
Aspirin | 4,060 | 3.65 | * | * | *
Warfarin | 6,320 | 3.72 | 2,260 | 0.08 | 30,110
75 years old, one risk factor
Aspirin | 6,110 | 3.07 | * | * | *
Warfarin | 6,660 | 3.18 | 550 | 0.11 | 4,900

1 Risk factors include systolic hypertension, diabetes, and previous history of thromboembolism

The warfarin strategy has higher cost and lower effectiveness compared with the aspirin strategy

* Numeric comparisons are with the aspirin strategy within that subgroup

NOTES: QALY= Quality-adjusted life-years. Costs rounded to the nearest $10 and QALYs rounded to the nearest 0.01.

##### Cost

The estimated total cost of the aspirin strategy chiefly reflected the cost of events, whereas the estimated total cost of the warfarin strategy also incorporated the additional cost of warfarin therapy. The warfarin strategy was estimated to cost more than the aspirin strategy for all six subgroups. However, the differences in estimated costs between the strategies were greater for those subgroups with low stroke rates (e.g., 55 years old without risk factors) than for those with high stroke rates (e.g., 75 years old with risk factors).

##### Effectiveness

For the two subgroups with the lowest ischemic stroke risk (55 and 75 years old without risk factors), the estimated average quality-adjusted survival was higher for the aspirin strategy than for the warfarin strategy. For the other four subgroups with higher ischemic stroke risks, the average quality-adjusted survival was higher for the warfarin strategy than for the aspirin strategy, with the difference in average QALYs increasing with age.

##### Cost-effectiveness

The strategy employing aspirin dominates (lower cost with higher effectiveness) the strategy employing warfarin for two of the three subgroups without risk factors (55 and 75 years old). Using $50,000/QALY as the threshold for cost-effectiveness, for the 65-year-olds without risk factors subgroup ($48,250/QALY), the strategy employing warfarin is borderline cost-effective compared with aspirin. The warfarin strategy is more clearly cost-effective for anyone with a risk factor (cost-effectiveness ratios $28,230/QALY, $30,110/QALY, and $4,900/QALY for the 55-year-old, 65-year-old, and 75-year-old subgroups, respectively).

In terms of the trade-offs involved in antithrombotic therapy, for the groups with an ischemic stroke risk of approximately 3 percent per year-65 years old without risk factors and any age with risk factors-the increased reduction in this risk on warfarin therapy is worth the increased cost of warfarin therapy and the increased risk of bleed.

In the analysis, that does account for some decreased quality of life because of taking warfarin (Table 6B).

Table 6B. Results for Base Case Assuming Decrease in Quality of Life on Warfarin Therapy: Comparison for Antithrombotic Therapy Without Cardioversion Attempt for Patients with New Onset Non-Postoperative Atrial Fibrillation

Strategy | Estimated 5-Year Costs | Estimated Quality-Adjusted Life-Years Over 5 Years | Marginal Cost | Marginal Quality-Adjusted Life-Years | Marginal Cost-Effectiveness Ratios
| ($) | (QALY) | ($) | (QALY) | ($/QALY)
55 years old, no risk factors^1^
Aspirin | 950 | 4.17
Warfarin | 4,970 | 4.10 | | | Dominated ^2^ by aspirin
65 years old, no risk factors
Aspirin | 3,150 | 3.87
Warfarin | 5,900 | 3.86 | | | Dominated ^2^ by aspirin
75 years old, no risk factors
Aspirin | 1,020 | 3.68
Warfarin | 4,490 | 3.61 | | | Dominated ^2^ by aspirin
55 years old, one risk factor
Aspirin | 3,990 | 3.90 | * | * | *
Warfarin | 6,360 | 3.91 | 2,370 | 0.01 | 296,380
65 years old, one risk factor
Aspirin | 4,060 | 3.65 | * | * | *
Warfarin | 6,320 | 3.68 | 2,260 | 0.03 | 66,410
75 years old, one risk factor
Aspirin | 6,110 | 3.05 | * | * | *
Warfarin | 6,660 | 3.13 | 550 | 0.08 | 6,950

1 Risk factors include systolic hypertension, diabetes, and previous history of thromboembolism

2 The warfarin strategy has higher cost and lower effectiveness compared with the aspirin strategy

* Numeric comparisons are with the aspirin strategy within that subgroup

NOTES: QALY= Quality-adjusted life-years. Costs rounded to the nearest $10 and QALYs rounded to the nearest 0.01.

##### Cost

The estimated costs would not change based upon assumptions of quality of life.

##### Effectiveness

For any age subgroup without risk factors, the estimated average quality-adjusted survival was higher for the aspirin strategy than for the warfarin strategy. For the subgroups with risk factors, the average quality-adjusted survival was higher for the warfarin strategy than for the aspirin strategy, and the difference between the warfarin and aspirin strategies increased with age. However, the average estimated quality-adjusted survival for the aspirin and warfarin strategies was similar for the groups with intermediate risk-both subgroups with patients 65 years old and 55 years old with risk factors.

##### Cost-effectiveness

The strategy employing aspirin dominates (lower cost with higher effectiveness) the strategy employing warfarin for the three subgroups without risk factors. Using $50,000/QALY as the threshold for cost-effectiveness, the warfarin strategy is not cost-effective for those 55 years old with a risk factor ($296,380/QALY), it is nearly cost-effective for those 65 years old with a risk factor ($66,410/QALY), and it is clearly cost-effective for those 75 years old with a risk factor ($6,950/QALY).

In terms of the trade-offs involved in antithrombotic therapy, accounting for decreased quality of life due to taking warfarin, in patients with an ischemic stroke risk of approximately 4 to 6 percent per year, the increased reduction in this risk on warfarin therapy is balanced by the increase in risk of central nervous system bleed and the inconvenience of taking warfarin. Stroke risk substantially greater than 4 to 6 percent favors warfarin therapy, and stroke risk less than 4 to 6 percent favors aspirin therapy.

#### One Cardioversion Attempt Versus Antithrombotic Therapy Only

To evaluate the overall decision of whether to attempt cardioversion in a patient with new onset AF (key question 1), electrical cardioversion with pharmacological maintenance therapy, the most cost-effective cardioversion strategy, was compared with the most cost-effective antithrombotic strategy for each of the six age-risk subgroups.

In the analysis that does not account for any decreased quality of life because of taking warfarin (Table 7A):

Table 7A. Results for Analysis Assuming No Decrease in Quality of Life on Warfarin: Comparison for One Cardioversion Attempt Versus Antithrombotic Therapy Without Cardioversion Attempt for Patients with New Onset Non-Postoperative Atrial Fibrillation

Strategy | Estimated 5-Year Costs | Estimated Quality-Adjusted Life-Years Over 5 Years | Marginal Cost | Marginal Quality-Adjusted Life-Years | Marginal Cost-Effectiveness Ratios
| ($) | (QALY) | ($) | (QALY) | ($/QALY)
55 years old, no risk factors^1^
Aspirin | 950 | 4.18 | * | * | *
Electrical Cardioversion with Pharmacological Maintenance ^2^ | 3,300 | 4.26 | 2,350 | 0.09 | 27,610
65 years old, no risk factors
Warfarin | 5,900 | 3.93 | * | * | *
Electrical Cardioversion with Pharmacological Maintenance ^3^ | 6,510 | 4.01 | 610 | 0.08 | 7,560
75 years old, no risk factors
Aspirin | 1,020 | 3.68 | * | * | *
Electrical Cardioversion with Pharmacological Maintenance ^2^ | 3,140 | 3.76 | 2,120 | 0.087 | 24,370
55 years old,^3^ one risk factor
Warfarin | 6,360 | 3.99 | * | * | *
Electrical Cardioversion with Pharmacological Maintenance ^3^ | 6,950 | 4.08 | 590 | 0.09 | 6,620
65 years old,^3^ one risk factor
Warfarin | 6,320 | 3.72 | * | * | *
Electrical Cardioversion with Pharmacological Maintenance ^3^ | 6,860 | 3.82 | 540 | 0.10 | 5,480
75 years old,^3^ one risk factor
Warfarin | 6,660 | 3.18 | * | * | *
Electrical Cardioversion with Pharmacological Maintenance ^3^ | 7,000 | 3.28 | 340 | 0.10 | 3,470

1 Risk factors include systolic hypertension, diabetes, and previous history of thromboembolism

2 Aspirin therapy for those who relapse to AF

3 Warfarin therapy for those who relapse to AF

* Numeric comparisons are with this strategy

NOTES: QALY= Quality-adjusted life-years. Costs rounded to the nearest $10 and QALYs rounded to the nearest 0.01.

##### Cost

The cost of the strategy employing one attempt of cardioversion was greater than the cost of the strategy employing antithrombotic therapy for each of the age-risk subgroups. Of note, in the base case, electrical cardioversion with pharmacological maintenance therapy was assumed to be performed in an outpatient setting.

##### Effectiveness

The average estimated quality-adjusted survival was greater for the strategy employing one attempt of cardioversion than for the strategy employing antithrombotic therapy, for each of the age-risk subgroups.

##### Cost-effectiveness

The cost-effectiveness ratio of the strategy employing one attempt of cardioversion compared with the strategy employing antithrombotic therapy ranged from $3,470 to $27,610 per QALY, becoming more cost-effective (lower ratio) with increasing ischemic stroke risk.

In the analysis, that does account for some decreased quality of life because of taking warfarin (Table 7B).

Table 7B. Results for Base Case Assuming Decrease in Quality of Life on Warfarin Therapy: Comparison for One Cardioversion Attempt Versus Antithrombotic Therapy Without Cardioversion Attempt for Patients with New Onset Non-Postoperative Atrial Fibrillation

Strategy | Estimated 5-Year Costs | Estimated Quality-Adjusted Life-Years Over 5 Years | Marginal Cost | Marginal Quality-Adjusted Life-Years | Marginal Cost-Effectiveness Ratios
| ($) | (QALY) | ($) | (QALY) | ($/QALY)
55 years old, no risk factors^1^
Aspirin | 950 | 4.17 | * | * | *
Electrical Cardioversion with Pharmacological Maintenance ^2^ | 3,300 | 4.26 | 2,350 | 0.09 | 25,790
65 years old, no risk factors
Aspirin | 3,150 | 3.87 | * | * | *
Electrical Cardioversion with Pharmacological Maintenance ^2^ | 4,860 | 3.99 | 1,720 | 0.12 | 14,300
75 years old, no risk factors
Aspirin | 1,020 | 3.68 | * | * | *
Electrical Cardioversion with Pharmacological Maintenance ^2^ | 3,140 | 3.76 | 2,120 | 0.08 | 24,940
55 years old,^3^ one risk factor
Aspirin | 3,990 | 3.90 | * | * | *
Electrical Cardioversion with Pharmacological Maintenance ^2^ | 5,500 | 4.04 | 1,510 | 0.14 | 10,840
65 years old,^3^ one risk factor
Aspirin | 4,060 | 3.65 | * | * | *
Electrical Cardioversion with Pharmacological Maintenance ^2^ | 5,290 | 3.76 | 1,230 | 0.12 | 10,730
75 years old,^3^ one risk factor
Warfarin | 6,660 | 3.13 | * | * | *
Electrical Cardioversion with Pharmacological Maintenance ^3^ | 7,000 | 3.24 | 340 | 0.11 | 3,120

1 Risk factors include systolic hypertension, diabetes, and previous history of thromboembolism

2 Aspirin therapy for those who relapse to AF

3 Warfarin therapy for those who relapse to AF

* Numeric comparisons are with the aspirin strategy for that subgroup

NOTES: QALY= Quality-adjusted life-years. Costs rounded to the nearest $10 and QALYs rounded to the nearest 0.01.

##### Cost

The cost of the strategy employing one attempt of cardioversion was greater than the cost of the strategy employing antithrombotic therapy for each of the age-risk subgroups.

##### Effectiveness

The average estimated quality-adjusted survival was greater in the strategy employing one attempt of cardioversion than in the strategy employing antithrombotic therapy for each of the age-risk subgroups. Of note, accounting for a decrease in quality of life because of taking warfarin affects not only the magnitude of the differences between strategies but also which strategies are compared. For example, when accounting for a decrease in quality of life because of warfarin, aspirin is the preferred antithrombotic strategy for five of the subgroups; when not accounting for it, warfarin is the preferred antithrombotic strategy in four of the subgroups.

##### Cost-effectiveness

The cost-effectiveness ratio of the strategy employing one attempt of cardioversion compared with the strategy employing antithrombotic therapy ranged from $3,120 to $25,790 per QALY, becoming more cost-effective (lower ratio) with increasing ischemic stroke risk. These cost-effectiveness ratios are not substantially different from those obtained when assuming no decrease in quality of life because of taking warfarin (Table 7A).

### Sensitivity Analysis

To assess the robustness of our base case results as well as to identify areas of needed research, all variables in the model (Table 4) were varied over a reasonable range for one subgroup (75 years old without risk factors), and other selected variables were varied for the other subgroups. The most relevant analyses are discussed below. Of note, sensitivity analysis used the model that accounted for a decrease in quality of life.

#### Outpatient Initiation of Antiarrhythmic Therapy

As noted previously, amiodarone was the only antiarrhythmic agent that was considered by our core experts to be a drug that could be started safely for a wide range of patients in the outpatient setting. This assumption accounted for most of the difference in cost among the strategies employing electrical cardioversion and pharmacological maintenance. If no cost of inpatient initiation was assumed, quinidine was the most cost-effective agent for maintenance of sinus rhythm (Table 8A). According to the calculated cost-effectiveness ratios, the higher medication costs of the other antiarrhythmic agents compared with quinidine were not worth the higher efficacy for maintenance therapy and the lower ventricular arrhythmia risk. However, our core experts expressed the most reservations about quinidine when discussing outpatient initiation of antiarrhythmic therapy because of the risks of ventricular arrhythmias.

Table 8A. Results of Sensitivity Analysis Assuming No Inpatient Antiarrhythmic Initiation Cost: One Pharmacological Cardioversion Attempt with Pharmacological Maintenance Therapy for Patients with New Onset Non-Postoperative Atrial Fibrillation (75 Years Old Without Risk Factors^1^)

Strategy | | | Estimated 5-Year Costs | Estimated Quality-Adjusted Life-Years Over 5 Years | Marginal Cost | Marginal Quality-Adjusted Life-Years | Marginal Cost-Effectiveness Ratios
| Cardioversion | Maintenance | ($) | (QALY) | ($) | (QALY) | ($/QALY)
A | Electrical | None | 4,100 | 3.67 | * | * | *
M | Electrical | Quinidine | 4,390 | 3.71 | 290 | 0.04 | 6,600
K | Electrical | Amiodarone | 5,150 | 3.72 | 1,170 ^2^ | 0.01 ^2^ | 54,110 ^2^
Q | Electrical | Sotalol | 5,650 | 3.73 | 1,260 ^2^ | 0.02 ^2^ | 60,100 ^2^
N | Electrical | Flecainide | 5,830 | 3.72 | 1,440 ^2^ | 0.01 ^2^ | 102,790 ^2^
O | Electrical | Propafenone | 6,520 | 3.74 | 2,140 ^2^ | 0.03 ^2^ | 68,810 ^2^

1 Risk factors include systolic hypertension, diabetes, and previous history of thromboembolism

2 Compared with electrical cardioversion with quinidine maintenance therapy (M)

* Numeric comparisons are with this strategy unless otherwise noted

NOTES: QALY = Quality-adjusted life-years. Costs rounded to the nearest $10 and QALYs rounded to the nearest 0.01.

In the overall comparison of whether to attempt cardioversion, outpatient initiation of antiarrhythmic therapy was assumed in the base case. If the cost of inpatient initiation was added, the cost-effectiveness ratios for electrical cardioversion with maintenance therapy compared with antithrombotic therapy increases (Table 8B). In fact, for two of the subgroups (55 and 75 years old without risk factors), the ratio was near the threshold of what is considered cost effective ($54,310/QALY and $49,080/QALY, respectively).

Table 8B. Results of Sensitivity Analysis Assuming Four Days of Hospitalization for Antiarrhythmic Initiation: Comparison for One Cardioversion Attempt Versus Antithrombotic Therapy Without Cardioversion Attempt for Patients with New Onset Non-Postoperative Atrial Fibrillation

Strategy | Estimated 5-Year Costs | Estimated Quality-Adjusted Life-Years Over 5 Years | Marginal Cost | Marginal Quality-Adjusted Life-Years | Marginal Cost-Effectiveness Ratios
| ($) | (QALY) | ($) | (QALY) | ($/QALY)
55 years old, no risk factors^1^
Aspirin | 950 | 4.17 | * | * | *
Electrical Cardioversion with Pharmacological Maintenance ^2^ | 4,940 | 4.26 | 3,990 | 0.09 | 49,220
65 years old, no risk factors
Aspirin | 3,150 | 3.87 | * | * | *
Electrical Cardioversion with Pharmacological Maintenance ^2^ | 6,500 | 3.99 | 3,360 | 0.12 | 27,970
75 years old, no risk factors
Aspirin | 1,020 | 3.68 | * | * | *
Electrical Cardioversion with Pharmacological Maintenance ^2^ | 4,780 | 3.76 | 3,760 | 0.08 | 44,240
55 years old,^3^ one risk factor
Aspirin | 3,990 | 3.90 | * | * | *
Electrical Cardioversion with Pharmacological Maintenance ^2^ | 7,140 | 4.04 | 3,150 | 0.14 | 22,630
65 years old,^3^ one risk factor
Aspirin | 4,060 | 3.65 | * | * | *
Electrical Cardioversion with Pharmacological Maintenance ^2^ | 6,930 | 3.76 | 2,874 | 0.12 | 24,990
75 years old,^3^ one risk factor
Warfarin | 6,660 | 3.13 | * | * | *
Electrical Cardioversion with Pharmacological Maintenance ^3^ | 8,640 | 3.24 | 1,980 | 0.11 | 18,310

1 Risk factors include systolic hypertension, diabetes, and previous history of thromboembolism

2 Aspirin therapy for those who relapse to AF

3 Warfarin therapy for those who relapse to AF

* Numeric comparisons are with the aspirin strategy for that subgroup

NOTES: QALY= Quality-adjusted life-years. Costs rounded to the nearest $10 and QALYs rounded to the nearest 0.01.

#### Time Horizon

A 5-year horizon was assumed in the base case analysis. Extending the time horizon for comparison of antithrombotic therapy to 20 years (Table 9A compared with the base case analysis of Table 6B), the aspirin strategy remains preferred for the lowest risk groups (55 and 75 years old without risk factors). However, the warfarin strategy becomes cost-effective for the three intermediate risk subgroups (65 years old without risk factors and 55 and 65 years old with risk factors). The warfarin strategy becomes dominant over aspirin in the subgroup that is 75 years old with risk factors. One explanation for this improvement in the overall cost-effectiveness of the warfarin strategy is that the absolute risk reduction with warfarin increases as the stroke risk increases with increased age.

Table 9A. Results for Sensitivity Analysis Assuming 20-Year Horizon: Comparison of Antithrombotic Therapy Strategies Without Cardioversion Attempt for Patients with New Onset Non-Postoperative Atrial Fibrillation

Strategy | Estimated 5-Year Costs | Estimated Quality-Adjusted Life-Years Over 5 Years | Marginal Cost | Marginal Effectiveness | Marginal Cost-Effectiveness Ratios
| ($) | (QALY) | ($) | (QALY) | ($/QALY)
55 years old, no risk factors^1^
Aspirin | 7,180 | 11.01
Warfarin | 14,630 | 10.90 | | | Dominated ^2^ by aspirin
65 years old, no risk factors
Aspirin | 9,820 | 8.55 | * | * | *
Warfarin | 14,380 | 8.67 | 4,560 | 0.12 | 38,010
75 years old, no risk factors
Aspirin | 2,580 | 5.60
Warfarin | 7,410 | 5.52 | | | Dominated ^2^ by aspirin
55 years old, > one risk factor
Aspirin | 14,940 | 8.60 | * | * | *
Warfarin | 17,830 | 9.09 | 2,900 | 0.51 | 5,700
65 years old, > one risk factor
Aspirin | 13,810 | 6.72 | * | * | *
Warfarin | 15,680 | 6.97 | 1,880 | 0.21 | 8,940
75 years old, > one risk factor
Aspirin | 13,900 | 4.08 | | | Dominated ^3^ by warfarin
Warfarin | 11,970 | 4.08

1 Risk factors include systolic hypertension, diabetes, and previous history of thromboembolism

The warfarin strategy has higher cost and lower effectiveness compared with the aspirin strategy

3 The aspirin strategy has higher cost and lower effectiveness compared with the warfarin strategy

* Numeric comparisons are with the aspirin strategy within that subgroup

NOTES: QALY = Quality-adjusted life-years. Costs rounded to the nearest $10 and QALYs rounded to the nearest 0.01.

Extending the horizon to 20 years for the decision whether to attempt cardioversion or give antithrombotic therapy without cardioversion reveals improved cost-effectiveness for the electrical cardioversion with maintenance therapy strategy (Table 9B compared with Table 7B).

Table 9B. Results of Sensitivity Analysis Assuming 20-Year Horizon: Comparison of One Cardioversion Attempt Versus Antithrombotic Therapy Without Cardioversion Attempt for Patients with New Onset Non-Postoperative Atrial Fibrillation

Strategy | Estimated 5-Year Costs | Estimated Quality-Adjusted Life-Years Over 5 Years | Marginal Cost | Marginal Quality-Adjusted Life-Years | Marginal Cost-Effectiveness Ratios
| ($) | (QALY) | ($) | (QALY) | ($/QALY)
55 years old, no risk factors^1^
Aspirin | 7,190 | 11.01 | * | * | *
Electrical Cardioversion with Pharmacological Maintenance ^2^ | 10,690 | 11.28 | 3,500 | 0.27 | 12,930
65 years old, no risk factors
Warfarin | 14,380 | 8.67 | * | * | *
Electrical Cardioversion with Pharmacological Maintenance ^3^ | 14,780 | 8.98 | 390 | 0.32 | 1,240
75 years old, no risk factors
Aspirin | 2,580 | 5.60 | * | * | *
Electrical Cardioversion with Pharmacological Maintenance ^2^ | 4,960 | 5.76 | 2,380 | 0.16 | 14,800
55 years old, > one risk factor
Warfarin | 17,830 | 9.09
Electrical Cardioversion with Pharmacological Maintenance ^3^ | 16,030 | 9.40 | | | Dominates ^4^ Warfarin
65 years old, > one risk factor
Warfarin | 15,680 | 6.97 | * | * | *
Electrical Cardioversion with Pharmacological Maintenance ^3^ | 15,930 | 7.19 | 240 | 0.22 | 1,120
75 years old, > one risk factor
Warfarin | 11,970 | 4.08 | * | * | *
Electrical Cardioversion with Pharmacological Maintenance ^3^ | 12,470 | 4.23 | 500 | 0.15 | 3,390

1 Risk factors include systolic hypertension, diabetes, and previous history of thromboembolism

Aspirin therapy for those who relapse to AF

3 Warfarin therapy for those who relapse to AF

4 The electrical cardioversion with pharmacological maintenance has lower cost and higher effectiveness than the warfarin strategy

* Numeric comparisons are with this strategy within the subgroup

NOTES: QALY= Quality-adjusted life-years. Costs rounded to the nearest $10 and QALYs rounded to the nearest 0.01.

#### Other Sensitivity Analyses

In the antithrombotic therapy analysis, the only parameter varied in sensitivity analysis for patients 75 years old without risk factors that substantially changed the result was the ischemic stroke rate. As mentioned previously, this subgroup had a low base case rate (0.9 percent/year) as determined by the Atrial Fibrillation Investigators (Atrial Fibrillation Investigators, 1994). With the upper limit of the 95 percent confidence interval for this estimate (6.7 percent/year), the cost-effectiveness of the warfarin strategy was $28,480/QALY.

Similarly, for the decision whether to attempt cardioversion in patients 75 years old with risk factors, none of the variables tested substantially changed the results (Table 10). Specifically, the variables tested were the rate of central nervous system bleed on warfarin, the ischemic stroke risk reduction with warfarin, the ischemic stroke risk reduction with sinus rhythm, the relative rate of relapse to AF on antiarrhythmic agent, the rate of ventricular arrhythmia on antiarrhythmic agent, the increased mortality due to either AF or having risk factors, the utility of the chronic health state, the utility of being in AF, the cost of warfarin, and the cost of antiarrhythmic agent.

Table 10. Sensitivity Analysis for One Cardioversion Attempt Versus Warfarin Therapy for Patients with New Onset Non-Postoperative Atrial Fibrillation (75 years old with risk factors^1^)

| | Electrical Cardioversion with Pharmacological Maintenance (ECV/PM) | | Warfarin
Variable | Value | Estimated 5-Year Costs | Estimated Quality-Adjusted Life-Years Over 5 Years | Estimated 5-Year Costs | Estimated Quality-Adjusted Life-Years Over 5 Years | Incremental Cost ^2^ | Incremental Quality-Adjusted Life-Years ^2^ | Incremental Cost-Effectiveness Ratios ^2^
| | ($) | (QALY) | ($) | (QALY) | ($) | (QALY) | ($/QALY)
CNS Bleed Rate | 0.15%/yr | 6,640 | 3.26 | 6,130 | 3.16 | 520 | 0.10 | 5,380
| 1.8%/yr | 7.760 | 3.20 | 7.,820 | 3.05 | (65) | 0.16 | ECV/PM Dominates ^3^
Ischemic Stroke Risk on Warfarin Compared with No Treatment | 0.19 | 6,350 | 3.28 | 5,670 | 3.19 | 690 | 0.09 | 7,310
Ischemic Stroke Risk on Warfarin Compared with No Treatment | 0.48 | 7,570 | 3.21 | 7,610 | 3.08 | (45) | 0.14 | ECV/PM Dominates
Relative Risk of Ischemic Stroke in Sinus Rhythm Compared with AF | 0.2 | 6,460 | 3.25 | 6,260 | 3.13 | 200 | 0.12 | 1,740
Relative Risk of Ischemic Stroke in Sinus Rhythm Compared with AF | 0.5 | 7,360 | 3.22 | 6,310 | 3.13 | 1,050 | 0.09 | 11,420
Relative Rate of Relapse to AF on Antiarrhythmic Agent Compared with No Treatment | 0.3 | 7,040 | 3.29 | 6,660 | 3.13 | 380 | 0.16 | 2,350
Relative Rate of Relapse to AF on Antiarrhythmic Agent Compared with No Treatment | 0.85 | 7,060 | 3.19 | 6,660 | 3.13 | 410 | 0.60 | 7,020
Rate of Ventricular Arrhythmia on Antiarrhythmic Agent | 0.12%/yr | 7,060 | 3.25 | 6,660 | 3.13 | 410 | 0.12 | 3,360
Rate of Ventricular Arrhythmia on Antiarrhythmic Agent | 1.2%/yr | 6,980 | 3.22 | 6,660 | 3.13 | 320 | 0.08 | 3,760
Increased Mortality Due to Atrial Fibrillation | 8% | 7,290 | 3.38 | 6,870 | 3.27 | 420 | 0.11 | 3,740
Increased Mortality Due to Atrial Fibrillation | 59% | 5,310 | 3.10 | 6,380 | 3.00 | (70) | 0.10 | ECV/PM Dominates
Increased Mortality Due to Risk Factors | 36% | 7,450 | 3.44 | 6,950 | 3.32 | 500 | 0.12 | 4,140
Increased Mortality Due to Risk Factors | 117% | 6,420 | 3.09 | 6,350 | 2.99 | 90 | 0.10 | 930
Utility of Chronic Stroke Health State | 0.27 | 7,000 | 3.12 | 6,660 | 3.11 | 340 | 0.10 | 3,390
Utility of Chronic Stroke Health State | 0.77 | 7,000 | 3.26 | 6,660 | 3.20 | 340 | 0.05 | 6,710
Utility for Having AF | 0.84 | 7,000 | 3.09 | 6,660 | 2.89 | 340 | 0.20 | 1,750
| 1 | 7,000 | 3.41 | 6,660 | 3.38 | 340 | 0.03 | 12,670
Cost of Warfarin | $45/mo | 5,900 | 3.24 | 5,180 | 3.13 | 720 | 0.11 | 6,670
| $108/mo | 7,640 | 3.24 | 7,770 | 3.13 | (130) | 0.11 | ECV/PM Dominates
Cost of Antiarrhythmic Agent | $35/mo | 5,360 | 3.24 | 6,290 | 3.13 | (930) | 0.11 | ECV/PM Dominates
| $151/mo | 7,840 | 3.24 | 6,950 | 3.13 | (880) | 0.11 | 8,180
Discount | 0 | 7,480 | 3.46 | 7,150 | 3.35 | 330 | 0.12 | 2,870
| 7% | 6,410 | 2.97 | 6,070 | 2.87 | 340 | 0.10 | 3,430

1 Risk factors include systolic hypertension, diabetes, and previous history of thromboembolism

2 Electrical cardioversion with pharmacological maintenance compared with warfarin

Electrical cardioversion with pharmacological maintenance has lower cost and higher effectiveness compared with warfarin

NOTES: QALY = Quality-adjusted life years. Costs rounded to the nearest $10 and QALYs rounded to the nearest 0.01.

### Echocardiography-Guided Antithrombotic Therapy

As discussed previously, the decision of which antithrombotic agent to use for the treatment of patients with AF involved a trade-off between risk of ischemic stroke and risk of bleed (as well as the cost and inconvenience of warfarin therapy). The cost-effectiveness of using transthoracic echocardiography and transesophageal echo¡cardiography to guide antithrombotic therapy was evaluated using data from the Atrial Fibrillation Investigators (Atrial Fibrillation Investigators, 1994) and from SPAF III (Stroke Prevention in Atrial Fibrillation III, 1996). A transthoracic echocardiography strategy option for all subgroups and a transesophageal echocardiography strategy option for the subgroups with risk factors were added and compared with the strategies employing aspirin or warfarin in all patients (Figure 62).

Figure 62. Echocardiography-guided antithrombotic therapy

In the analysis that did not account for a decrease in quality of life for taking warfarin, the transthoracic echocardiography strategy was not cost-effective for the subgroups of patients 55 or 65 years old without risk factors, but it was cost-effective for the subgroup of patients 75 years old without risk factors (Table 11A).

Table 11A. Results for Analysis Assuming No Decrease in Quality of Life for Taking Warfarin: Comparison of Echocardiography-Guided Antithrombotic Therapy Without Cardioversion Attempt for Patients with New Onset Non-Postoperative Atrial Fibrillation

Strategy | Estimated 5-Year Costs | Estimated Quality-Adjusted Life-Years Over 5 Years | Incremental Cost | Incremental Effectiveness | Incremental Cost-Effectiveness Ratios
| ($) | (QALY) | ($) | (QALY) | ($/QALY)
55 years old, no risk factors^1^
Aspirin | 950 | 4.18 | * | * | *
Transthoracic Echocardiography | 1,470 | 4.18 | | | Dominated ^3^
Warfarin | 4,970 | 4.14 | | | Dominated ^3^
65 years old, no risk factors
Aspirin | 3,150 | 3.87 | * | * | *
Transthoracic Echocardiography | 3,860 | 3.87 | 710 | 0.00 | 356,000
Warfarin | 5,900 | 3.93 | 2,750 | 0.06 | 48,250
75 years old, no risk factors
Aspirin | 1,020 | 3.68 | * | * | *
Transthoracic Echocardiography | 1,620 | 3.72 | 600 | 0.04 | 13,220
Warfarin | 4,490 | 3.65 | | | Dominated ^3^
55 years old, > one risk factor
Aspirin | 3,990 | 3.89 | * | * | *
Transesophageal Echocardiography | 4,050 | 4.00 | 60 | 0.11 | 540
Transthoracic Echocardiography | 4,700 | 3.91 | 710 | 0.02 | 31,040 ^4^
Warfarin | 6,360 | 3.99 | 2,370 | 0.10 | 23,480 ^4^
65 years old, > one risk factor
Aspirin | 4,060 | 3.65 | * | * | *
Transesophageal Echocardiography | 4,080 | 3.74 | 20 | 0.09 | 210
Transthoracic Echocardiography | 4,530 | 3.66 | 470 | 0.02 | 29,310 ^4^
Warfarin | 6,320 | 3.72 | 2,260 | 0.08 | 30,110 ^4^
75 years old > one risk factor^1^
Aspirin | 6,110 | 3.07 | * | * | * ^2^
Transesophageal Echocardiography | 6,290 | 3.15 | 180 | 0.08 | 2,400 ^3^
Transthoracic Echocardiography | 6,580 | 3.09 | 470 | 0.02 | 21,280 ^4^
Warfarin | 6,660 | 3.18 | 550 | 0.11 | 4,900 ^5^

Risk factors include systolic hypertension, diabetes, and previous history of thromboembolism

Aspirin has lower cost and higher effectiveness compared with warfarin and transthoracic echocardiography

3 Strategy is dominated by the reference strategy (higher cost and lower effectiveness than standard)

4 Strategy is dominated by the transesophageal echocardiography strategy

The warfarin strategy costs $11,530/QALY compared with the transesophageal echocardiography strategy

* All comparisons with this standard strategy

NOTES: QALY = Quality-adjusted life years. Cost rounded to the nearest $10 and QALYs rounded to the nearest 0.01.

For the subgroups of patients 55 years old and 65 years old with risk factors, the transesophageal echocardiography strategy was most cost-effective. In fact, this strategy dominated the transthoracic echocardiography strategy and the warfarin strategy in these subgroups. Also, the CER compared with aspirin was under $600/QALY for each age group. For the subgroup of patients 75 years old with risk factors, the warfarin strategy was cost-effective ($11,530/QALY) compared with the transesophageal echocardiography strategy.

In the analysis that accounted for a decrease in quality of life for taking warfarin, the aspirin strategy dominated the transthoracic echocardiography strategy for patients 55 years old without risk factors (Table 11B). However, for the other two subgroups without risk factors, the transthoracic echocardiography strategy was cost-effective. For these two latter subgroups, the ability to identify a higher risk subgroup for warfarin therapy resulted in improved outcomes and was worth the cost of transthoracic echocardiography.

Table 11B. Base Case for Echocardiography-Guided Anithtrombotic Therapy Assuming No Cardioversion Attempt for Patients with New Onset Non-Postoperative Atrial Fibrillation

Strategy | Estimated 5-Year Costs | Estimated Quality-Adjusted Life-Years Over 5 Years | Incremental Cost | Incremental Effectiveness | Incremental Cost-Effectiveness Ratios
| ($) | (QALY) | ($) | (QALY) | ($/QALY)
55 years old, no risk factors^1^
Aspirin | 950 | 4.17 | | | Dominates ^2^
Transthoracic Echocardiography | 1,470 | 4.16 | | | ^3^
Warfarin | 4,970 | 4.10 | | | ^3^
65 years old, no risk factors
Aspirin | 3,150 | 3.87 | | | *
Transthoracic Echocardiography | 3,860 | 3.88 | 710 | 0.01 | 64,820
Warfarin | 5,900 | 3.86 | | | ^3^
75 years old, no risk factors
Aspirin | 1,020 | 3.68 | | | *
Transthoracic Echocardiography | 1,620 | 3.72 | 600 | 0.04 | 14,170
Warfarin | 4,490 | 3.51 | | | ^3^
55 years old, > one risk factor
Aspirin | 3,990 | 3.90 | | | *
Transesophageal Echocardiography | 4,050 | 3.97 | 60 | 0.06 | 910
Transthoracic Echocardiography | 4,700 | 3.93 | 710 | 0.03 | 26,440 ^4^
Warfarin | 6,360 | 3.91 | 2,370 | 0.01 | 296,380 ^4^
65 years old, > one risk factor
Aspirin | 4,060 | 3.65 | | | *
Transesophageal Echocardiography | 4,080 | 3.72 | 20 | 0.07 | 250
Transthoracic Echocardiography | 4,530 | 3.65 | 470 | 0.00 | 156,330 ^4^
Warfarin | 6,320 | 3.68 | 2,260 | 0.03 | 66,410 ^4^
75 years old, > one risk factor
Aspirin | 6,110 | 3.05 | | | *
Transesophageal Echocardiography | 6,290 | 3.16 | 180 | 0.11 | 1,600
Transthoracic Echocardiography | 6,580 | 3.10 | 470 | 0.04 | 10,590 ^4^
Warfarin | 6,660 | 3.13 | 550 | 0.08 | 6,950 ^4^

1 Risk factors include systolic hypertension, diabetes, and previous history of thromboembolism

2 Aspirin has lower cost and higher effectiveness compared with warfarin or transthoracic echocardiography

3 Strategy is dominated by reference strategy (higher cost and lower effectiveness than for reference)

4 Strategy is dominated by transesophageal echocardiography strategy

* Reference strategy for any numerical comparison

NOTES: QALY = Quality-adjusted life years. Cost rounded to the nearest $10 and QALYs rounded to the nearest 0.01.

For the subgroups with risk factors, the transesophageal echocardiography strategy was cost-effective compared with the aspirin strategy, and it dominated the warfarin and transthoracic echocardiography strategies. In other words, the ability of transesophageal echocardiography to risk-stratify these patients was worth the added cost.

## Discussion

The results of this decision analysis strongly support at least one attempt of electrical cardioversion with subsequent antiarrhythmic maintenance therapy in all risk groups over the age of 55. However, some issues arose that influenced this analysis.

First, although electrical cardioversion was preferred over pharmacological conversion, conversion using ibutilide or flecainide was nearly as effective. The cost-effectiveness was influenced predominantly by the assumptions of increased cost due to inpatient services necessary for the initiation of the pharmacological agents, whereas electrical cardioversion could be performed in an outpatient setting.

Second, the choice of antiarrhythmic agent for subsequent maintenance of sinus rhythm was influenced less by the differing efficacies of the antiarrhythmic agents than by assumptions of safety regarding initiation of therapy. Unfortunately, few data are available regarding outpatient initiation of therapy. The indirect data that are available suggest a substantial incidence of arrhythmia in the first few days of therapy (Maisel, Kuntz, Reimold et al., 1997; Chung, Schweikert, Wikoff et al., 1998). These studies found life-threatening ventricular arrhythmias in about 1 to 2 percent of patients and worrisome arrhythmic complications in about 15 to 20 percent of patients. The relative rates of these incidences among different antiarrhythmic agents, particularly for amiodarone, are not known. Our assumption that amiodarone was the only agent that could be started safely as an outpatient strongly influenced the analysis, identifying amiodarone as the most cost-effective agent. However, amiodarone has not been tested adequately in randomized clinical trials. Thus, studies comparing the safety and efficacy of outpatient initiation of amiodarone with inpatient and outpatient initiation of different antiarrhythmic agents are needed to determine the appropriateness of outpatient-based approaches to the initial management of AF.

Third, the choice between warfarin and aspirin for stroke prevention was influenced strongly by the underlying risk of ischemic stroke. This risk for the model was obtained from a pooled analysis of the placebo arms of three large trials (Atrial Fibrillation Investigators, 1994). However, this pooled analysis found a "u-shaped" risk with increasing age for those without risk factors for thromboembolism. In other words, the risk was low (<1 percent/year) in patients 55 years old and 75 years old but higher (3.9 percent/year) in patients 65 years old. Although a true clinical explanation may be made (e.g., healthy survivor effect), the lower ischemic stroke risk for the older group may be due to the imprecision of the estimate due to small numbers of events. This lower ischemic stroke risk in the older cohort without risk factors influences many of the comparisons. This "u-shaped" risk pattern was not observed in those patients with risk factors.

Fourth, the effect of taking warfarin on quality of life also influences many of the comparisons. In particular, for the comparison between warfarin and aspirin when cardioversion is not attempted, if no decrease in quality of life due to taking warfarin is assumed, warfarin is cost-effective for most risk groups. Only in the low-risk groups-55 years old without risk factors and 75 years old without risk factors-is it cost-effective to use aspirin. However, if a decrease in quality of life due to taking warfarin is assumed, warfarin is cost-effective in only the highest risk group, 75 years old with risk factors. More information on how individual patients view the quality-of-life effects of warfarin would enhance the ability to tailor decisions to the preferences of individual patients.

Fifth, the choice of horizon presented a trade-off. Ideally, clinical decisions about management of non-postoperative AF should be made based on a long-time horizon; however, rarely did the data in the literature present outcomes after 5 years. In fact, the trials studying maintenance of sinus rhythm rarely followed patients longer than 1 year.

Sixth, the use of transthoracic echocardiography and transesophageal echocardiography to guide antithrombotic therapy is projected to increase the cost-effectiveness of conservative therapy (no cardioversion attempt). These results suggest that these modalities can be used to identify subgroups of patients where it may not be cost-effective to attempt cardioversion.

Finally, with regard to a technical consideration of Monte Carlo modeling, only a finite number of trials (5,000) were run for each comparison. Many of the comparisons showed minimal differences in the estimates of the outcomes, particularly for QALYs, between strategies. Small variations due to chance may have influenced some of the results. As stated previously, the standard error of the mean for the total cost estimates was approximately $80 and the standard error of the mean for the estimates of quality-adjusted survival was 0.02 QALYs.

## Conclusions

- One attempt of electrical cardi`oversion with pharmacological maintenance therapy is cost-effective compared with conservative antithrombotic therapy alone for all patients 55 years of age or older, regardless of risk factors.
- If antiarrhythmic therapy can be started safely in an outpatient setting, the cost-effectiveness of an attempt of electrical cardioversion with pharmacological maintenance therapy is improved considerably. However, more research is needed in this area to determine the safety of this practice.
- For patients at low risk of stroke (~1 percent/year), aspirin is the preferred therapy. For patients with a high risk of stroke (~10 percent/year), warfarin is the preferred strategy. For those with an intermediate risk of ischemic stroke (~3--6 percent/year), aspirin therapy is preferred if quality of life is assumed to be decreased by taking warfarin. If no decrease in quality of life is assumed, warfarin is preferred for the intermediate-risk groups.
- Transthoracic echocardiography is projected to be a cost-effective test for guiding decisions about the choice of antithrombotic treatment in patients without risk factors for thromboembolism.
- Transesophageal echocardiography is projected to be a cost-effective test for guiding decisions about the choice of antithrombolytic treatment in patients with risk factors for thromboembolism.

## Future Research

The results of the decision analysis point out the need for additional research, including:

- Determination of the quality-of-life effects of alternative treatment strategies for AF.
- Investigation of the safety and cost of initiating antiarrhythmic therapy in the outpatient setting.
- Randomized clinical trials of warfarin, aspirin, and other agents (e.g., ticlopidine, clopidogrel) in patient subgroups where the most uncertainty exists, such as low and intermediate risk of ischemic stroke and high risk of major bleeds.
- Randomized clinical trials evaluating the effects on outcomes of using transthoracic and transesophageal echocardiography to help guide decisions about the choice of antithrombotic treatment.