# Future Research

## Conversion and Maintenance of Sinus Rhythm

It is important to identify gaps in the evidence from this review. First, a substantial number of relevant antiarrhythmic comparisons have not been done. In particular, no clinical trials have compared flecainide with ibutilide/dofetilide for acute conversion of AF. These two agents have the strongest evidence of efficacy for acute conversion, and a direct comparison would be beneficial to clinicians.

Second, with respect to both acute conversion and maintenance of sinus rhythm, evidence regarding amiodarone is scarce and problematic. Additional trials evaluating amiodarone for both acute conversion and maintenance of sinus rhythm would allow definitive classification of amiodarone efficacy.

Third, given safety concerns, particularly of Class I agents, future trials-with better characterization of subjects in terms of coronary artery disease and risk for ventricular arrhythmias for each of the pharmacological antiarrhythmic agents-would solidify the evidence for efficacy by allowing stratification for risk of adverse events.

Fourth, almost no data were found in this review regarding the interaction between use of the various antiarrhythmic agents and quality of life. Given the known existence of this interaction, future trials incorporating assessment of quality of life would complete the picture on efficacy by reaching into an assessment of overall effectiveness.

Finally, the followup times for all the clinical trials on maintenance of sinus rhythm were relatively short. Because the ability to remain free of recurrences likely affects a patient's quality of life, it would be beneficial to test the antiarrhythmic agents for a longer time for efficacy regarding maintenance of sinus rhythm. The results of the ongoing Atrial Fibrillation Follow-up Investigation of Rhythm Management (AFFIRM) should help address this issue (Planning and Steering Committees of the AFFIRM study, 1997; Hohnloser and Kuck, 1997).

## Rate Control

Future studies are needed that evaluate outcomes-including quality-of-life effects most important to patients, such as exercise tolerance and functional status-because, in essence, heart rate is only a surrogate for these outcomes. More studies are needed to evaluate the rate control effect of some of the newer medications, particularly those used for pharmacological conversion of atrial fibrillation such as amiodarone and propafenone. An ideal medication would be one that restores sinus rhythm and also effectively controls the ventricular rate in case of reversion to atrial fibrillation. Notably absent from our review of the literature are any randomized controlled trials that report the rate-controlling effect of amiodarone alone. Confirmatory studies are needed of the rate-controlling effect of sotalol, perhaps without concomitant digoxin. Similarly, trials of oral propafenone would be useful because it is likely to be effective for conversion and rate control, and only one trial has been done for this medication taken orally for rate control.

## Anticoagulants and Antiplatelet Agents

Additional studies of warfarin versus aspirin in moderate-risk and low-risk populations are needed. The only completed study of the combination of aspirin with low-dose warfarin was done in a high-risk population. The study in a lower risk group was terminated early, so the question of the efficacy in a lower risk population is uncertain, and it may warrant reevaluation.

Comparisons of low molecular weight heparin with warfarin and low molecular weight heparin with aspirin are needed, in addition to larger studies comparing heparin with placebo.

A study of indobufen versus warfarin for primary stroke prevention also may be warranted, because the only published trial is for secondary prevention.

Studies are needed that evaluate other antithrombotic agents such as ticlopidine and clopidogrel, particularly for those patient groups unable to take warfarin.