# Conclusions

## Summary of Findings

### Pharmacological Conversion of AF

#### Strong Evidence of Efficacy (Compared With Control Treatment)

The antiarrhythmic agents with the strongest evidence of efficacy for conversion of AF were flecainide (OR 24.7, CI 9.0 to 68) and ibutilide/dofetilide (OR 29.1, CI 9.8 to 86). Strong evidence of efficacy also existed for propafenone (OR 4.6, CI 2.6 to 8.2).

#### Moderate Evidence of Efficacy (Compared With Control Treatment)

There was moderate evidence of efficacy for quinidine compared with control treatment (OR 2.9, CI 1.2 to 7.0), for conversion of AF.

#### Suggestive Evidence of Efficacy (Compared With Control Treatment)

Disopyramide (OR 7.0, CI 0.3 to 152) and amiodarone (OR 5.7, CI 1.0 to 33.4) had suggestive evidence of benefit for acute conversion of AF relative to control treatment.

#### Suggestive Evidence of Negative Efficacy (Compared With Control Treatment)

The evidence was suggestive of negative efficacy of sotalol (OR 0.4, CI 0.0 to 3.0) for acute conversion of AF.

#### Minimal Evidence

Minimal evidence existed for agents in Class II, IV, and V and in the miscellaneous category.

### Pharmacological Maintenance of Sinus Rhythm

#### Strong Evidence of Efficacy (Compared With Control Treatment)

All of the following antiarrhythmic agents had strong evidence of efficacy for maintenance of sinus rhythm after cardioversion of AF: quinidine (OR 4.1, CI 2.5 to 6.7), disopyramide (OR 3.4, CI 1.6 to 7.1), flecainide (OR 3.1, CI 1.5 to 6.2), propafenone (OR 3.7, CI 2.4 to 5.7), and sotalol (OR 7.1, CI 3.8 to 13.4). Our review did not support any definitive ranking of these five agents for efficacy of maintaining sinus rhythm.

#### Potentially Strong Evidence of Efficacy (Compared With Control Treatment)

We identified no trials of amiodarone compared with control treatment for maintenance of sinus rhythm, but one trial had moderate evidence of amiodarone efficacy relative to disopyramide.

#### Minimal Evidence

Minimal evidence existed for N-acetylprocainamide and agents in Class IV and the miscellaneous category.

### Rate Control

Overall, 45 trials were identified that evaluated 17 agents. The design and outcomes of these trials were too disparate for meta-analysis.

- Compared with placebo or digoxin, the calcium-channel-blockers diltiazem and verapamil were more efficacious in reducing the heart rate at rest and during exercise in patients with AF.
- Compared with placebo or digoxin, beta-blockers were more efficacious in reducing the heart rate at rest and during exercise in patients with AF. However, exercise tolerance was decreased on beta-blockers in a number of the studies. The effect of beta-blockers on resting heart rate was inconsistent, with only about half of the studies demonstrating better control with beta-blockers than placebo.

The evidence was inconclusive regarding the efficacy of digoxin, particularly during exercise.

### Antithrombotic Therapy for Stroke Prevention

There was strong evidence of the efficacy of warfarin (OR 0.30, CI 0.19 to 0.48) compared with placebo. However, the evidence was suggestive for a higher bleeding rate on warfarin (OR 1.90, CI 0.89 to 4.04) than placebo. For every 1,000 patients with AF that are treated with warfarin for 1 year, 30 strokes are prevented at the expense of 6 major bleeds.

The evidence for efficacy in preventing stroke was suggestive for aspirin (OR 0.65; CI 0.43 to 0.99) compared with placebo. The evidence for an increased odds of major bleeding associated with aspirin (OR 0.81, CI 0.37 to 1.77) compared to placebo was inconclusive. For every 1,000 patients with AF that are treated with aspirin for 1 year, 12.5 strokes are prevented.

The evidence from trials directly comparing warfarin and aspirin did not permit strong conclusions.

The evidence does not support the use of a combination of low-dose warfarin with aspirin or the use of low molecular weight heparin or induprofen for stroke prevention, but the data are limited.

### Echocardiography

From our comprehensive literature search of clinical trials, no completed trials were identified that directly addressed the clinical utility of echocardiography in the management of AF.

Of the 46 studies of acute cardioversion identified in our comprehensive search of clinical trials, only 9 gave information relating left-atrial diameter from echocardiography to success of cardioversion. Although the results were not consistent, they suggested an inverse association between left-atrial diameter and successful cardioversion.

### Outpatient Initiation of Antiarrhythmic Therapy

Our comprehensive literature search did not identify any randomized controlled clinical trials that addressed this question directly.

Note: Additional conclusions based on the decision analysis are presented in Chapter 8, Decision Analysis, under Conclusions.

## Intended Uses of the Evidence Report

The evidence report synthesizes the evidence that should guide clinical decisionmaking in patients with non-postoperative AF. Several strategies will be employed to make this information available to clinicians and their patients. The entire evidence report will be disseminated by AHRQ's Publications Clearinghouse and its Web site. In addition, condensed versions of each major component of the report will be submitted for publication in peer-reviewed journals that are widely read by the types of clinicians most likely to be involved in the management of patients with AF. Efforts also will be made to present the key findings of the evidence report at national meetings of major professional organizations such as the American Academy of Family Physicians, the Society of General Internal Medicine, the American College of Cardiology, and the American Heart Association. These efforts to disseminate the evidence directly to clinicians will be complemented by efforts to translate the contents of the evidence report into practice guidelines by leading professional organizations that have well-developed mechanisms for producing practice guidelines relevant to their members. We also will seek to translate the contents of the evidence report into innovative computerized information and decision support systems being developed by organizations such as the American College of Physicians and the Johns Hopkins University.