# Methodology

In September 1997, the Federal Agency for Health Care Policy and Research (AHCPR) awarded a contract to the Johns Hopkins University Evidence-based Practice Center (EPC) to prepare an evidence report on the management of new onset atrial fibrillation (AF). The task was to formulate a report that incorporated the best available evidence on this topic. This project consisted of recruiting a group of experts, identifying a target patient population, identifying relevant questions, performing a comprehensive literature search, constructing evidence tables, performing meta-analyses, performing decision analyses, and submitting the report for extensive peer review.

## Recruitment of Experts

We identified a core group of five clinically and/or methodologically oriented technical experts who provided extensive input throughout the project. This group included representatives from the American Academy of Family Physicians (AAFP) and a clinical expert identified through the American College of Cardiology (ACC). The core group of technical experts included the following:

- Hanan S. Bell, Ph.D., a health scientist with extensive experience in the development of practice guidelines for family physicians.
- Ronald D. Berger, M.D., Ph.D., Assistant Professor of Medicine in the Division of Cardiology at the Johns Hopkins University, a cardiologist with special training and expertise in cardiovascular electrophysiology.
- Gary Gerstenblith, M.D., Professor of Medicine in the Division of Cardiology at the Johns Hopkins University, a cardiologist with extensive clinical and research experience in the management of cardiovascular disease in the elderly.
- David E. Haines, M.D., Professor of Internal Medicine in the Division of Cardiology at the University of Virginia, a cardiologist identified through the ACC with a primary research focus on AF.
- Michael L. LeFevre, M.D., Professor at the University of Missouri, a family physician representing the AAFP.

Other technical experts helped identify the relevant questions and served as peer reviewers of the evidence report. These technical experts included physicians; nurses; and representatives of professional organizations, Government agencies, health plans, and industry (Appendix A). Of note, we had representatives of a range of professional societies, including the AAFP, the American College of Physicians (ACP), the American Geriatrics Association (AGA), the ACC, the American Heart Association (AHA), and the North American Society of Pacing and Electrophysiology (NASPE). We also had representatives of selected government agencies, including the Food and Drug Administration (FDA) and the Health Care Financing Administration (HCFA), and representatives of health plans, including Blue Cross/Blue Shield of Maryland and Mid-Atlantic Medical Systems, Inc. (MAMSI).

Two representatives of the American College of Physicians (Jerome A. Osheroff, M.D., and David R. Goldmann, M.D.) have been included on our panel of technical experts because of their interest in exploring the feasibility of incorporating relevant portions of our evidence report into an Internet-based model for providing primary care practitioners with point-of-care access to up-to-date recommendations on how to manage commonly encountered clinical problems. This will give our EPC an exciting opportunity to participate in the development of an innovative way to disseminate the results of our evidence reports.

We decided to broaden the perspective of our panel of technical experts by including nurses who have extensive experience in the management of cardiovascular disease and cardiac arrhythmias. We expect that our nurse experts will help to ensure that all potentially relevant patient concerns are taken into consideration.

This evidence report is targeted toward clinicians involved in the management of AF, including physicians and nurses. Several of the experts indicated that they thought their organizations could use our evidence report to develop new or revised practice guidelines on the management of AF. Other potential uses of the evidence report that were endorsed by our technical experts were to develop a disease management program on AF, to prepare educational materials for physicians, to prepare educational materials for patients, and to guide utilization management plans.

## Patient Population

Based on input from our technical experts, we decided to focus primarily on the patient population of greatest importance to primary care practitioners. This target population consisted of ambulatory adult patients with new onset AF, defined as those who present with persistent or paroxysmal AF for the first time, regardless of whether the duration of the arrhythmia was known or unknown at the time of presentation. Pediatric patients were not included in this review because AF is rare in children. Patients who develop AF intra- or postoperatively also were not included because the management issues are substantially different. Patients with atrial flutter were included in many of the trials on management of AF, but the data were inadequate to support separate conclusions about management of atrial flutter.

## Identifying the Specific Questions

The study team prepared a brief questionnaire for identifying the most relevant specific questions regarding the management of AF. After a pilot test with the group of core experts, the final version was developed (Appendix B). Through this questionnaire, we asked the experts to independently rate the importance of a number of questions that arise in the management of AF. We sent the finalized questionnaire to our wider group of experts and representatives. From this questionnaire and discussion with the core experts, we identified the following questions, which were addressed in the evidence report:

### Key Questions

1 Which patients with new onset AF should receive attempts at cardioversion and which should receive only conservative treatment with rate control and thromboembolism prophylaxis?
2 What is the efficacy of electrical cardioversion alone compared with antiarrhythmic therapy alone compared with both together for patients with new onset AF?
3 What are the risks and benefits of each of the antiarrhythmic agents used for conversion of AF and/or the maintenance of sinus rhythm after successful cardioversion?
4 What types of therapy for AF can safely be performed in an outpatient rather than an inpatient setting?
5 What is the diagnostic value of tests, such as transesophageal echocardiography and transthoracic echocardiography, that can be used in the evaluation of patients with new onset AF?

#### Supplementary Questions

1 How does anticoagulation compare with aspirin in preventing thromboembolism in patients with AF?
2 How do each of the pharmacological agents used for rate control compare in efficacy?

#### Secondary Questions

1 What are the indications for use of invasive therapy such as the surgical Maze procedure or atrial pacing with a permanent pacemaker?
2 What are the indications for use of emerging therapy such as an implantable atrial defibrillator, catheter-based Maze procedure, or ablation of focal AF?
3 What are the performance characteristics of emerging diagnostic tests that could be used in the evaluation of patients with AF?

The evidence report focused primarily on the key questions and the supplementary questions. Although some of our technical experts commented that recent studies have demonstrated the superiority of anticoagulation over aspirin for such patients, we decided to include this as a supplementary question because it remains a fundamentally important consideration in the overall management of AF, and we needed to have an estimate of the magnitude of the benefit of anticoagulation relative to aspirin or no treatment. The efficacy of the various pharmacological agents used for rate control also was included for similar reasons.

In addition, we identified literature that is pertinent to the secondary questions, but we did not have enough resources to perform a formal review and synthesis of this literature. The secondary questions about invasive or emerging therapies apply more to patients' refractory to traditional management strategies than to our targeted patient population.

Based on the input from the technical experts, we decided that some of the questions to be addressed in the evidence report required a meta-analysis, and some required a decision analysis and/or cost-effectiveness analysis, in addition to the initial literature review and synthesis.

### Causal Pathway

Having defined the questions that would be addressed in the evidence report, we proceeded with developing a model of the causal pathway of AF. The final causal pathway based upon input from the study team and core experts is given in Appendix C. As indicated in the model, several types of intervention (noted in the ellipses) can alter the underlying pathophysiologic process, and specific diagnostic tests (noted in the circles) have a role in assessing the risk of adverse outcomes (noted in rectangles). Also, a number of patient characteristics can influence the pathophysiologic process. This model of the causal pathway is used to illustrate the clinical and scientific importance of the questions addressed in the evidence report.

## Literature Search Methods

### Sources

Several literature sources were used to ensure a comprehensive search that would identify all studies potentially relevant to the study questions. The primary source was the CENTRAL database produced by the Cochrane Collaboration's extensive and worldwide efforts to identify controlled clinical trials. CENTRAL is designed to contain studies that may be relevant for inclusion in systematic reviews. Cochrane Collaborators submit for inclusion in CENTRAL the results from searches of electronic databases such as MEDLINE and EMBASE, as well as the results of hand searches of more than 1,000 biomedical journals. The CENTRAL database was accessed via The Cochrane Library, which is issued quarterly. The Cochrane Library 1998 Issue 1 and Issue 2 were searched. A database of search results was developed using the bibliographic software package ProCite.

MEDLINE was used as the second source to ensure comprehensiveness, especially for more recent publication years. The search of MEDLINE took two forms. First, MEDLINE as provided by third-party vendor OVID was searched from 1966 to 1998 using the search strategy outlined in Appendix D, limiting retrieval to those citations tagged as "randomized controlled trial" or "controlled clinical trial." The duplicate check within ProCite was then used to flag any newly identified trials to add to the database created from CENTRAL. MEDLINE was also accessed via PubMed, a system that allows direct access to the MEDLINE database and thus access to those citations most recently added to MEDLINE. MEDLINE, via PubMed, was searched using Phase 1 of the Cochrane optimal search strategy (Appendix E) combined with the search strategy outlined in Appendix D. Citations not tagged as "randomized controlled trial" or "controlled clinical trial" were reviewed by a trained searcher to determine whether they were controlled trials. The ProCite duplicate check was then used for all citations to identify any citations not already included in the search results database. This direct search of MEDLINE via PubMed was completed on a bimonthly basis until June 1, 1998, with each search limited to citations published between 1995 and 1998.

The third source used to ensure completeness of the literature identification process was the PubMed feature of "related articles." A new feature of several Web-based databases, such as OVID and PubMed, is the provision of hyperlinks to related articles for each citation retrieved in a search. The related articles are identified by a non-MeSH-based (MeSH stands for Medical Subject Headings), nonhierarchical search engine that uses a precomputed metric based on textual analysis of titles, abstracts, and MeSH terms. From the search of CENTRAL, primary articles were selected to use in the "related articles" feature to determine whether there were any related and relevant citations that had not already been identified.

A fourth source was a review of recent hand-search results submitted to the Baltimore Cochrane Center. Full copies of the articles submitted by the Cardiovascular Randomized Controlled Trial (CVRCT) Registry were reviewed by a trained hand searcher for relevant citations. The duplicate check of the database in ProCite was then used to identify any newly identified citations.

Other measures were taken to ensure that all relevant studies were identified. The reference lists contained in relevant meta-analyses, recent review articles, and recent major clinical trials were scanned to identify any studies missed by the searches of CENTRAL and MEDLINE. In addition, to identify any new studies published, the core study team scanned the table of contents from those journals most frequently cited in the search results database. The REVEAL (part of UNCOVER) service from the Johns Hopkins University's Welch Library, which delivers tables of contents within 2 or 3 days of the journal publication, was used for this process. The tables of contents from the journals identified from the search results database (see Appendix D) were sent via E-mail to the members of the core study group for review. Any citations identified in this manner were added to the search results database, and the abstracts were reviewed for eligibility.

### Search Terms and Strategies

All strategies were designed to maximize sensitivity and were developed in consultation with the members of the core study team. First, an overall search strategy was designed to identify all trials on the management of atrial fibrillation. For this strategy, it was decided to limit retrieval to randomized controlled trials in order to focus on the studies that used the strongest study design.

The overall strategy was modified for use with the different sources. The search strategy used to identify articles in the CENTRAL database is included in Appendix D. To identify articles in MEDLINE, Phase 1 of the Cochrane optimal search strategy (Appendix E) was combined with the topic-specific search strategy (Appendix D).

For the key questions concerning outpatient strategies (key question 4) and different diagnostic strategies (key question 5), the overall search strategy described above retrieved very few citations. It was decided for these questions to conduct additional searches not limiting retrieval to randomized controlled trials. Additional searches were completed for key question 4 about outpatient strategies (Appendix F) and key question 5 about the diagnostic value of tests that can be used in the evaluation of patients with atrial fibrillation (Appendix G).

### Abstract Review

All search results were downloaded or hand entered into a database of trials that were considered potentially eligible for inclusion in the literature review. Weekly, or as needed, the abstracts of any newly identified citations were distributed among the core study team for review to determine eligibility. All citations not meeting eligibility criteria were coded with the reason for exclusion. The database, developed in ProCite, was used for tracking search results, the abstract review process, and printing reports regarding identification of relevant literature.

In the review of abstracts, the emphasis was placed on identifying all citations that may have relevant data. The following criteria were used to exclude articles from further consideration:

a) Article does not address management of atrial fibrillation or atrial flutter.

b) Article does not include human data.

c) Study only addressed postoperative atrial fibrillation.

d) Adults are not part of the study population.

e) No original data.

The abstract review form (Appendix H) was pilot tested by three members of the core study team (Eric B. Bass, M.D., M.P.H., Robert L. McNamara, M.D., M.H.S., and David Yu, M.D.) using 30 of the abstracts. As part of the pilot testing, any disagreements were discussed, consensus was reached, and modifications were made to the abstract review form. The remaining citations were then distributed among four reviewers, including two faculty clinician-investigators (Drs. McNamara and Bass) and two clinical trainees with methodologic expertise (Marlene R. Miller, M.D., and Dr. Yu). Each citation was re¡viewed independently by two reviewers, including at least one faculty member. Any disagreements were resolved by consensus of the two reviewers.

In addition to the exclusion criteria, reviewers of the abstracts identified citations that were not written in English so potentially valuable studies reported in other languages would not be overlooked. The reviewers of the abstracts also identified citations that were not controlled trials and checked the questions the abstract addressed.

## Article Review

### Framing the Questions

Based on a preliminary review of the literature, we anticipated which questions regarding antiarrhythmic and antithrombotic therapy in atrial fibrillation could potentially have sufficient evidence to be evaluated with meta-analytic techniques. The main outcomes identified were acute pharmacological conversion, pharmacological maintenance of sinus rhythm, pharmacological heart rate control, and reduction in the rates of stroke associated with antithrombotic therapy. The resultant questions for the article review were narrowly focused.

Regarding antiarrhythmic management, the questions were as follows:

1 What is the magnitude of the difference in proportion of subjects with non-postoperative atrial fibrillation who acutely convert to sinus rhythm with each of the different antiarrhythmic agents?
2 What is the magnitude of the difference in proportion of subjects with non-postoperative atrial fibrillation who are maintained in sinus rhythm with each of the different antiarrhythmic agents?
3 What is the magnitude of the difference in proportion of subjects with non-postoperative persistent atrial fibrillation who achieve adequate heart rate control with each of the different antiarrhythmic agents?

Regarding antithrombotic management, the questions were as follows:

1 What is the magnitude of the reduction in risk of stroke for subjects with non-postoperative atrial fibrillation treated with warfarin compared with aspirin, placebo, or other treatment regimens?
2 What is the magnitude of the increase in risk of major bleeding for subjects with non-postoperative atrial fibrillation treated with warfarin compared with aspirin, placebo, or other treatment regimens?

### Selection of Articles

We chose to include in this systematic review only randomized clinical trials. The target population, as discussed in the introduction, was non-postoperative AF. This definition includes persistent AF and paroxysmal AF. Because AF often occurs in association with atrial flutter, we realized that the identified articles might include subjects with persistent or paroxysmal atrial flutter as well. We planned to extract data separately for atrial fibrillation and for atrial flutter in order to address as pure a population of non-postoperative atrial fibrillation as possible. We did not restrict the inclusion of articles based on the duration of treatment, the specific pharmacological intervention, or the study setting. Furthermore, studies were not excluded based on concomitant therapies given to the subjects. Other eligibility criteria to be met for consideration of inclusion in this review were the use of adult, human subjects and presentation of original data. Any inclusion of subjects with postoperative AF resulted in exclusion of the article unless data on non-postoperative subjects could be separately extracted.

### Abstraction of Qualitative and Quantitative Data

A form was developed to allow consistent data abstraction from the articles (Appendices I and J). This form included separate sections for the qualitative and quantitative data. The cover sheet of this instrument included seven eligibility criteria. Five of the criteria were those used in the abstract review process, and the two additional items were (1) lack of randomization and (2) inability to separate subjects with AF from those with other arrhythmias. These items were reevaluated at this step in the process to exclude articles that had appeared potentially appropriate for inclusion based on abstract review but that were not when the complete article was reviewed.

To create the qualitative section, we reviewed quality assessment forms used in other meta-analytic studies performed by the principal investigators of this Evidence-based Practice Center. In addition, we reviewed the literature, enlisted the assistance of the Cochrane Collaboration, and had consensus discussions among our study team. The resultant form incorporated the 6 key questions used by the Cochrane Collaboration and 14 key questions identified by Detsky, Naylor, O'Rourke et al. (1992). This quality assessment form was pilot tested for clarity and reproducibility by pairs of reviewers using the form with several articles. Discrepancies in interpretation of the questions were noted and then discussed among all the investigators, and revisions were made as needed. The final quality assessment form contained 22 questions, which were grouped as follows: (1) representativeness of the study population-how completely the authors described the study subjects, (2) bias and confounding-which includes a requirement for description of randomization and degree of masking, (3) description of therapy-which includes the description of the protocol and other therapies received, (4) outcomes and followup-which includes explicit description of the outcomes and the subjects withdrawing, and (5) statistical quality and interpretation. Each question could earn a point value from 0 to 2. The score is the percentage of the total points available in each category. The overall quality score for each study is the average of its five categorical scores.

The quantitative data form resulted from discussions among our study team. For pilot testing, each pair of reviewers reviewed two articles independently. Questions were added to the form as needed, mostly because of the different ways in which outcomes were reported. Additional items were added for completeness, and instructions were circulated regarding interpretation of the questions. These were developed by consensus for the purpose of consistency. The elements collected on this form included the subject inclusion and exclusion criteria as well as baseline subject characteristics that could influence outcomes, including age; baseline left atrial size; duration of atrial fibrillation or flutter; percentage of subjects with atrial flutter; and comorbid illnesses, including hypertension, previous myocardial infarction, previous stroke, and any other reported comorbidities. We also abstracted from each article the therapeutic protocols; the goal time of followup; and data regarding the main outcomes and secondary outcomes, including adverse events necessitating cessation of the study drug or reduction of the dosage.

A pair of independent reviewers performed the qualitative and quantitative assessment of each article. All reviewers had both clinical and methodologic experience, and most had graduate education in epidemiology and biostatistics. The main reviewers were Drs. Robert McNamara and Eric Bass, the lead investigators on the project; Dr. Marlene Miller, a pediatric cardiology fellow with graduate training in epidemiology; and Dr. Jodi Segal, a general internal medicine fellow with a master's degree in public health. Additional reviewers were Dr. Steven Goodman, a physician experienced in meta-analysis with a doctorate in biostatistics; Dr. Sean Tunis, a clinician with graduate training in epidemiology; Dr. Robert McCarthy, a cardiology fellow; Dr. David Yu, an internal medicine resident with epidemiology experience; and Paul Abboud, a senior medical student experienced in meta-analysis.

The two reviewers assessed the methodological quality of each study. Disagreements were resolved by consensus, and a quality score was assigned for each question. For the quantitative data, one of the reviewers was assigned primary responsibility for extracting the data for each article. The second reviewer was responsible for checking the accuracy of the first reviewer's data extraction. Again, differences were resolved by consensus. The discussion of the articles was done in batches of approximately 10 articles, so that early comparison of the reviewers' assessments could help to calibrate the reviewers. The reviewers were not masked as to the author, institution, and journal, because it seemed unlikely to make a significant difference in the results (Justice, Cho, Winker, et al., 1998) and because this allowed the process to proceed more expeditiously.

Data from trials that were inappropriate for the meta-analysis were abstracted for other use, including for presentation in evidence tables and for use in the decision and cost-effectiveness analyses. Trials excluded from review altogether were noted with the reasons for exclusion.

All qualitative and quantitative data abstracted were entered into a computer database. This database was subsequently used for construction of evidence tables, and as the source of the data for mathematical pooling.

### Obtaining Additional Data From Investigators

Because of resource limitations, we did not seek to obtain additional data or raw data from investigators.

### Assessing Publication Bias

In order to assess the existence of important publication bias, we made several inquiries. First, investigators in the field and search coordinators of relevant Cochrane Collaborative Review Groups were asked to identify any trials that have been completed but not published. This did not yield any additional data for evaluation. Second, the final programs of the 1997-98 meetings of the ACC and the AHA were reviewed to search for abstracts suggesting unpublished data. This review did not yield any significant additional data for evaluation.

### Evidence Tables

Evidence tables were constructed to present the data retrieved for each key question (Evidence Tables 1-9). Separate tables were created for the evidence on pharmacological conversion, maintenance of sinus rhythm, heart rate control, and the outcomes from antithrombotic therapy. Based on recommendations from the expert review panel, two summary tables were constructed for each of these four main outcome areas, one a study design table and the other a results table. The design tables include information on the source of the article, treatment groups and sample size, additional treatments allowed during the trial but not assigned, goal followup time, inclusion/exclusion criteria, and study quality. The results tables include information on baseline subject characteristics, main outcomes, adverse events, and comments that help in interpretation of the outcomes.

The article abstraction forms were used to create a database. The evidence tables were populated directly from the database. Subsequently, the accuracy of the evidence tables was confirmed by comparison with the original articles. To display the data in a useful form for readers, we generated scatter-plots of the absolute rates of conversion, maintenance of sinus rhythm, rate control, and outcomes with antithrombotic therapy. These figures display the actual rates of each major outcome for each trial by therapy and allow the reader to quickly appreciate the relative efficacy of each therapy (Figures 1 - 11 , 23 - 30 , 39 - 44 , 46 - 58 ).

Figure 1. Proportion of subjects with successful pharmacological conversion

Notes: *Control treatment includes groups receiving placebo, verapamil, diltiazem, or digoxin **Vertical lines represent 95% confidence intervals for the proportion of subjects with successful pharmacological conversion + n equals the number of trials evaluating each comparison ++This point represents 2 distinct trials of propafenone vs. control treatment (confidence intervals for each trial: -0.57,0.18; 0.01,0.13) +++Confidence intervals for this trial are from 0.54 to 1.0 These three trials with x=0 were offset laterally to avoid the overlap

Figure 11. Proportion of subjects with successful pharmacological conversion conjunction with DC cardioversion

Notes: *Control treatment includes groups receiving placebo, verapamil, diltiazem, or digoxin ** Vertical lines represent 95% confidence intervals for the proportion of subjects with successful pharmacological conversion conjuncion with DC cardioversion + n equals the number of trials evaluating each comparison

Figure 23. Proportion of subjects with successful maintenance of sinus rhythm

Notes: *Control treatment includes groups receiving placebo, verapamil, diltiazem, or digoxin **Vertical lines represent 95% confidence intervals for the proportion of subjects with successful maintenance of sinus rhythm + n equals the number of trials evaluating each comparison

Figure 30. Proportion of subjects with successful maintenance of sinus rhythm

Notes: *Control treatment includes groups receiving placebo, verapamil, diltiazem, or digoxin **Vertical lines represent 95% confidence intervals for the proportion of subjects with successful maintenance of sinus rhythm + n equals the number of trials evaluating each comparison ++ LA refers to "long acting"; SA refers to "short acting"

Figure 39. Rate control trials of calcium-channel-blockers versus placebo for subjects with atrial fibrillation

Figure 44. Rate control trials of digoxin versus digoxin combined with other drugs for subjects with atrial fibrillation

Figure 46. Rates of stroke

Figure 58. Rates of major hemorrhage

## Methods for Mathematical Pooling of Results

### Framing the Questions

The questions with results appropriate for pooling were defined after the literature was reviewed. Although we knew which questions we hoped to answer at the outset, we needed to focus the questions based on the available evidence.

The questions to be addressed with mathematical pooling were those that met the following criteria: (1) had evidence from randomized clinical trials, (2) had an adequate number of trials with qualitatively similar subjects, and (3) had an adequate number of trials that evaluated similar outcomes. The proportion of subjects attaining adequate heart rate control was reported too disparately to be combined easily. The data for this outcome were aggregated and presented in evidence table format only.

The specific questions to be addressed by the pooling of the data are as follows:

1 What is the magnitude of the difference in proportion of subjects with non-postoperative atrial fibrillation who acutely convert to sinus rhythm for each of the different antiarrythmic agents?
2 What is the magnitude of the difference in proportion of subjects with non-postoperative atrial fibrillation who are maintained in sinus rhythm for each of the different antiarrhythmic agents?
3 What is the magnitude of the reduction in risk of stroke for subjects with non-postoperative atrial fibrillation treated with warfarin compared to aspirin, placebo, or other treatment regimens?
4 What is the magnitude of the increase in risk of major bleeding for subjects with non-postoperative atrial fibrillation treated with warfarin compared to aspirin, placebo, or other treatment regimens?

### Abstraction of Qualitative and Quantitative Data

The data from the studies identified as appropriate for inclusion in the mathematical pooling were abstracted concurrently with abstraction of the data for the evidence tables. The same review process was done using the qualitative and quantitative data abstraction forms developed for abstracting data for construction of the evidence tables. Many of the data included in the evidence tables were abstracted with the goal of mathematical pooling, including the inclusion and exclusion criteria and the detailed description of the enrolled subjects.

### Choice of Effect Measure

The effect measures were chosen to have units most recognizable to the readers. Most of the pooled results are given in terms of odds ratios. For the studies of pharmacological conversion, the treatment effect was expressed as an odds ratio: the odds of converting to sinus rhythm on one drug compared to the odds of converting on the other drug tested. For maintenance of sinus rhythm by the various antiarrhythmic medications, the treatment effect also was expressed as an odds ratio: the odds of remaining in sinus rhythm on one treatment divided by the odds of remaining in sinus rhythm on the other treatment. Finally, for the trials of antithrombotic therapy, the effect of therapy on each outcome is expressed as an odds ratio. For example, the odds ratio for stroke is the odds of having a stroke while on one therapy compared with the odds of having a stroke while on another therapy. The above results are also presented as absolute rates to facilitate the comparison of the rates of different outcomes.

For our summary findings on conversion and maintenance of sinus rhythm, we report the important findings not only as odds ratios but also as the number of subjects needed to treat with one agent in order to see a benefit relative to the comparison group. Because this is a key section of our report, we wanted to present the results in various formats so they would be most usable.

Translating these odds ratios into the more clinically relevant concept of the number of subjects needed to be treated (NNT) in order to see a benefit of these agents relative to control treatment was problematic for two reasons. First, there was statistical imprecision of these odds ratio (OR) estimates, reflected in the 95 percent confidence intervals (CI). Second, there was imprecision in estimating the spontaneous conversion rates and recurrence rates in control treatment groups. The overall range of control treatment conversion rates was 0 to 76 percent, probably in part because of chance variation and in part because of differences in subject characteristics such as paroxysmal AF versus long-standing persistent AF. Nevertheless, in order to calculate an NNT we chose to assume a control treatment conversion rate of 30 percent, reflecting the mean control treatment conversion rate of all the included trials. For any particular antiarrhythmic agent, we calculated an NNT range using the upper and lower 95 percent CI estimates as opposed to the point estimate. For calculating NNT in regard to maintenance of sinus rhythm, we assumed a 30 percent recurrence rate of AF in control treatment. This assumption is supported by our evidence tables in studies with adequate followup time, defined as greater than or equal to 6 months.

### Judging Combinability

Because a qualitative assessment of combinability was needed before a quantitative assessment of heterogeneity could be done, we examined the evidence tables to assess combinability. We anticipated that different inclusion and exclusion criteria might preclude combination of some of the studies, and also that different dosing regimens or route of administration of the same drugs might preclude combination.

After review of the designs of the trials and discussion with our core clinical experts, we decided that the results from the trials using calcium-channel-blockers and digoxin as the comparison agents for antiarrhythmic drugs could be combined with trials that used placebo controls. Ibutilide and dofetilide were the only other pharmacological agents similar enough to allow for pooling.

After dividing the trials into groups that were clinically relevant to consider together and that appeared qualitatively homogeneous, we assessed the quantitative variability by looking at the within-group heterogeneity, described as a chi-square statistic with n-1 degrees of freedom, where n is the number of studies being combined. When significant heterogeneity was found, the pooled estimates were derived by a random-effects model.

### Mathematical Pooling

Estimates of the relative rates of the outcomes of interest were pooled using the usual methods for combining odds ratios for the outcomes of conversion to sinus rhythm, maintenance of sinus rhythm, stroke, peripheral embolism, major bleeding, minor bleeding, and mortality. Studies were weighted on the basis of study size and the precision of the estimate within each study. We used a fixed-effects model to summarize the evidence. In two instances-propafenone versus control treatment for conversion and amiodarone versus control treatment for conversion-we used a random-effects model because of the significant quantitative heterogeneity of the data. The software programs used for these calculations were RevMan 3.1 (statistical software from the Cochrane Collaboration) and STATA 5.0 (Stata Corp., College Station, TX).

### Subgroup Analysis

Because data on baseline characteristics of each subject and on the individual's outcome generally were not presented in the articles, we evaluated the impact of the baseline characteristics of the subjects collectively within each study on the aggregate study outcomes. For example, analysis regarding successful pharmacological conversion for subjects with mean left-atrial (LA) size less than or equal to 4.0 centimeters was accomplished by pooling all trials with an overall mean LA size of less than or equal to 4.0 centimeters for all study subjects. Although we realized that this would lessen our ability to detect treatment effects, we thought it was important to explore certain clinically relevant subgroups. For the outcomes of acute conversion and maintenance of sinus rhythm, we compared the study results based on the following subgroupings: choice of control treatment (placebo, verapamil, diltiazem, or digoxin), route of antiarrhythmic administration (intravenous or oral), duration of atrial fibrillation (less than or equal to 2 weeks or more than 2 weeks), mean left atrial size (less than or equal to 4.0 cm or more than 4.0 cm), and inclusion of subjects with atrial flutter (no subjects, some subjects, or all subjects). Specific to acute conversion, we also examined the impact of goal followup time (less than 24 hours or more than or equal to 24 hours). Comparably, with respect to maintenance of sinus rhythm, we also examined the impact of goal followup time (less than 6 months or more than or equal to 6 months). For the trials of antithrombotic therapies, we compared the outcomes of studies based on the target upper limit of the international normalized ratio (INR) (more than or equal to 4.0 or less than 4.0).

### Sensitivity Analysis

Because of the small number of studies for each comparison within the subgroupings, the influence of study quality and study size could not be evaluated formally.

## Presentation and Interpretation of the Results

The results are presented as "forest plots," showing odds ratios and 95 percent confidence interval bars for each study (Figures 12 - 22 , 31 - 38 , 45a - 45f , 59a - 59b ). Each figure incorporates a vertical line at an odds ratio of 1.0 in order to emphasize the point of equivalency between two treatments.

Figure 12. Meta-analysis on pharmacological conversion

Notes: Vertical bars are point estimates. Horizontal bars and numbers in brackets are 95% confidence intervals using fixed-effects model unless otherwise indicated. * Control treatment includes groups receiving placebo, verapamil, diltiazem, or digoxin **Confidence interval using random-effects mode Individual study data are available on request (Supplemental Figures, 1999)

Figure 22. Meta-analysis on pharmacological conversion

Notes: DCC refers to direct current cardioversion Vertical bars are point estimates. Horizontal bars and numbers in brackets are 95% confidence intervals using fixed-effects model unless otherwise indicated. *Control treatment includes groups receiving placebo, verapamil, diltiazem, or digoxin Individual study data available on request

Figure 31. Meta-analysis on maintenance of sinus rhythm

Notes: Vertical bars are point estimates. Horizontal bars and numbers in brackets are 95% confidence intervals using fixed-effects model unless otherwise indicated. *Control treatment includes groups receiving placebo, verapamil, diltiazem, or digoxin Individual study data available on request

Figure 38. Meta-analysis on maintenance of sinus rhythm

Notes: Vertical bars are point estimates. Horizontal bars and numbers in brackets are 95% confidence intervals using fixed-effects model unless otherwise indicated. Individual study data available on request

Figure 45a. Summary of meta-analysis results on the efficacy of warfarin versus placebo in patients with atrial fibrillation

Notes: Vertical bars are point estimates. Horizontal bars and numbers in brackets are 95% confidence intervals using fixed-effects model unless otherwise indicated. Individual study data available on request

Figure 45f. Summary of meta-analysis results on the efficacy of low molecular weight heparin (LMWH) versus placebo in patients with atrial fibrillation

Notes: Vertical bars are point estimates. Horizontal bars and numbers in brackets are 95% confidence intervals using fixed-effects model unless otherwise indicated. Individual study data available on request

Figure 59a. Summary of meta-analysis results on the efficacy of warfarin versus placebo in patients with atrial fibrillation

Notes: INR refers to International Normalized Ratio Vertical bars are point estimates. Horizontal bars and numbers in brackets are 95% confidence intervals using fixed-effects model unless otherwise indicated. Individual study data available on request

Figure 59b. Summary of meta-analysis results on the efficacy of warfarin versus placebo in patients with atrial fibrillation

Notes: INR refers to International Normalized Ratio Vertical bars are point estimates. Horizontal bars and numbers in brackets are 95% confidence intervals using fixed-effects model unless otherwise indicated. Individual study data available on request

Realizing that it is difficult to categorize the strength of evidence, we felt it was important to facilitate interpretation of the odds ratio. The concept of "strength of evidence" depends on the estimated magnitude of effect, the precision of that estimate, and our confidence that the true effect is different from zero. Quantitatively, all of these dimensions are captured by the point estimate and confidence interval, but it may be difficult to interpret results presented only in that fashion. Therefore, we provided descriptors of the strength of evidence. For the evidence on conversion and maintenance of sinus rhythm, an OR greater than 1.0 represents a higher odds of conversion or maintenance of sinus rhythm compared with the comparison group. For the evidence on anticoagulation and antiplatelet agents, an OR less than 1.0 represents a lower odds of adverse events such as stroke and bleeding compared with the comparison group. We chose the following categorization of strength of evidence by noting the placement of the point estimate and the width of the CI surrounding it:

### Conversion and Maintenance of Sinus Rhythm

- Strong evidence of efficacy: OR > 1.0, 99 percent CI does not include 1.0 (p < 0.01).
- Moderate evidence of efficacy: OR > 1.0, 95 percent CI does not include 1.0, but 99 percent CI includes 1.0 (0.01< p < 0.05).
- Suggestive evidence of efficacy: 95 percent CI includes 1.0 in the lower tail (0.05 < p < 0.2 to 0.3) and the OR is in a clinically meaningful range.
- Inconclusive evidence of efficacy: 95 percent CI widely distributed around 1.0.
- Strong evidence of lack of efficacy: OR near 1.0, 95 percent CI is narrow.

When the point estimate was less than 1.0, we termed this negative efficacy and used the same categorization of strong, moderate, and suggestive evidence based on the CI.

### Anticoagulation and Antiplatelet Agents

- Strong evidence of efficacy: OR < 1.0, 99 percent CI does not include 1.0 (p < 0.01).
- Moderate evidence of efficacy: OR < 1.0, 95 percent CI does not include 1.0, but 99 percent CI includes 1.0 (0.01 < p < 0.05).
- Suggestive evidence of efficacy: 95 percent CI includes 1.0 in the upper tail (0.05 < p < 0.2 to 0.3) and the OR is in a clinically meaningful range.
- Inconclusive evidence of efficacy: 95 percent CI is widely distributed around 1.0.
- Strong evidence of lack of efficacy: 95 percent CI symmetrically and narrowly distributed around 1.0.

When the point estimate was greater than 1.0, we termed this negative efficacy and used the same categorization of strong, moderate, and suggestive evidence based on the CI.

In some situations, these categorizations did not completely capture some element of the result that was important for interpretation, particularly in cases with large point estimates and/or very wide confidence intervals. In those instances, we added additional descriptive text.

The strength of the evidence is described in the text accompanying the results of the pooled analyses for acute conversion, maintenance of sinus rhythm, and anticoagulant and antiplatelet agents.

## Plan for Updating

The literature search strategies used for these meta-analyses were carefully documented, including medical subject headings and keywords. The data abstraction forms had multiple pilot testings and will be stored for future use in updating this report. A computer database of the abstraction results was created, enabling additional data entry as studies are identified. In addition, as discussed, we have registered the meta-analyses with the Cochrane Collaboration to give researchers in the future access to this work. All meta-analyses were performed with the RevMan software to facilitate submission and dissemination of the pooled-analysis through the Cochrane Collaboration database.