# Introduction

Atrial fibrillation (AF) is the most common arrhythmia physicians face in clinical practice. The prevalence of AF, estimated to be 0.4 percent of the general population (Ostrander, Brandt, Kjelsberg et al., 1965), increases with age. The Framingham Heart Study found a prevalence of 0.5 percent in those aged 50 to 59 years and 8.8 percent in those 80 to 89 years (Wolf, Abbott, and Kannel, 1991). In Britain, the prevalence of AF was 0.4 percent for men 40 to 69 years old in the Whitehall Study and 0.7 percent for men 40 to 59 years old in the Regional Heart Study (Flegel, Shipley, and Rose, 1987). The prevalence of AF in the Cardiovascular Health Study, which enrolled participants aged over 65 years, was 3 to 5 percent (Furberg, Psaty, Manolio et al., 1994). Although the overall prevalence is higher in women than in men, the age-adjusted prevalence is higher in men (Kannel, Abbott, Savage et al., 1983). In the hospital setting, a series found AF to be the most common arrhythmia, accounting for 34.5 percent of the patients admitted with an arrhythmia (Bialy, Lehmann, Schumacher et al., 1992).

In the Manitoba Followup Study of male air crew recruits, the incidence of AF increased from less than 0.5 per thousand in those under age 50 years to 9.7 per thousand in those over 70 years old (Krahn, Manfreda, Tate et al., 1995). In the Framingham Study (Wolf, Abbott, and Kannel, 1987), the overall 2-year incidence detected by electro¡cardiography was 5.9 per thousand in men and 3.8 per thousand in women. For men, the incidence tripled with each decade, from 0.4 per thousand per 2-year interval for men 30 to 39 years old to 45.9 per thousand per 2-year interval in men 80 to 89 years old. For women, the incidence doubled with each decade, from 0.0 per thousand per 2-year interval to 35.8 per thousand per 2-year interval. As an indicator of the future impact of AF, the age-adjusted incidence has increased over the 30-year period of the Framingham Study (Prystowsky, Benson, Fuster et al., 1996).

## Etiology and Classification

Many different etiologies have been implicated in the development of AF. Self-limited AF is frequent following cardiac surgery and infrequent following myocardial infarction. Noncardiac etiologies, often reversible, include hyperthyroidism, hypoxic pulmonary conditions, surgery, and alcohol intoxication. The chronic cardiac conditions most commonly associated with the development of AF are rheumatic mitral valve disease, coronary artery disease, congestive heart failure, and hypertension (Kannel, Abbott, Savage et al., 1983; Krahn, Manfreda, Tate et al., 1995). In the Manitoba Followup Study, 53 percent of those who developed AF had hypertension, 36 percent had ischemic heart disease, 15 percent had congestive heart failure, and 8 percent had valvular disease. In this study, the age-adjusted relative risks (with 95 percent confidence intervals) for the development of AF were 9.9 (7.0 to 14.0) for congestive heart failure, 6.9 (4.5 to 10.7) for valvular heart disease, 3.5 (2.7 to 4.4) for ischemic heart disease, and 2.3 (1.8 to 2.9) for hypertension. All four conditions remained statistically significant in multivariate analysis. In the Framingham Study, echocardiographic associations with AF included left-atrial enlargement and increased left-ventricular thickness (Vaziri, Larson, Benjamin et al., 1993). When no predisposing condition exists, AF is called "lone AF." The reported frequency of lone AF is less than 10 percent of all cases of AF (Brand, Abbott, Kanne et al., 1985; Kopecky, Gersh, McGoon et al., 1987; and Furberg, Psaty, Manolio et al., 1994). However, the frequency observed in a typical office-based setting may be higher (Prystowsky, Benson, Fuster et al., 1996).

The classification of AF remains problematic. Many terms are used inconsistently in the literature. In general, the terms are used to describe temporal patterns. Acute AF often refers to onset within 48 hours (Sopher and Camm, 1996). Paroxysmal AF signifies that the fibrillation has terminated spontaneously on at least one occasion. Persistent AF usually refers to fibrillation with duration greater than 48 hours that has not terminated spontaneously. Permanent AF has been used to describe fibrillation that is resistant to pharmacological or electrical cardioversion. First-onset AF is often distinguished from chronic AF, which can refer to persistent, permanent, or paroxysmal AF (Waktare and Camm, 1998). This evidence report is aimed toward addressing the patient who presents to a clinician for the first time with AF, whether it is persistent or paroxysmal.

## Manifestations

The manifestations of AF may be divided into two categories-hemodynamic compromise and thromboembolic complications. Symptoms of hemodynamic compromise range from the classic complaint of irregular palpitations to the more insidious feeling of malaise. In one series of 28 patients awaiting elective cardioversion, exertional dyspnea was seen in 54 percent, while no or minimal symptoms were seen in 21 percent (Waktare and Camm, 1998). Other symptoms included exertional weakness/tired legs (29 percent), somnolence/tiredness (21 percent), rest dyspnea (18 percent), weakness (18 percent), general ill health (18 percent), bloating/fluid retention (18 percent), dizziness/light-headedness (14 percent), mental symptoms such as poor concentration (14 percent), chest pain or discomfort (7 percent), exertional palpitations (7 percent), and rest palpitations (7 percent). These symptoms generally are thought to arise from the increased ventricular rate and the loss of left-atrial contribution to cardiac output. A tachycardia-induced left-ventricular dysfunction also may be responsible for symptoms. However, given the association of left-ventricular dysfunction preceding development of AF, the frequency of this complication is difficult to determine.

Thromboembolism is a well-known complication of AF. In the Framingham Study, the risk of stroke in those with rheumatic heart disease and AF was increased 17-fold compared with age-matched controls (Wolf, Dawber, Thomas et al., 1978). The risk was increased five-fold in those with nonrheumatic AF. In the Manitoba Followup Study, AF independently doubled the risk for stroke (Krahn, Manfreda, Tate et al., 1995). In the Whitehall Study and the Regional Heart Study, the relative risk for stroke in non¡rheumatic AF was 6.9 and 2.3, respectively (Flegel, Shipley and Rose, 1987). The attributable risk of stroke increased with age in the Framingham Study (Wolf, Abbott, Kannel et al., 1991). The attributable risk of AF for stroke was only 1.5 percent in participants aged 50 to 59 years and increased to 23.5 percent for those aged 80 to 89 years. The increased risk of stroke in patients with AF is thought to be due to thrombi developing in the left atria, particularly the left-atrial appendage, resulting from left-atrial dilatation and loss of left-atrial function.

The total mortality rate also is increased in patients with AF. The Manitoba Followup Study found a 1.3-fold increase (Krahn, Manfreda, Tate et al., 1995), the Framingham Study a 1.7-fold increase (Kannel, Abbott, Savage et al., 1982), and the Whitehall Study a 2.6-fold increase (Flegel, Shipley, and Rose, 1987).

## Management

In addition to treating underlying conditions, the management of AF may be divided into three areas-ventricular rate control, restoration and maintenance of sinus rhythm, and prevention of thromboembolism.

Rate control most commonly is achieved by the pharmacological suppression of conduction and prolongation of refractoriness in the atrio-ventricular node, resulting in a slower ventricular response to the fibrillating atrium. For patients with severe symptoms related to a rapid ventricular rate, intravenous medications often are indicated. For rate control in patients with less severe or no symptoms, oral medications are sufficient. Digoxin has long been used in the management of AF. Beta-adrenergic antagonists and calcium-channel-blockers frequently are used in patients who tolerate them (e.g., who have no significant heart failure). If the pharmacological control of ventricular rate is not effective, nonpharmacological methods such as atrioventricular nodal ablation with permanent pacemaker insertion may be employed.

Restoration of sinus rhythm in patients with AF can be achieved through electrical cardioversion or pharmacological conversion. Lown (1963) first described the use of direct current cardioversion in patients with AF in 1963. Alternatively, several anti¡arrhythmic agents have been proposed for the pharmacological conversion of AF. In addition, these agents have been used to maintain sinus rhythm, whether cardioversion was achieved through electrical or pharmacological means. Quinidine was the first antiarrhythmic agent, introduced in 1918 (Singh, 1998). In the 1960s, multiple other agents were developed, including beta-adrenergic antagonists and amiodarone. The most common classification of antiarrhythmic agents outlined by Vaughan-Williams (Singh, 1998; Vaughan-Williams, 1970) is based on the electropharmacological actions on the myocardial tissue. Class I agents block sodium-channel conduction. These agents are further divided into Ia (quinidine, procainamide, and disopyrimide), Ib (e.g., lidocaine), and Ic (e.g., flecainide, propafenone) classes. Class II agents (e.g., propanolol, esmolol) are beta-adrenergic antagonists. Class III agents (e.g., amiodarone, sotalol, ibutilide, dofetilide) prolong repolarization through potassium channel blockade. Class IV agents are calcium channel antagonists (e.g., verapamil, diltiazem). Some agents have properties from different classes; particularly notable are the beta-adrenergic antagonist properties of propafenone and sotalol. The Class I and III agents are the most frequently used to convert to or maintain sinus rhythm. Their use must be weighed against the risk of ventricular proarrhythmia such as torsade des pointes. Because of this risk of ventricular arrhythmia, antiarrhythmic therapy has traditionally been initiated in a hospital setting. With newer agents having a better toxicity profile, the decreased cost and increased convenience of outpatient treatment may lead to more outpatient initiation.

The prevention of thromboembolic complications predominantly consists of antiplatelet therapy (e.g., aspirin, indobufen), anticoagulation (e.g., heparin, coumadin), or a combination (e.g., aspirin plus low-dose coumadin). Standard heparin, though effective in the acute setting, is not practical for long-term anticoagulation. Low molecular weight heparin has been developed for potential longer-term management but has not yet been adequately studied. Thus, warfarin is the most common long-term anticoagulant. However, safe but effective anticoagulation with warfarin requires chronic laboratory monitoring to remain within a therapeutic window that balances risks of thromboembolic and bleeding complications. The risk-benefit ratio of anticoagulation depends upon the risk status of the patient. Though it is thought that in lower-risk patients the benefits of anticoagulation may not outweigh the risks and costs, no absolute risk threshold has been established. In addition to its use in patients who are to remain in AF chronically, anticoagulation is used for stroke prophylaxis in those patients undergoing acute cardioversion. If AF has been present for more than 48 hours in these patients, therapeutic anticoagulation is recommended for 3 weeks before cardioversion and 4 weeks after cardioversion (Prystowsky, Benson, Fuster et al., 1996).

Echocardiography has been proposed to aid in the management of AF in three ways. First, because a complicating stroke is presumed to originate from an intracardiac thrombus, echocardiography has been proposed to stratify patients as to risk of stroke. Transesophageal echocardiography is highly accurate for visualizing thrombus in the left-atrial appendage (Manning, Weintraub, Waksmonski et al., 1995). Transthoracic echocardiography also can identify patients with left-ventricular dysfunction, who are at high risk for stroke. Second, echocardiography has been proposed to identify patients with dilated left atria, the theory being that these patients would be less likely to be cardioverted to sinus rhythm or less likely to maintain sinus rhythm. Third, trans¡esophageal echocardiography has been proposed to identify patients without left-atrial thrombus, who safely could undergo acute cardioversion without the conventional 3 weeks of precardioversion anticoagulation. A randomized controlled clinical trial-the Assessment of Cardioversion Using Transesophageal Echocardiography (ACUTE)-is under way to evaluate this strategy.

Thus, the management of patients with AF presents many options for the clinician. The initial choice of aggressive rhythm control versus appropriate rate control with treatment to prevent thromboembolism is being tested in a randomized controlled trial (Atrial Fibrillation Follow-up Investigation of Rhythm Management [AFFIRM], 1997; Planning and Steering Committees of the AFFIRM study, 1997). However, this study is not scheduled to finish analysis until 2002. Even after the results of this trial are known, questions regarding the best strategy for a given patient likely will remain. Many strategies of restoration and maintenance of sinus rhythm exist. Similarly, many strategies for the prevention of thromboembolism exist.

## Purpose of Evidence Report

This report presents the results of our assessment of the evidence on key issues in the management of AF. We chose to limit the study population to those patients with new onset AF (excluding postoperative AF) to best approximate a typical outpatient pre¡sentation. We chose to limit the assessment to first-line strategies, excluding invasive or emerging therapies applied more frequently to AF refractory to first-line therapies.

We identified the relevant questions, performed a systematic review of the evidence, and constructed evidence tables of the available information. We supplemented the tables with meta-analyses and decision analyses where relevant. The overall objective of this report is to synthesize the evidence that should guide clinicians in their management of patients with new onset AF.