# Appendix I. Article Review Form

## Conversion of AF and Maintenance of Sinus Rhythm

1. Article ID# ________________________

2. First author: _______________________

3. Reviewer's Name: ____________________

4. BASIC FEATURES:

a. did NOT addresshuman data
b. ONLY addressed post-op atrial fibrillation
c. ONLY addressed refractory atrial fibrillation
d. adults are NOT part of the population
e. NO original data
f. did NOT address pharmacologic or electrical management of atrial fibrillation or atrial flutter
g. was NOT randomized or quasi-randomized (acceptable randomization includes random number generators OR using techniques like DOB, date of admission, hospital #, or an alternating scheme for assignment OR not stating exact method used although article describes the study as 'randomized')
h. cannot separate subjects with atrial fibrillation from those with other arrhythmias

## Do Not Go On If Any of the Above Items Is Checked

5. Type of study: *CIRCLE ALL THAT APPLY*

- cardioversion (drug or DC) vs no cardioversion (rate control, anticoagulation)
- DC cardioversion vs drug cardioversion
- drug cardioversion and/or maintenance of sinus rhythm (drug vs drug vs placebo)
- rate control (drug vs drug vs placebo)
5 other ( ............................................................................................................... )

## Quality Assessment

### I. Representativeness of Study Population

| | | POINTS
6. Was the setting and population from which study sample drawn described and dates of study reported?
| a. adequate | (setting AND population described AND start date and end date specified) | 2
| b. fair | (one or more of these NOT reported OR poor descriptions) | 1
| c. inadequate | (not specified) | 0
| d. not applicable | | NA
7. Were detailed inclusion/exclusion criteria provided, so as to allow replication?
| a. adequate | (detailed description of specific inclusion and exclusion criteria OR statement that all consecutive patients enrolled) | 2
| b. fair | (some description but would be difficult to replicate based on information provided) | 1
| c. inadequate | (minimal description or none at all) | 0
| d. not applicable | | NA
8. Was a log of patients excluded/not participating provided?
| a. adequate | (all reasons for exclusion AND # excluded or no exclusions) | 2
| b. fair | (only one of above criteria specified or information not quite sufficient to allow replication) | 1
| c. inadequate | (none of above criteria specified) | 0
| d. not applicable | NA
9. Does the study describe patients' characteristics at enrollment in 3 key areas?
| demographics: | age gender race socioeconomic status
| arrhythmia: | type of atrial fibrillation (e.g. new onset, chronic, flutter, paroxysmal) duration of atrial fibrillation
| co-morbidities: | h/o HTN/CAD/MI/angina/rheumatic heart disease h/o DM/smoking h/o CVA/TIA baseline LV function or LA size NYHA class or CHF symptoms
| a. adequate | (>2 factors in all 3 key areas described) | 2
| b. fair | (1-2 factors in at least 2 areas described) | 1
| c. inadequate | (factors in 0-1 areas described) | 0
| d. not applicable | | NA

### II. Bias and Confounding

| | | POINTS
10. | Was assignment of patients to study groups randomized?
| a. yes | (investigators could not predict assignment) | 2
| b. partial | (used DOB, date of admission, hospital #, or alternating scheme for assignment OR did not state method of randomization | 1
| c. not randomized | | 0
| d. unclear | | 0
| e. not applicable | | NA
11. | Was there blinding of treatment supervisors, patients, and outcome assessors?
| a. adequate | (all three blinded, including all treatment arms) | 2
| b. fair | (only 2 of the 3 blinded, or some but not all of the armsblinded in all 3 ways) | 1.5
| c. poor | (only 1 of the 3 blinded) | 1
| d. none of the 3 blinded or unknown | | 0
| e. not applicable | | NA
12. | Did the groups have any important differences on key factors?
| key factors:; - age; - gender; - race; - socioeconomic status; - type of atrial fibrillation; - h/o HTN/CAD/MI/angina/rheumatic heart disease; - h/o DM/smoking; - h/o CVA/TIA; - baseline LV function or LA size; - NYHA class or CHF symptoms
| a. groups equivalent in all factors examined | | | 2
| b. groups have an important difference on at least one factor | | | 1
| c. analysis not done | | | 0
| d. not applicable or impossible | | | NA

### III. Description of Therapy

| | | POINTS
13. | 13. Was there a complete description of the primary therapeutic regimens used by each group?
| a. adequate | (protocol could be replicated given the completeness and detail-e.g., procedures, drugs, dose, route, duration) | 2
| b. fair | (some detail but insufficient to ensure replication) | 1
| c. inadequate | (very little or no detail) | 0
| d. not applicable | | NA
14. | 14. Was there an assessment of treatment compliance?
| a. adequate | (pill counts or drug levels) | 2
| b. fair | (surveys, phone calls, or other patient reports) | 1
| c. not done or technique not reported | | 0
| d. not applicable | | NA
15. | Was there a description of other ancillary medications/procedures given to each treatment group (e.g., coumadin, ASA, digoxin, cardioversion)?
| a. adequate | (e.g., drug name, dose, frequency, route, duration,procedure) | 2
| b. fair | (some description but would be difficult to replicate with information provided) | 1
| c. inadequate | (not described or not mentioned) | 0
| d. not applicable | | NA
16. | Were there any differences in ancillary medications/procedures between the treatment groups which could have affected results?
| a. no differences | (essentially the same) | 2
| b. minor differences | (minor differences in protocols) | 1
| c. major differences or differences not discussed
| | (e.g. different drugs/procedures between groups) | 0
| d. not applicable | | NA

### IV. Outcomes and Follow-Up

| | | POINTS
17. | Which of the following outcomes were reported?
| 1 conversion to sinus rhythm; 2 relapse of atrial fibrillation; 3 decrease in resting heart rate; 4 all cause mortality; 5 CVD-specific mortality; 6 MI; 7 CVA; 8 TIA; 9 NYHA class or CHF symptoms; 10 QOL measure; 11 complications & side effects (hemorrhage, ventricular arrhythmias)
| a. 6 - 11 of the above | (>50% of the determined important outcomes) | 2
| b. 3 - 5 of the above | (25-50% of the determined important outcomes) | 1
| c. 0 - 2 of the above | (<25% of the determined important outcomes) | 0
18. | Was there a description of the criteria for determining outcomes?
| a. adequate | (clear definitions of each outcome ANDexact techniques to assess the outcome) | 2
| b. fair | (only one of above provided) | 1
| c. inadequate | (neither provided) | 0
| d. not applicable | | NA
19. | Were the outcome assessment procedures objective?
| a. adequate | (e.g., Holter monitors, head CT/MRI) | 2
| b. fair | (e.g., patient reports, physician opinion) | 1
| c. inadequate | (no mention of evaluation methods) | 0
| d. not applicable | | NA
20. | Are there numbers, reasons, and outcomes of withdrawals?
| a. numbers, reasons, and outcomes (or no withdrawals) | | 2
| b. only 1-2 of the 3 discussed | | 1
| c. none of the 3 discussed | | 0
| d. not applicable | | NA
21. | What was the most withdrawals for any treatment group?
| a. none | | 2
| b. < 10% | | 2
| c. 10 - 20% | | 1
| c. > 20% | | 0
| d. unknown | | 0
| e. not applicable | | NA
22. | What was the planned length of followup?
| a. > 12 months | | 2
| b. 1 - 12 months | | 1
| c. < 1 month | | 0
| d. not stated | | 0
| e. not applicable (e.g., study on acute conversion only) | | NA

### V. Statistical Quality and Interpretation

| | | POINTS
23. | For primary endpoints, is the magnitude of difference between groups AND an index of variability (e.g., test statistic, p value, standard error, confidence interval) stated?
| a. adequate | (both reported with index of variabilityusing standard error or confidence intervals) | 2
| b. fair | (both reported with index of variability usingonly test statistic or p value) | 1
| c. inadequate | (one or both not reported) | 0
| d. not applicable | | NA
24. | Was the statistical test for all analyses clearly identified?
| a. adequate | (yes for all analyses) | 2
| b. fair | (yes for only some of the analyses) | 1
| c. inadequate | (not for any of the analyses) | 0
| c. not applicable | | NA
25. | For primary endpoints, was there assessment at multiple time points in the followup?
| a. yes | | 2
| b. no | | 0
| c. not applicable | (e.g., followup period very short) | NA
26. | If groups were not comparable at study onset, was there adjustment for potential confounders with multivariate or stratified analyses AND were confounders coded in a way to make such control adequate?
| a. adequate | (adjustment done AND confounders appropriately coded) | 2
| b. fair | (adjustment done BUT confounders not coded appropriately OR coding unclear) | 1
| c. inadequate | (adjustment not done) | 0
| d. not applicable | | NA
27. | Were cross-overs handled appropriately in analysis?
| a. sensitivity analysis | | 2
| b. by intention to treat | | 2
| c. by 'treatment received' analysis only | | 1
| d. by none of the above | | 0
| e. unknown | | 0
f. not applicable | NA

## Content Assessment

### Basic Features

28. In what country was the study mainly performed?

a. US
b. Canada
c. Europe
d. >2 of the above
e. other ( ............................................... )
f. unknown

29. How many centers were involved?

a. 1
b. 2-5
c. > 5
d. unknown

30. - 31. years of study (i.e., data collection) ............................. to ...............................

32. list inclusion/exclusion criteria: (verbatim from article description)

| | INCLUSION | EXCLUSION
a. | age
b. | gender/race
c. | type of atrial fibrillation (e.g., chronic, paroxysmal, flutter)
d. | duration of atrial fibrillation
e. | h/o HTN, CAD, MI, angina, valvular disease
f. | h/o DM, smoking
g. | h/o CVA, TIA
h. | baseline LV function or LA size
i. | NYHA class or CHF symptoms
j. | h/o hyperthyroidism
k. | other (please specify)

| | INCLUSION | EXCLUSION
DEMOGRAPHICS | AGE
| GENDER
| RACE
ARRHYTHMIA | AFIB ONLY
| CHRONIC AFIB
| PAROXYSMAL AFIB
| FLUTTER
| NEW-ONSET AFIB
| OTHER
| DURATION
HEART DISEASE | H/O HTN
| H/O CAD
| H/O RECENT MI
| H/O VALVULAR DISEASE
| H/O ANGINA
| BASELINE LVFUNCTION
| BASELINE LA SIZE
| NYHA CLASS
| CHF SYMPTOMS
| OTHER
| CURRENTANTIARRYTHMIC USE
OTHER DISEASE | H/O DM
| H/O SMOKING
| H/O CVA OR TIA
| HEPATICDYSFUNCTION
| ASTHMA/COPD
| RENAL DYSFUNCTION
| H/O THYROIDDISEASE
| PREGNANCY/LACTATION
| CHILDBEARING AGE
| OTHER

| | INCLUSION | EXCLUSION
STATUS | VENTRICULAR RATE
| HEMODYNAMICINSTABILITY
| CURRENT DIGOXINUSE
| DIGOXIN TOXICITY
| SYSTOLIC BP
| OTHER
LABS | POTASSIUM
| ELECTROLYTEABNORMALITY
| MAGNESIUM
| OTHER
EKG | PRE-EXCITATION
| 2 OR 3 AV BLOCK
| SICK SINUSSYNDROME
| BUNDLE BRANCHBLOCK
| QRS DURATION
| QT INTERVAL
| H/O TORSADES
| OTHER
ALLERGIES | ALLERGIES

33. - 40. treatment groups:

| | Group A | Group B | Group C | Group D | Group E | comments
33 | drug
34 | N
35 | initial dose (write in UNITS)
36 | initial route (0 = po, 1 = IV)
37 | maintenance dose (write in UNITS)
38 | maintenance frequency
39 | maintenance route (0 = po, 1 = IV)
40 | goal treatment duration (write in UNITS)

1. DC cardioversion | 7. propafenone | 13. digoxin
2. quinidine | 8. amiodarone | 14. placebo or 'usual care' or control
3. procainamide | 9. sotalol | 15. other (............................... )
4. disopyramide | 10. esmolol | 16. other (............................... )
5. flecainide | 11. verapamil | 17. other (............................... )
6. encainide | 12. diltiazem | 18. other (............................... )

41. Any important changes in protocols after study started? (please describe)

42. - 46. other medications/procedures given to ANY subjects in each treatment group: *CHECK ALL THAT APPLY*

| | Group A | Group B | Group C | Group D | Group E
42 | digoxin
43 | coumadin
44 | ASA
45 | DC cardioversion
46 | other (____________)

### Patients

47. age range of subjects (years) ................................. to...................................
48. did the study do subgroup analysis by age? (0 = no, 1 = yes)
| a. used < or > 65 yo | .....................................
| b. ages by decades | .....................................
| c. other: ___________________ | .....................................

49. - 51. age of subjects in years:

| | Group A | Group B | Group C | Group D | Group E | overall
49 | mean age
50 | median age
51 | other method of reporting age (specify): ___________

52. type of population from which study subjects drawn: *CHECK ALL THAT APPLY*

a. hospitalized patients
b. generalist outpatient practices
c. cardiology outpatient specialist practices
d. other (............................................................ )
e. not stated

53. - 56. study breakdown of atrial fibrillation duration: (ex. <1 week: 20 in Group A, 19 in Group B; > 30 days: 12 in Group A, 22 in Group B)

| duration | Group A | Group B | Group C | Group D | Group E | overall
53
54
55
56

57. - 75. baseline characteristics of subjects:

| | Group A | Group B | Group C | Group D | Group E | overall
57 | # male
58 | # non-white
59 | # with prevalentangina, MI, CAD
60 | # with prevalentHTN
61 | # with prevalentDM
62 | # prevalentsmokers
63 | # with h/o CVA orTIA
64 | # with normal LV function (defined in study as ____________)
65 | # with normal LAsize (defined in study as ____________)
66 | mean LVfunction (write in EF vs SF)
67 | mean LA size (write in UNITS)
68 | # using other CVmeds at study onset (anticoagulation excluded)
69 | # in NYHA class IIIor IV
70 | # in chronicatrial fibrillation
71 | # with paroxysmalatrial fibrillation
72 | # with atrialflutter
73 | # with new onsetatrial fibrillation (no prior documented episodes)
74 | # withrheumatic/valvular heart disease
75 | # hyperthyroid

76. comments on any of the above characteristics:

### Outcomes

77. Primary outcome (s) of the study: (main outcome (s) for which the study was powered)

*CIRCLE ALL THAT APPLY*
a. conversion to sinus rhythm | g. CVA
b. relapse of atrial fibrillation | h. TIA
c. decrease in resting heart rate | i. improvement in NYHA class/CHF symptoms
d. all-cause mortality | j. improvement in QOL score
e. CVD-specific mortality | k. arrhythmia
f. MI | l. other:______________________________

78. Were costs of the therapeutic regimens estimated in this report?

a. yes
b. no

79. Does this study evaluate the cost-benefit or cost-effectiveness of the therapeutic interventions?

a. yes
b. no

80. Did the study perform Kaplan Meier/survival or time to event analysis?

a. yes
b. no

81. - 82.

| | Group A | Group B | Group C | Group D | Group E | comments
81 | goal time of F/U
82 | mean # relapses ofatrial fibrillation per patient (for paroxysmal AF)

83. conversion to sinus rhythm

| Group A | Group B | Group C | Group D | Group E
numerator
denominator
mean time of F/U
median time toevent
OR
comments:

84. relapse of atrial fibrillation

| Group A | Group B | Group C | Group D | Group E
numerator
denominator
mean time of F/U
median time toevent
OR
comments:

85. decrease in resting heart rate (if dichotomized, defined in study as )

| Group A | Group B | Group C | Group D | Group E
numerator
denominator
mean time of F/U
median time toachieve target rate
OR
mean HR or mean HR [image]
comments:

86. all-cause mortality

| Group A | Group B | Group C | Group D | Group E
numerator
denominator
mean time of F/U
median time toevent
OR
comments:

87. CVD-specific mortality

| Group A | Group B | Group C | Group D | Group E
numerator
denominator
mean time of F/U
median time toevent
OR
comments:

88. MI

| Group A | Group B | Group C | Group D | Group E
numerator
denominator
mean time of F/U
median time toevent
OR
comments:

89. CVA related to electrical cardioversion

| Group A | Group B | Group C | Group D | Group E
anticoagulatednumerator
anticoagulateddenominator
non-anticoagulatednumerator
non-anticoagulateddenominator
comments:

90. CVA, other than in the above question (#89)

| Group A | Group B | Group C | Group D | Group E
numerator
denominator
mean time of F/U
median time to event
OR
comments:

91. TIA related to electrical cardioversion

| Group A | Group B | Group C | Group D | Group E
anticoagulatednumerator
anticoagulateddenominator
non-anticoagulatednumerator
non-anticoagulateddenominator
OR
comments:

92. TIA, other than in the above question (#91)

| Group A | Group B | Group C | Group D | Group E
numerator
denominator
mean time of F/U
median time to event
OR
comments:

93. improvement in NYHA class/CHF symptoms

| Group A | Group B | Group C | Group D | Group E
numerator
denominator
mean time of F/U
median time to event
OR
comments:

94. improvement in QOL score (QOL measure: )

| Group A | Group B | Group C | Group D | Group E
numerator
denominator
mean time of F/U
median time to event
OR
mean change in QOL score
comments:

95. life-threatening arrhythmias

| Group A | Group B | Group C | Group D | Group E
numerator
denominator
mean time of F/U
median time to event
OR
comments: (list short-term life-threatening arrhythmias)

96. other arrhythmia (not atrial fibrillation)

| Group A | Group B | Group C | Group D | Group E
numerator
denominator
mean time of F/U
median time to event
OR
comments: (list short-term other arrhythmias)

97. other side effects causing study withdrawal (i.e., hemorrhage, severe nausea)

| Group A | Group B | Group C | Group D | Group E
numerator
denominator
mean time of F/U
median time to event
OR
comments: (list reported side effects)

98. Did the study report echocardiographic predictors of these outcomes?

CVA | | (0 = no, 1 = yes)
| a. in stratified analysis | ______________
| b. in regression model | ______________
| c. other: _____________________________________ | ______________
conversion to sinus rhythm
| d. in stratified analysis | ______________
| e. in regression model | ______________
| f. other:______________________________________ | ______________
other outcome: ____________________
| g. in stratified analysis | ______________
| h. in regression model | ______________
| i. other:______________________________________

99. heart rate control in context of exercise tolerance

| Group A | Group B | Group C | Group D | Group E
units measured (specify UNITS used e.g., VO_2_, distance walked)
units measured (specify UNITS used e.g., VO_2_, distance walked)
was method used a treadmill test/exercise stress test (EST)?
was method used a test of walking distance?
comments: (e.g., EST protocol used, average minutes accomplished)

100. Do you know of other publications about this same trial in the literature?

a. yes (trial name or pertinent authors or article ID:__________________________)
b. no