# Appendix H. Abstract Review Form

Delete, because article: did not address management of atrial fibrillation or atrial flutter; - did not address human data; - only addressed post-op atrial fibrillation; - Adults are not part of the study population; - No original data; - Others:_______________________________ Do not go on if any of above items is checked; - Article not in English | - Cardioversion (Electric or Pharmacological) vs No Cardioversion (rate control, anticoagulation); Cardioversion vs None; - Electric Cardioversion vs Pharmacological Cardioversion; - Pharmacological Cardioversion or maintenance of sinus rhythm (drug vs drug, drug vs placebo); - ________________________Outpatient strategies; - Clinical trial on different diagnostic strategies; - ____Anticoagulation vs aspirin or vs placebo; - ____Rate control (drug vs drug vs placebo)
- not a controlled trial | - This article does not apply to any of the above study questions.; - However, get article for reference regarding ____________
*Secondary questions | - Unclear: get article to decide
- Invasive treatment; - New invasive diagnostic tests | Any comments to be tagged ____________________________________________ ____________________________________________