# Appendix G. Additional Search Strategy for Key Question 5

What is the diagnostic value of tests, such as transesophageal echocardiography and transthoracic echocardiography, that can be used in the evaluation of new onset atrial fibrillation?

Database: Ovid Version 3.0, Medline <1966 - present> Searched on June 4, 1998

1 exp atrial fibrillation/
2 atrial fibrillat$.tw.
3 electric countershock/
4 cardiover$.tw.
5 thromboembolism/
6 thromboembol$.tw.
7 cerebrovascular disorders/
8 stroke$.tw.
9 1 or 2
10 3 or 4
11 5 or 6
12 7 or 8
13 11 or 12
14 9 and 10 and 13
15 limit 14 to human
16 limit 15 to english language
17 echocardiography/
18 echocardiograph$.tw.
19 17 or 18
20 9 and 19 and 13
21 limit 20 to human
22 limit 21 to english language
23 echocardiography, transesophageal/
24 transesophageal echocardiography.tw.
25 23 or 24
26 9 and 25 and 13
27 limit 26 to human
28 limit 27 to english language
29 9 and 19 and 10
30 limit 29 to human
31 limit 30 to english language
32 16 or 22 or 28 or 31