# Appendix F. Additional Search Strategy for Key Question 4

What types of therapy can be safely administered as outpatient?

Database: Ovid Version 3.0, Medline <1966 - present> Searched on March 6, 1998

- Overall Atrial Fibrillation
  1 exp atrial fibrillation/
  2 atrial fibrillat$.tw.
  3 atrial flutter.tw,sh
  4 or/1-3
- Outpatient/
  5 Outpatients/
  6 outpatient$.tw.
  7 5 or 6
  8 clinic.tw.
  9 office.tw.
  10 8 or 9
- Atrial Fibrillation and Outpatient/
  11 4 and 7
  12 4 and 10
  13 11 or 12
  14 limit 13 to english language