# Appendix E. Cochrane Optimal Search Strategy for Retrieval of Controlled Trials

## Phase 1

1 randomized controlled trial.pt
2 controlled clinical trial.pt
3 randomized controlled trials/
4 random allocation/
5 double-blind method/
6 single-blind method/
7 or/1-6
8 animal/not human/
9 7 not 8