# Appendix D. Overall Topic Search Strategy for CENTRAL and MEDLINE

1 exp atrial fibrillation/
2 atrial fibrillat$.tw.
3 atrial flutter.tw,sh
4 or/1-3