# Appendix B. Questionnaire Regarding New Onset Atrial Fibrillation

Name: ___________________________________________________________________

We at the Johns Hopkins University Evidence-Based Practice Center will be developing an evidence report on management of new onset atrial fibrillation. We would like to solicit input from experts from varied clinical perspectives on key questions regarding new onset atrial fibrillation. Please take a moment to assist us in identifying the most pertinent issues that need to be addressed in our study. Your feedback is most appreciated. Please return the survey by fax to Dr. Robert McNamara at (410) 955-0825 by November 1. Should you have any questions, please call us at (410) 614-4768 or e-mail us at rmcnamara@jhsph.edu.

The following nine questions regarding new onset atrial fibrillation are being considered for our study. Please write in the spaces provided any other questions that you think are particularly relevant or controversial. Please choose five questions that you deem as the most important and rank them in the order of importance (i.e., number 1 being the most important), including any additional questions you have written.

Appendix B. Questionnaire Regarding New Onset Atrial Fibrillation

Rank 1-5 1 = most important | Possible Questions | Comments
| Which patients with new onset atrial fibrillation should receive attempts at cardioversion and which should receive only conservative treatment with rate control and thromboembolism prophylaxis?
| What is the efficacy of electrical cardioversion alone compared with antiarrhythmic therapy alone compared with both together?
| What is the risk/benefit ratio of each of the antiarrhythmic agents used in the management of atrial fibrillation?
| How does anticoagulation compare to aspirin in preventing thromboembolism in patients with atrial fibrillation?
| Should transesophageal echocardiography be used to determine whether anticoagulation is necessary before cardioversion?
| What should be included in the diagnostic work-up for new onset atrial fibrillation (e.g., thyroid function tests, echocardiography, etc.)?
| What types of therapy for atrial fibrillation can safely be performed as an outpatient rather than as an inpatient?
| What is the role of invasive therapy such as the surgical Maze procedure or atrial pacing with a permanent pacemaker?
| What is the role of emerging therapy such as implantable atrial defibrillator, catheter-based maze procedure, or ablation of focal atrial fibrillation?

FAX to Robert L. McNamara (410) 955-0825

Below are four additional questions that may apply to any of the above general management questions. Write in the spaces provided any other questions that you think are particularly important to be assessed in an evidence report. Then, choose three questions that you deem as the most important and rank them in the order of importance (i.e., number 1 being the most important), including any additional questions you have written.

Rank 1-3 1= most important | The most importance in an evidence report to be determined, the role of: | Comments
| age of the patient
| duration of atrial fibrillation (e.g., sustained vs. paroxysmal)
| degree of associated structural heart disease (as opposed to lone atrial fibrillation)
| other (please specify)
| other (please specify)

FAX to Robert L. McNamara (410) 955-0825

1. How might your organization use an evidence report on new onset atrial fibrillation? Check all that apply.

- Would use report of facilitate development of new pratice guideline on management of atrial fibrillation
- Would use report to assess the appropriateness of our organization's existing guidelines on management of atrial fibrillation
- Would use report to prepare eductaional materials for physicians
- Would use report to prepare educational materials for patients
- Other (please specify)
- Other (please specify)

2. Other comments? ________________________________________________________________________ ________________________________________________________________________ ________________________________________________________________________ ________________________________________________________________________ ________________________________________________________________________ * * * * * * * * * * * * * * * * * * * * * * * * * * * * * * * * * * * * * * * * * * * * * * * * * * * * *

Completed by: _________________________ __________________________________

Last Name First Name

Telephone #: (__) ___________________ Fax #: (__) __________________