# Appendix O. Articles Identified Too Late for Inclusion in Evidence Synthesis

The following articles were identified too late for inclusion in this evidence synthesis.

Bianconi L, Mennuni M, for the PAFIT-3 Investigators. Comparison between propafenone and digoxin administered intravenously to patients with acute atrial fibrillation. Am J Cardiol 1998;82:584-8.

Massacci E, Morellini C, De PG, Chioffi M, Longobardi M, Cellino F, Dulbinska D, Salerno JA. Flecainide versus amiodarone in preventing paroxysmal idiopathic atrial fibrillation. New Trends Arrhythmias 1991;7:693-8.

Reisinger J, Gatterer E, Heize G, Wiesinger K, Zeindlhofer E, Gattermeier M, Poelzl G, Kratzer H, Ebner A, Hohenwallner W, Lenz K, Slany J, Kuhn P. Prospective comparison of flecainide versus sotalol for immediate cardioversion of atrial fibrillation. Am J Cardiol 1998 Jun 15;81:1450-4.

Volgman AS, Carberry PA, Stambler B, Lewis WR, Dunn GH, Perry KT, Vanderlugt JT, Kowey PR. Conversion efficacy and safety of intravenous ibutilide compared with intravenous procainamide in patients with atrial flutter or fibrillation. J Am Coll Cardiol 1998 May;31(6):1414-9.

Vos MA, Golitsyn SR, Stangl K, Ruda MY, Van Wijk L, Harry JD, Perry KT, Touboul P, Steinbeck G, Wellens HJJ, for the Ibutilide/Sotalol Comparator Study Group. Superiority of ibutilide (a new class III agent) over DL-sotalol in converting atrial flutter and atrial fibrillation. Heart 1998;79:568-75.

The article by Massacci et al., although published in 1991, was only recently added to EMBASE. It, at present, is not cited in Medline. In addition, this study included only subjects that were "resistant to conventional antiarrhythmic therapy," an inclusion criterion that differed from the other trials included in our review.

The other four articles were all published in 1998, which is why they were not previously identified by our searches.