# Appendix N. Summary of Abstract Review Disagreements Between Reviewers

A pilot test for the abstract review form was conducted using first 30 citations. The reviewers for the pilot test were Eric Bass, Robert McNamara, and David Yu. Consensus was reached regarding disagreements between all reviewers, and the abstract form was modified.

The remaining citations were then distributed among five reviewers in a way that each citation is reviewed by two reviewers. Overall, the pairings for reviewers were as follows: Eric Bass (EB) and David Yu (DY) reviewed 212 citations together, Robert McNamara (RM) and Marlene Miller (MM) reviewed 232, Jodi Segal (JS) and Eric Bass (EB) reviewed 31, Eric Bass and Robert McNamara reviewed 20, Robert McNamara and David Yu reviewed 20, and Eric Bass and Marlene Miller reviewed 6 citations.

Types of disagreement among reviewers

Disagreements (Number of Citations) | | | | | | | | | Total Number n=521
Deletion | Disagreement on whether to include the study or not | Reviewer A=delete-post-op Reviewer B=eligible for CV question or Reviewer A=eligible for anticoag. Q Reviewer B=not applicable to any Q | 24 | 0 | 1 | 3 | 27 | 1 | 56/521 (10%)
Deletion | Disagreement on the reason for deletion | Reviewer A=delete-not manage. of Afib Reviewer B=delete-not post-op or Reviewer A=not applicable to any Q Reviewer B=delete-post-op | 22 | 0 | 0 | 1 | 32 | 2 | 57/521(10%)
Classification | Complete disagreement on the classification of the study topics | Reviewer A=Cardioversion Reviewer B=Anticoagulation | 5 | 1 | 0 | 0 | 4 | 0 | 10/521 (1%)
Classification | Partial disagreement on the classification of the study topic | Reviewer A=Cardioversion and Anticoagulation Reviewer B=Cardioversion | 9 | 2 | 3 | 0 | 4 | 1 | 19/521 (3%)
Quantifying of the Secondary Question | Disagreement on classification | Reviewer A=invasive treatment Reviewer B=did not choose the category | 3 | 0 | 0 | 2 | 5 | 0 | 10/521 (1%)
Identifying Articles Not in English | Disagreement on identification | Reviewer A=checked "not in English" Reviewer B=did not check "not in English" | 2 | 0 | 0 | 0 | 2 | 0 | 4/521 (0.007%)
Identifying "Not controlled Trial"Disagreement on identification | Disagreement on identification | Reviewer A=checked "not a controlled trial" Reviewer B=did not check "not a controlled trial" | 2 | 0 | 0 | 0 | 4 | 0 | 6/521 (1%)