# Appendix M. Article Review

## Reasons for Ineligibility (total number ineligible 64)

Reasons for Ineligibility (total number ineligible 64)

Category | Number of Citations
did not address human data | 0
only addressed postoperative atrial fibrillation | 2
only addressed refractory atrial fibrillation | 1
adults are not part of the population | 0
no original data | 6
not applicable to one of study question | 12
was not randomized or quasi-randomized | 14
duplicate tria | l4
no data on relevant clinical outcomes | 12
data in this article are reported in another article about the study | 2
data on AF patients cannot be separated from data on patients with other arrhythmias | 8
data on non-postoperative AF cannot be separated from data on postoperative AF | 1
half of the patients were randomized and other half not randomized: can't separate the results | 1
only addressed management of patients with accessory pathways, including patients with AV reentrant tachycardia or atrial fibrillation | 1
Total # not eligible | 64