# Appendix L. Abstract Review

## Reasons for Ineligibility (total number ineligible 283)

Reasons for Ineligibility (total number ineligible 283)

Reasons for ineligibility | Number of citations
article does not address management of atrial fibrillation or atrial flutter | 128
article does not include human data | 0
study only addressed postoperative atrial fibrillation | 65
adults are not part of the study population | 0
no original data | 21
not applicable to study question | 59
no usable data on outcomes by treatment group | 5
bioavailability | 1
other: does not provide subgroup data on treatment group because group still blinded | 1
pharmacokinetics | 2
duplicate citation | 1
Total: | 283