# Appendix K. List of Journals Cited More Than Twice in Atrial Fibrillation Database as of April 2, 1998, Used for REVEAL Service

Journal Name (number of citations in database)

- American Journal of Cardiology (31)
- European Heart Journal (16)
- Journal of The American College of Cardiology (13)
- American Heart Journal (11)
- British Heart Journal (8)
- Circulation (8)
- Annals of Internal Medicine (7)
- International Journal of Cardiology (6)
- Lancet (6)
- Archives of Internal Medicine (5)
- Clinical Cardiology (5)
- Journal of Cardiovascular Pharmacology (5)
- New England Journal of Medicine (5)
- Pacing-Clin-Electrophysiol (4)
- Acta-Med-Scand (3)
- Annals of Emergency Medicine (3)
- Cardiovascular Drugs and Therapy (3)
- Chest (3)
- Journal of Electrocardiology (3)