# Appendix J. Article Review Form

Article I.D. #______

## Antithrombotic Therapy

1. Article I.D. #

2. First Author

3. Reviewer's Name

4. Basic Features:

a. did NOT address human data
b. ONLY addressed post-operative atrial fibrillation
c. adults are NOT part of the population
d. NO original data
e. did NOT address anti-coagulation in atrial fibrillation or atrial flutter
f. NO randomization or quasi-randomization such as with random numbers, alternating pattern, dates of entry, dates of birth, chart numbers

DO NOT GO ON IF ANY OF THE ABOVE ITEMS ARE CHECKED

5. Type of study:

a. Long term anticoagulation for atrial fibrillation
b. Short term anticoagulation around the time of cardioversion

## Quality Assessment

Instructions: Circle the letter of the one best response.

### Representativeness

| | Points
6. Is there a description of the setting and the population from which the study participants were drawn and the period of time over which they were enrolled?
| a. Adequate (description of setting, population, and time) | 2
| b. Fair (inadequate description of one) | 1
| c. Inadequate (inadequate description of more than one) | 0
| d. Not applicable | NA
7. | Is there a detailed description of both the inclusion and exclusion criteria to allow for replication?
| a. Adequate (there is a detailed description of specific inclusion and exclusion criteria, or there is a statement that all consecutive patients were enrolled) | 2
| b. Fair (there is description of inclusion and exclusion criteria but would be difficult to replicate based on information presented) | 1
| c. Inadequate (minimal description or none at all) | 0
| d. Not applicable | NA
8. Is there a log and description of the patients excluded from the study?
| a. Adequate (complete description of excluded subjects or no exclusions) | 2
| b. Fair (log or description or detail sufficient to allow replication) | 1
| c. Inadequate (no log or description) | 0
| d. Not applicable | NA
9. Are the characteristics of the study population described?
| · demographics; - age; - gender; - race; - socioeconomic status
| · arrhythmia; - type [flutter, fibrillation, paroxysmal, chronic]; - duration of condition
| · comorbidities; - history of CVA, HTN, smoking, diabetes, coronary artery disease,rheumatic heart disease, valvular disease
| a. Adequate (describes two or more variables in each category) | 2
| b. Fair (describes one or two variables in two or more categories) | 1
| c. Inadequate (only one or no category described adequately) | 0
| d. Not applicable | NA

### Bias and Confounding

| | Points
10. | Was assignment of patients to groups randomized?
| a. Yes (investigators could not predict assignment) | 2
| b. Questionable (used chart numbers, alternating pattern, dates of entry, dates of birth, or other method susceptible to selection bias) | 1
| c. No | 0
| d. Not applicable | NA
11. How complete was the blinding?
| a. Very complete (treatment supervisors, patients, and outcomes evaluators blinded and all arms of the study were blinded) | 2
| b. Fairly complete (only two of the three were blinded or not all of the arms were blinded) | 1
| c. Incomplete (no blinding) | 0
| d. Unknown | 0
| e. Not applicable | NA
12. | Do the groups have important differences in any one of the following characteristics?; - Age; - Sex; - Race; - Socioeconomic status; - % with only A. fibrillation; - % with only A. flutter; - % with mixed fib./flutter; - % with paroxysmal A. fib; - HTN; - DM; - History of stroke or TIA; - CHF; - Smoking; - Aspirin use; - Angina; - Peripheral vascular disease; - MI; - Carotid bruit; - Rheumatic heart disease
| a. No differences in any of the variables examined | 2
| b. Some differences (differences in one of the above variables) | 1
| c. Major differences (differences in two or more of the above variables) | 0
| d. Analysis not presented or unknown | 0
| e. Not applicable | NA

### Description of Therapy

| | Points
13. | Is there complete description of the primary therapeutic regimens used by each group?
| a. Adequate (protocol could be replicated given the completeness and detail of the description-e.g., procedures, drugs, dose, duration) | 2
| b. Fair (major intervention is described but insufficient detail to ensure replication) | 1
| c. Inadequate (very little or no detail) | 0
| d. Not applicable | NA
14. | Is there assessment of compliance with treatment?
| a. Adequate (documentation with pill counts or with PT/INR) | 2
| b. Fair (likely compliance, documentation by patient report or survey) | 1
| c. Inadequate (poor or undocumented assessment) | 0
| d. Not applicable | NA
15. | Is there a description of other therapies given to the groups?
| a. Adequate (complete description of use of aspirin, anti-platelet agents, anti-coagulants, antiarrhythmics, or explicit statement that these were not used) | 2
| b. Fair (partial description of other medications or treatments used) | 1
| c. Inadequate (not discussed) | 0
| d. Not applicable | NA
16. | Are there differences in the ancillary therapies received by the groups?
| a. No differences in therapy | 2
| b. Minor differences in therapy (dose or duration differences in ancillary medications or modest differences in therapy) | 1
| c. Major differences in therapy (ancillary medication or therapy used in one group that could influence outcome, or no documentation) | 0
| d. Not applicable | NA

### Outcome Assessment and Followup

| | Points
17. | Which of the following clinical outcomes were reported?
  [image] stroke | [image] deaths from stroke
  [image] hemorrhage | [image] deaths from hemorrhage
  [image] emboli | [image] deaths from emboli (excluding cerebral)
  [image] myocardial infarction | [image] deaths from myocardial infarction
  [image] deaths from all causes | [image] quality of life
| a. > 5 of the above (> 50% of the outcomes defined as important) | 2
| b. 3-4 of the above (25%-50% of the outcomes defined as important) | 1
| c. 0-1 of the above (< 25% of the outcomes defined as important) | 0
18. | Was there a description of the criteria for determining outcomes?
| a. Adequate (provides clear definitions of each outcome and the means of assessing the outcome) | 2
| b. Fair (defines the outcomes, but no description of the means of assessment) | 1
| c. Inadequate (unclear what outcomes are being assessed) | 0
| d. Not applicable | NA
19. | Were the means of determining all major outcomes objective?
| a. Yes (e.g., determined cerebral event with CT or MRI, quantified blood transfused, Doppler, or angiography to detect emboli) | 2
| b. Fair (used clinical judgment without objective measure for one or more outcomes) | 1
| c. No (no objective means of diagnosis or not described) | 0
| d. Not applicable | NA
20. | Are data presented on the numbers, reasons, and outcomes of withdrawals?
| a. Yes (all three presented or no withdrawals) | 2
| b. Fair (one or two of the three described) | 1
| c. No (no description of withdrawals) | 0
| d. Not applicable | NA
21. | What was the greatest percentage of withdrawal from either group?
| a. None (no withdrawals) | 2
| b. <10% | 2
| c. 10%-20% | 1
| d. >20% | 0
| e. Not applicable | NA
22. | What was the planned duration of followup?
| a. > 12 months | 2
| b. 1 month to 12 months | 1
| c. < 1 month | 0
| d. unreported or unknown | 0
| e. Not applicable | NA

### Statistical Analysis

| | Points
23. | For major endpoints, were the essential measurements of statisticalsignificance presented?
| a. Adequate (reports magnitude of effect and reports variability with confidence intervals or standard error) | 2
| b. Fair (reports magnitude of effect but reports variability with test statistic or p value only) | 1
| c. Inadequate (one or both not reported) | 0
| d. Not applicable | NA
24. | Were the statistical methods clearly identified for all analyses?
| a. Adequate (description of methods for all analyses) | 2
| b. Fair (description of methods for major outcomes only) | 1
| c. Inadequate (little or no description of statistical methods) | 0
| d. Not applicable | NA
25. | For the major outcomes, was there assessment at multiple time points during the followup time?
| a. Yes | 2
| b. No | 0
| c. Not applicable (e.g., followup period very short) | NA
26. | Were confounders adjusted for in the analysis if there were differences in the groups at the time of randomization?
| a. Yes (multivariate analysis or stratified analysis was performed, with confounders coded appropriately for control of confounding) | 2
| b. Possibly (multivariate analysis done but confounders coded suboptimally or unclearly, or possibility of residual confounding) | 1
| c. No (analysis was not done) | 0
| d. Not applicable (e.g., no differences at time of randomization) | NA
27. | How were cross-overs handled in the analysis?
| a. Adequately (analyzed by intention-to-treat with a sensitivity analysis comparing this to analysis by treatment received) | 2
| b. Adequately (analyzed by intention-to-treat without sensitivity analysis) | 2
| c. Fair (analyzed by treatment received only) | 1
| d. Poorly (analyzed by another method) | 0
| e. Unknown (no description of how they were handled) | 0
| f. Not applicable | NA

Descriptive Features | warfarin | aspirin | other or placebo (specify)

28a.Total Number of Subjects Enrolled
28b. age [ ] mean and S.D. or
[ ] median and range

29. number male

30. number from a minority ethnic group

31. number with hypertension

32. number with diabetes

33. number with history of stroke or TIA

34. number with history of TIA

35. number with CHF

36. measure of LV function

[specify EF (%), LV ED dimension (mm), etc.]

37. left atrial size (mm)

38. number with valvular heart disease

39. number with hyperthyroidism

40. number with angina

41. number with a history of myocardial infarct

42. number with vascular disease

[claudication, bruits, dx, of PVD, carotid bruits]

43. number with carotid bruits

44. number of smokers

[specify definition; eg., current, ever]

45. number using aspirin (if not study drug)

46. number on antiarrhythmic therapy for the purpose of conversion to sinus rhythm

47. number with atrial fibrillation

[chronic and paroxysmal]

48. number with paroxysmal atrial fibrillation

49. number with atrial flutter

[chronic and paroxysmal]

50. number with paroxysmal atrial flutter

## The Database. Anticoagulation Sub-Study

What were the inclusion criteria for this study?

demographics

- Age _______
- Sex _______
- Race _______

type of atrial fibrillation

- only atrial fibrillation
- only atrial flutter
- mixed fib./flutter
- paroxysmal A. fib.
- any of the above

comorbidities

- HTN ________
- DM
- History of stroke or TIA
- CHF (EF%) ________
- Smoking
- Aspirin use
- Angina
- Peripheral vascular disease
- MI
- Carotid bruit
- Rheumatic heart disease

What were the exclusion criteria for this study?

demographics

- Age _______
- Sex _______
- Race _______

type of atrial fibrillation

- mixed fib./flutter
- paroxysmal A. fib
- only atrial flutter

comorbidities

- Requirement for anticoagulation
- Medical contraindication to anticoagulation or study drug
- Aspirin use
- NSAID use
- HTN _________
- DM
- History of stroke or TIA
- CHF (EF%) or (class) _________
- Smoking
- Angina
- Peripheral vascular disease
- MI
- Carotid bruit disease/ or any valvular disease
- impaired renal function __________
- impaired hepatic function
- bleeding (coagulation) disorder
- alcoholism
- hyperthyroidism
- pregnancy
- history of gastrointestinal bleeding or ulcers
- thromocytopenia
- cancer

(specify)

### Costs and Study Details

51. Are estimates provided of costs associated with treatment?

a. yes
b. no

52. In what country was the study mainly done?

a. U.S.
b. Canada
c. Europe
d. Other
e. Unknown

53. How many centers were involved?

a. 1
b. 2-5
c. >5
d. unknown

54. From where did the patients come?

a. hospitalized patients
b. general practitioners offices (outpatients)
c. specialty clinics (outpatients)
d. unknown

55. What was the source of financial support?

a. N.I.H.
b. V.A.
c. Drug company
d. Other or Unknown

56. What were the inclusion criteria for this study?

demographics | other
- Age _______; - Sex _______; - Race _______ | __________________ __________________ __________________

type of atrial fibrillation

- only atrial fibrillation
- only atrial flutter
- mixed fib./flutter
- paroxysmal A. fib
- any of the above

comorbidities

- HTN ________
- DM
- History of stroke or TIA
- CHF (EF%) ________
- Smoking
- Aspirin use
- Angina
- Peripheral vascular disease
- MI
- Carotid bruit
- Rheumatic heart disease

57. What were the exclusion criteria for this study?

demographics | other
- Age _______; - Sex _______; - Race _______ | __________________ __________________ __________________
type of atrial fibrillation; - mixed fib./flutter; - paroxysmal A. fib; - only atrial flutter
comorbidities; - Requirement for anticoagulation; - Medical contraindication to anticoagulation or study drug; - Aspirin use; - HTN _________; - DM; - History of stroke or TIA; - CHF (EF%)_________; - Smoking; - Angina; - Peripheral vascular disease; - MI; - Carotid bruit; - Rheumatic heart disease/or any valvular disease

Treatment | Comments
Warfarin
  58. Brand
  59. Target INR
  60. Percentage of time at target INR
  61. Percentage of time above target INR
  62. Percentage of time below target INR
  63. Was treatment intended to continue throughout the time of followup? | Yes/No
Aspirin
  64. Dose
  65. Was treatment intended to continue throughout time of follow up? | Yes/No
  65. Was treatment intended to continue throughout time of follow up?
Anti-coagulant
  66. Specify drug
  67. Dose
  68. Target PTT
  69. Percentage of time at target PTT
  70. Percentage of time above target PTT
  71. Percentage of time below target PTT
  72. Was treatment intended to continue throughout time of follow up? | Yes/No
  72. Was treatment intended to continue throughout time of follow up?
  73. How long was followup for each group?
  a. warfarin
  b. aspirin
  c. anti-coagulant
  d. placebo
  74. Was there a sub-group analysis done by age? | Yes/No
  75. Does this study report the significant predictors of the major outcomes? | Yes/No

Instruction: Use intention-to-treat data if presented. Specify if not intention-to-treat.

Outcomes | Proportion (num/denom) | O.R.[C.I.] | mean time-to-event | Comments (e.g., reference group)
76. Total incidence of stroke
  a. with warfarin
  b. with aspirin
  c. with anti-coagulant
  d. with placebo
77. Total incidence of major hemorrhage
  a. with warfarin
  b. with aspirin
  c. with anti-coagulant
  d. with placebo
78. Total incidence of minor hemorrhage
  a. with warfarin
  b. with aspirin
  c. with anti-coagulant
  d. with placebo
79. Total incidence of emboli
  a. with warfarin
  b. with aspirin
  c. with anticoagulant
  d. with placebo
80. Total incidence of M.I.
  a. with warfarin
  b. with aspirin
  c. with anticoagulant
  d. with placebo
81. Case-fatality of stroke
  a. with warfarin
  b. with aspirin
  c. with anti-coagulant
  d. with placebo
82. Case-fatality of hemorrhage
  a. with warfarin
  b. with aspirin
  c. with anti-coagulant
  d. with placebo
83. Case-fatality of emboli
  a. with warfarin
  b. with aspirin
  c. with anti-coagulant
  d. with placebo
84. Case-fatality of M.I.
  a. with warfarin
  b. with aspirin
  c. with anti-coagulant
  d. with placebo
85. Overall mortality
  a. with warfarin
  b. with aspirin
  c. with anti-coagulant
  d. with placebo
86. other outcome (specify)
  a. with warfarin
  b. with aspirin
  c. with anti-coagulant
  d. with placebo
87. other outcome (specify)
  a. with warfarin
  b. with aspirin
  c. with anti-coagulant
  d. with placebo
88. Quality of Life score
  a. with warfarin
  b. with aspirin
  c. with anti-coagulant
  d. with placebo
89. Costs specify units
  a. with warfarin
  b. with aspirin
  c. with anti-coagulant
  d. with placebo
90. Do you know of other publications about this same trial in the literature?; a. yes (trial name or pertinent authors or article ID: __________________); b. no