# Appendix A. Technical Experts for Evidence Report on Management of Atrial Fibrillation

## Core Experts

- Hanan S. Bell, Ph.D., American Academy of Family Physicians
- Ronald D. Berger, M.D., Ph.D., Johns Hopkins University School of Medicine
- Gary Gerstenblith, M.D., Johns Hopkins University School of Medicine
- David E. Haines, M.D., University of Virginia
- Michael L. LeFevre, M.D., American Academy of Family Physicians

## American College of Cardiology/American Heart Association (ACC/AHA)

- Andrew E. Epstein, M.D., University of Alabama
- Peter Kudenchuk, M.D., University of Washington
- Douglas P. Zipes, M.D., Indiana University School of Medicine

## American College of Physicians (ACP)

- John Kastor, M.D., University of Maryland Medical System
- Jerome A. Osheroff, M.D., Deputy Editor, Integrated Clinical Information Resources
- David R. Goldmann, M.D., Editor-in-Chief, Physicians' Information and Educational Resource Project

## American Heart Association (AHA)

- Barbara Drew, R.N., Ph.D., School of Nursing, University of California at San Francisco
- Kathleen McCauley, Ph.D., R.N., C.S., F.A.A.N., University of Pennsylvania School of Nursing

## North American Society of Pacing and Electrophysiology (NASPE)

- Robert J. Myerburg, M.D., University of Miami
- Eric Prystowsky, M.D.

## American Medical Association (AMA)

- Naomi Kuznet, M.D.

## Society for Medical Decision-Making (SMDM)

- Randall Cebul, M.D., MetroHealth Medical Center

## Food and Drug Administration (FDA)

- Mitchell J. Shein

## National Blue Cross/Blue Shield

- Clifford Amend, M.D.

## Mid-Atlantic Medical Services, Inc. (MAMSI)

- Scott Cantor, M.D.

## Other

- Chris Burton, M.D., Consensus Conference on Atrial Fibrillation
- Brian Gage, M.D., M.H.S., Washington University