# Appendixes

Appendix A. Technical Experts for Evidence Report on Management of Atrial Fibrillation

Appendix B. Questionnaire Regarding New Onset Atrial Fibrillation

Appendix C. Causal Pathway of Atrial Fibrillation

Appendix D. Overall Topic Search Strategy for CENTRAL and MEDLINE

Appendix E. Cochrane Optimal Search Strategy for Retrieval of Controlled Trials

Appendix F. Additional Search Strategy for Key Question 4

Appendix G. Additional Search Strategy for Key Question 5

Appendix H. Abstract Review Form

Appendix I. Article Review Form

Appendix J. Article Review Form

Appendix K. List of Journals Cited More Than Twice in Atrial Fibrillation Database as of April 2, 1998, Used for REVEAL Service

Appendix L. Abstract Review

Appendix M. Article Review

Appendix N. Summary of Abstract Review Disagreements Between Reviewers

Appendix O. Articles Identified Too Late for Inclusion in Evidence Synthesis

Appendix P. Subgroup Analysis