# Glossary

Bipolar disorder - a type of mood disorder characterized by both (1) one or more major depressive episodes and (2) either one or more manic or mixed episodes (Bipolar 1) or hypomanic episodes (Bipolar II). The disorder may or may not be accompanied by psychotic symptoms. In community samples, the prevalence of bipolar disorder (approximately 1 percent) is lower than the prevalence of major depressive disorder (at least 6 percent). Given that management of bipolar disorder is notably different from that of major depressive disorder, making such a diagnostic distinction is critical.

External validity - the extent to which a study's conclusions can be applied to populations and settings outside those of the study itself.

Incidence - the percentage of the population with an illness episode that begins within a given period of time (e.g., during pregnancy or within the first 3 months following delivery).

Internal validity - the extent to which a study is appropriately designed and conducted to measure what it is intended to measure.

Major depressive disorder - a type of mood disorder characterized by one or more major depressive episodes. The Diagnostic and Statistical Manual, version III (DSM-III) defines a major depressive episode as a period of at least 2 weeks during which an individual experiences daily disturbance in mood (intense feelings of sadness or loss of interest in activities that are usually pleasurable) and at least four of eight symptoms: (1) too much or too little sleep, (2) appetite or weight disturbance, (3) psychomotor agitation or retardation, (4) loss of energy, (5) feelings of worthlessness or excessive guilt, (6) problems with concentration or indecisiveness, (7) loss of interest in sex, and (8) recurrent suicidal thoughts or attempts. DSM-IV changed these criteria to the following: (1) symptoms must be present most of the day and nearly every day during the episode, (2) clinically significant distress or impairment in functioning must be present, (3) the syndrome must not be the result of the direct physiologic effects of a substance or a general medical condition, (4) major depressive disorder is still diagnosed after an acute grief reaction if the syndrome lasts for more than 2 months.

Major depressive disorder is not diagnosed if the syndrome is attributable to an acute grief reaction or a nonaffective psychotic condition such as schizophrenia. In addition, major depressive disorder is not diagnosed if there is a history of a manic, hypomanic, or mixed episode.

Maternity blues - a subthreshold cluster of depressive symptoms commonly described in up to 50 percent of postpartum women. This transient condition does not require an intervention.

Meta-analysis - a quantitative approach for systematically combining evidence from multiple previous research studies on a particular parameter or association to arrive at a conclusion about the body of research on that parameter or association.

Meta-regression - a statistical analysis of the association between one or more study characteristics and the observed magnitude of effect.

Minor depressive disorder (also known as minor depression) - a subthreshold diagnosis with a variety of definitions, but in general seen as one or more episodes of depression lasting 2 weeks or more but with fewer symptoms than required for a diagnosis of major depressive disorder.

Period prevalence - the percentage of the population with depression over a period of time (e.g., during pregnancy or from delivery to the end of the first 3 months postpartum).

Perinatal depression - a condition encompassing major and minor depressive episodes that occur during pregnancy (prenatal) or within the first 12 months following delivery (postpartum).

Point prevalence - the percentage of the population with a condition at a given point in time (e.g., at 24 weeks gestation or 9 weeks postpartum).

Postpartum - for the purposes of this review, the period from parturition to 12 months after delivery.

Postpartum depression - according to DSM-IV, a specific type of major depressive disorder with onset of a major depressive episode within 4 weeks postpartum.

Postpartum psychosis - also known as puerperal psychosis, this condition is a severe and rare postpartum disorder, affecting 1 to 2 per 1,000 births. Women with postpartum psychosis present with new onset of delusions or prominent hallucinations. More than half of these episodes meet the criteria for major depressive disorder, and many women ultimately prove to have bipolar illness. Management of postpartum psychosis substantially differs from the much more common presentation of major depressive disorder with postpartum onset.

Power (statistical power) - the probability of detecting as “statistically significant” a postulated level of effect.

Precision - a measure of how close an estimator is expected to be to the true value of a parameter. Precision is related to the standard error of the estimator; less precision is reflected by a larger standard error.

Prenatal - the period of pregnancy from conception to parturition.

Puerperium - the 6-week period following delivery.

Reference standard (also known as gold standard) - the diagnostic assessment against which the screening test is compared to gauge the accuracy of the screening test. The reference standard determines the actual presence of disease. For psychiatric illness, the reference standard is often a clinical assessment by a mental health professional or a structured or semi-structured diagnostic interview.

Screen (also screening) - the use of a measure or test, often a formal instrument or tool, to classify an individual with respect to her likelihood of having a particular disorder. A screen itself does not diagnose the illness—those screening positive require subsequent diagnostic confirmation to confirm the presence of the disease.

Sensitivity - the ability of a test to identify correctly those who have a condition, computed as the percentage of true positive values correctly predicted by the test. A sensitive test identifies few false-negative cases.

Specificity - the ability of a test to identify correctly those who do not have a condition, computed as the percentage of true negative values correctly predicted by the test. A specific test identifies few false-positive cases.