# References and Included Studies

1 Kessler R C, McGonagle K A, Zhao S, et al. Lifetime and 12-month prevalence of DSM-III-R psychiatric disorders in the United States. Results from the National Comorbidity Survey. Arch Gen Psychiatry. 1994;51(1):8-19. [pmid: 8279933].
2 Robins L, Regier D. Psychiatric Disorders in America. New York: Free Press, 1991.
3 Depression Guideline Panel. Depression in Primary Care: Volume 1. Detection and Diagnosis. Clinical Practice Guideline, Number 5. Rockville, Md: Agency for Health Care Policy and Research, 1993; AHCPR No. 93-0550.
4 Shaw J, Kennedy SH, Joffe RT. Gender differences in mood disorders: A clinical focus. In. Gender Psychopathol. Washington, DC: American Psychiatric Press, 1996: 89–111.
5 Burke K C, Burke J D Jr, Rae D S, et al. Comparing age at onset of major depression and other psychiatric disorders by birth cohorts in five US community populations. Arch Gen Psychiatry. 1991;48(9):789-95. [pmid: 1929768].
6 Kessler R C. Epidemiology of women and depression. J Affect Disord. 2003;74(1):5-13. [pmid: 12646294].
7 Murray L, Stein A. The effects of postnatal depression on the infant. Baillieres Clin Obstet Gynaecol. 1989;3(4):921-33. [pmid: 2700150].
8 Marmorstein N R, Malone S M, Iacono W G. Psychiatric disorders among offspring of depressed mothers: associations with paternal psychopathology. Am J Psychiatry. 2004;161(9):1588-94. [pmid: 15337648].
9 Burke L. The impact of maternal depression on familial relationships. Int Rev Psychiatry. 2003;15(3):243-55. [pmid: 15276963].
10 Stein A, Gath D H, Bucher J, et al. The relationship between post-natal depression and mother-child interaction. Br J Psychiatry. 1991;158:46-52. [pmid: 2015451].
11 Flynn H A, Davis M, Marcus S M, et al. Rates of maternal depression in pediatric emergency department and relationship to child service utilization. Gen Hosp Psychiatry. 2004;26(4):316-22. [pmid: 15234828].
12 American Psychiatric Association (APA). Practice guideline for the treatment of patients with major depression (revision). Am J Psychiatry 2000; 157(4).
13 Wagner H R, Burns B J, Broadhead W E, et al. Minor depression in family practice: Functional morbidity, comorbidity, service utilization, and outcomes. Psychol Med. 2000;30(2):1377-90. [pmid: 11097078].
14 Oxman T E, Sengupta A. Treatment of minor depression. Am J Geriatr Psychiatry. 2002;10(3):256-64. [pmid: 11994212].
15 Judd L L, Rapaport M H, Yonkers K A, et al. Randomized, placebo-controlled trial of fluoxetine for acute treatment of minor depressive disorder. Am J Psychiatry. 2004;161(10):1864-71. [pmid: 15465984].
16 Bloch M, Daly R C, Rubinow D R. Endocrine factors in the etiology of postpartum depression. Compr Psychiatry. 2003;44(3):234-46. [pmid: 12764712].
17 Jones I, Craddock N. Familiality of the puerperal trigger in bipolar disorder: results of a family study. Am J Psychiatry. 2001;158(6):913-7. [pmid: 11384899].
18 Klein M, Essex M J. Pregnant or depressed? The effect of overlap between symptoms of depression and somatic complaints of pregnancy on rates of major depression during the second trimester. Depression. 1994;2:1994-5.
19 O'Hara M W, Neunaber D J, Zekoski E M. Prospective study of postpartum depression: Prevalence, course, and predictive factors. J Abnorm Psychol. 1984;93(2):158-71. [pmid: 6725749].
20 Cox J L, Murray D, Chapman G. A controlled study of the onset, duration and prevalence of postnatal depression. Br J Psychiatry. 1993;163:27-31. [pmid: 8353695].
21 O'Hara M W, Swain A M. Rates and risk of postpartum depression -- A meta-analysis. Int Rev Psychiatry. 1996;8:37-54.
22 Llewellyn A M, Stowe Z N, Nemeroff C B. Depression during pregnancy and the puerperium. J Clin Psychiatry. 1997;58(Suppl 15):26-32. [pmid: 9427874].
23 Yonkers K A, Ramin S M, Rush A J, et al. Onset and persistence of postpartum depression in an inner-city maternal health clinic system. Am J Psychiatry. 2001;158(11):1856-63. [pmid: 11691692].
24 Gaynes B, Gavin N, Meltzer-Brody S, Sleath B, Sutton S. Perinatal Depression: Feasibility Study. Rockville, Md.: Agency for Healthcare Quality and Research (AHRQ), 2003.
25 Cochrane Methods Working Group. Based on the Cochrane Methods Working Group on Systematic Review of Screening and Diagnostic Tests: Recommended Methods, updated June 6, 1996. 1996.
26 Downs S H, Black N. The feasibility of creating a checklist for the assessment of the methodological quality both of randomised and non-randomised studies of health care interventions. J Epidemiol Community Health. 1998;52(6):377-84. [pmid: 9764259].
27 Bennett H A, Einarson A, Taddio A, et al. Prevalence of depression during pregnancy: Systematic review. Obstet Gynecol. 2004;103(4):698-709. [pmid: 15051562].
28 American Psychiatric Association (APA). Diagnostic and statistical manual of mental disorders. Fourth edition. Washington, DC: American Psychiatric Association, 1994.
29 Affonso D D, Lovett S, Paul S M, et al. A standardized interview that differentiates pregnancy and postpartum symptoms from perinatal clinical depression. Birth. 1990;17(3):121-30. [pmid: 2222637].
30 Areias M E, Kumar R, Barros H, et al. Comparative incidence of depression in women and men, during pregnancy and after childbirth. Validation of the Edinburgh Postnatal Depression Scale in Portuguese mothers. Br J Psychiatry. 1996;169(1):30-5. [pmid: 8818365].
31 Berle J, Aarre T, Mykletun A, et al. Screening for postnatal depression. Validation of the Norwegian version of the Edinburgh Postnatal Depression Scale, and assessment of risk factors for postnatal depression. J Affect Disord. 2003;76(13):151-6. [pmid: 12943945].
32 Campbell S B, Cohn J F. Prevalence and correlates of postpartum depression in first-time mothers. J Abnorm Psychol. 1991;100(4):594-9. [pmid: 1757673].
33 Cooper P J, Murray L, Hooper R, et al. The development and validation of a predictive index for postpartum depression. Psychol Med. 1996;26(3):627-34. [pmid: 8733220].
34 Cox J L, Connor Y, Kendell R E. Prospective study of the psychiatric disorders of childbirth. Br J Psychiatry. 1982;140:111-7. [pmid: 7074291].
35 Garcia-Esteve L, Ascaso C, Ojuel J, et al. Validation of the Edinburgh Postnatal Depression Scale (EPDS) in Spanish mothers. J Affect Disord. 2003;75(1):71-6. [pmid: 12781353].
36 Gotlib I H, Whiffen V E, Mount J H, et al. Prevalence rates and demographic characteristics associated with depression in pregnancy and the postpartum. J Consult Clin Psychol. 1989;57(2):269-74. [pmid: 2785127].
37 Hobfoll S E, Ritter C, Lavin J, et al. Depression prevalence and incidence among inner-city pregnant and postpartum women. J Consult Clin Psychol. 1995;63(3):445-53. [pmid: 7608357].
38 Kent G N, Stuckey B G, Allen J R, et al. Postpartum thyroid dysfunction: Clinical assessment and relationship to psychiatric affective morbidity. Clin Endocrinol. 1999;51(4):429-38.
39 Kitamura T, Shima S, Sugawara M, et al. Psychological and social correlates of the onset of affective disorders among pregnant women. Psychol Med. 1993;23:967-75. [pmid: 8134520].
40 Kitamura T, Sugawara M, Shima S, et al. Temporal variation of validity of self-rating questionnaires: Improved validity of repeated use of Zung's Self-Rating Depression Scale among women during the perinatal period. J Psychosom Obstet Gynecol. 1999;20(2):112-7.
41 Kumar R, Robson K M. A prospective study of emotional disorders in childbearing women. Br J Psychiatry. 1984;144:35-47. [pmid: 6692075].
42 Lee D, Yip A, Chiu H, et al. A psychiatric epidemiological study of postpartum Chinese women. Am J Psychiatry. 2001;158(2):220-6. [pmid: 11156804].
43 Lee D, Yip A, Chiu H, et al. Screening for postnatal depression: Are specific instruments mandatory?. J Affect Disord. 2001;63(13):233-8. [pmid: 11246101].
44 Lucas A, Pizarro E, Granada M L, et al. Postpartum thyroid dysfunction and postpartum depression: Are they two linked disorders?. Clin Endocrinol. 2001;55(6):809-14.
45 Matthey S, Barnett B, Howie P, et al. Diagnosing postpartum depression in mothers and fathers: Whatever happened to anxiety?. J Affect Disord. 2003;74(2):139-47. [pmid: 12706515].
46 Murray D, Cox J L. Screening for depression during pregnancy with the Edinburgh Depression Scale (EPDS). J Reprod Infant Psychol. 1990;8(2):99-107.
47 Pop V J, Essed G G, de Geus C A, et al. Prevalence of post partum depression--or is it post-puerperium depression?. Acta Obstet Gynecol Scand. 1993;72(5):354-8. [pmid: 8392265].
48 Watson J P, Elliott S A, Rugg A J, et al. Psychiatric disorder in pregnancy and the first postnatal year. Br J Psychiatry. 1984;144:453-62. [pmid: 6733369].
49 Whiffen V. Vulnerability of postpartum depression: A prospective multivariate study. J Abnorm Psychol. 1988;97(4):467-74. [pmid: 3204233].
50 Yamashita H, Yoshida K, Nakano H, et al. Postnatal depression in Japanese women.Detecting the early onset of postnatal depression by closely monitoring the postpartum mood. J Affect Disord. 2000;58(2):145-54. [pmid: 10781704].
51 Yoshida K, Marks M, Kibe N, et al. Postnatal depression in Japanese women who have given birth in England. J Affect Disord. 1997;43(1):69-77. [pmid: 9127832].
52 Cooper P J, Campbell E A, Day A, et al. Non-psychotic psychiatric disorder after childbirth. A prospective study of prevalence, incidence, course and nature. Br J Psychiatry. 1988;152:799-806. [pmid: 3167466].
53 O'Hara M W, Zekoski E M, Philipps L H, et al. Controlled prospective study of postpartum mood disorders: Comparison of childbearing and nonchildbearing women. J Abnorm Psychol. 1990;99(1):3-15. [pmid: 2307763].
54 Bryan T L, Georgiopoulos A M, Harms R W, et al. Incidence of postpartum depression in Olmsted County, Minnesota. A population-based, retrospective study. J Reprod Med. 1999;44(4):351-8. [pmid: 10319305].
55 Georgiopoulos A M, Bryan T L, Wollan P, et al. Routine screening for postpartum depression. J Fam Pract. 2001;50(2):117-22. [pmid: 11219558].
56 Endicott J, Spitzer R L. A diagnostic interview: The schedule for affective disorders and schizophrenia. Arch Gen Psychiatry. 1978;35(7):837-44. [pmid: 678037].
57 Spitzer RL, Williams JBW, Gibbon M, First MB. Structured Clinical Interview for SSM-III-R. Washington, DC: American Psychiatric Press, 1990.
58 Frist MB, Spitzer RL, Gibbon M, Williams JBW. Structured Clinical Interview for DSM-IV Axis I Disorders (SCID), Clinical Version. Washington, DC: American Psychiatric Press, 1996.
59 Goldberg D P, Cooper B, Eastwood M R, et al. A standardized psychiatric interview for use in community surveys. Br J Prev Soc Med. 1970;24(1):18-23. [pmid: 5435083].
60 Janca A, Ustun T B, Sartorius N. New versions of World Health Organization instruments for the assessment of mental disorders. Acta Psychiatr Scand. 1994;90(2):73-83. [pmid: 7976462].
61 Robins L N, Helzer J E, Croughan J, et al. National Institute of Mental Health Diagnostic Interview Schedule. Its history, characteristics, and validity. Arch Gen Psychiatry. 1981;38(4):381-9. [pmid: 6260053].
62 Lecrubier Y, Sheehan D, Weiller E, et al. The Mini International Neuropsychiatric Interview (M.I.N.I) a short diagnostic structured interview: Reliability and validity according to the CIDI. Euro Psychiatry. 1997;12:224-31.
63 Wing JK, Cooper JE, Sartorius N. The Measurement and Classification of Psychiatric Symptoms. Cambridge: Cambridge University Press, 1974.
64 Montgomery S A, Asberg M. A new depression scale designed to be sensitive to change. Br J Psychiatry. 1979;134:382-9. [pmid: 444788].
65 Spitzer R L, Endicott J, Robins E. Research diagnostic criteria: Rationale and reliability. Arch Gen Psychiatry. 1978;35(6):773-82. [pmid: 655775].
66 American Psychiatric Association (APA). Diagnostic and statistical manual of mental disorders. Third edition. Washington, DC: American Psychiatric Association, 1987.
67 Pitt B. “Atypical” depression following childbirth. Br J Psychiatry. 1968;114(516):1325-35. [pmid: 5750402].
68 Blazer D G, Kessler R C, McGonagle K A, et al. The prevalence and distribution of major depression in a national community sample: The National Comorbidity Survey. Am J Psychiatry. 1994;151(7):979-86. [pmid: 8010383].
69 Finlay-Jones R, Brown G W, Duncan-Jones P, et al. Depression and anxiety in the community: Replicating the diagnosis of a case. Psychol Med. 1980;10(3):445-54. [pmid: 7443899].
70 Ballard C G, Davis R, Cullen P C, et al. Prevalence of postnatal psychiatric morbidity in mothers and fathers. Br J Psychiatry. 1994;164(6):782-8. [pmid: 7952984].
71 Beck C T, Gable R K. Comparative analysis of the performance of the Postpartum Depression Screening Scale with two other depression instruments. Nurs Res. 2001;50(4):242-50. [pmid: 11480533].
72 Boyce P, Stubbs J, Todd A. The Edinburgh Postnatal Depression Scale: Validation for an Australian sample. Aust N Z J Psychiatry. 1993;27(3):472-6. [pmid: 8250792].
73 Cox J, Chapman G, Murray D, et al. Validation of the Edinburgh Postnatal Depression Scale (EPDS) in non-postnatal women. J Affect Disord. 1996;39(3):185-9. [pmid: 8856422].
74 Harris B, Huckle P, Thomas R, et al. The use of rating scales to identify post-natal depression. Br J Psychiatry. 1989;154:813-7. [pmid: 2597888].
75 Leverton T J, Elliott S A. Is the EPDS a magic wand? 1. A comparison of the Edinburgh Postnatal Depression Scale and health visitor report as predictors of diagnosis on the Present State Examination. J Reprod Infant Psychol. 2000;18(4):279-96.
76 Murray L, Carothers A. The validation of the Edinburgh Post-natal Depression Scale on a community sample. Br J Psychiatry. 1990;157:288-90. [pmid: 2224383].
77 Whiffen V E. Screening for postpartum depression: A methodological note. J Clin Psychol. 1988;44(3):367-71. [pmid: 3384962].
78 Guedeney N, Fermanian J. Validation study of the French version of the Edinburgh Postnatal Depression Scale (EPDS): New results about use and psychometric properties. Eur Psychiatry. 1998;13:83-9. [pmid: 19698604].
79 Lawrie T, Hofmeyr G, de Jager M, et al. Validation of the Edinburgh Postnatal Depression Scale on a cohort of South African women. S Afr Med J. 1998;88(10):1340-4. [pmid: 9807193].
80 Kitamura T, Shima S, Sugawara M, et al. Temporal variation of validity of self-rating questionnaires: Repeated use of the General Health Questionnaire and Zung's Self-rating Depression Scale among women during antenatal and postnatal periods. Acta Psychiatr Scand. 1994;90(6):446-50. [pmid: 7892778].
81 Lee D, Yip A, Chiu H, et al. Screening for postnatal depression using the double-test strategy. Psychosom Med. 2000;62(2):258-63. [pmid: 10772406].
82 Lee D, Yip S, Chiu H, et al. Detecting postnatal depression in Chinese women. Validation of the Chinese version of the Edinburgh Postnatal Depression Scale. Br J Psychiatry. 1998;172:433-7. [pmid: 9747407].
83 Muzik M, Klier C, Rosenblum K, et al. Are commonly used self-report inventories suitable for screening postpartum depression and anxiety disorders?. Acta Psychiatr Scand. 2000;102(1):71-3. [pmid: 10892613].
84 Wickberg B, Hwang C. Counselling of postnatal depression: A controlled study on a population based Swedish sample. J Affect Disord. 1996;39(3):209-16. [pmid: 8856425].
85 Cox J L, Holden J M, Sagovsky R. Detection of postnatal depression. Development of the 10-item Edinburgh Postnatal Depression Scale. Br J Psychiatry. 1987;150:782-6. [pmid: 3651732].
86 Beck A T, Ward C H, Mendelson M, et al. An inventory for measuring depression. Arch Gen Psych. 1961;4:561-71.
87 Beck AT, Steer RA, Brown GK. Manual for Beck Depression Inventory II (BDI-II). San Antonio, Tx: Psychology Corporation, 1996.
88 Beck A T, Guth D, Steer R A, et al. Screening for major depression disorders in medical inpatients with the Beck depression inventory for primary care. Behav Res Ther. 1997;35:785-91. [pmid: 9256522].
89 Radloff L S. The CES-D Scale: A self-report depression scale for research in the general population. Appl Psychol Measure. 1977;1:385-401.
90 Williams J Jr, Pignone M, Ramirez G, et al. Identifying depression in primary care: A literature synthesis of case-finding instruments. Gen Hosp Psych. 2002;24:225-37.
91 Henkel V, Mergl R, Kohnen R, et al. Use of brief depression screening tools in primary care: Consideration of heterogeneity in performance in different patient groups. Gen Hosp Psychiatry. 2004;26(3):190-8. [pmid: 15121347].
92 Meager I, Milgrom J. Group treatment for postpartum depression: A pilot study. Aust N Z J Psychiatry. 1996;30(6):852-60. [pmid: 9034477].
93 Brisco M. The detection of emotional disorders in the post natal period by health visitors. Health Visit. 1989;62(11):336-8. [pmid: 2592230].
94 Stamp G E, Williams A S, Crowther C A. Evaluation of antenatal and postnatal support to overcome postnatal depression: A randomized, controlled trial. Birth. 1995;22(3):138-43. [pmid: 7575861].
95 Brugha T S, Wheatley S, Taub N A, et al. Pragmatic randomized trial of antenatal intervention to prevent post-natal depression by reducing psychosocial risk factors. Psychol Med. 2000;30(6):1273-81. [pmid: 11097068].
96 Elliott S A, Leverton T J, Sanjack M, et al. Promoting mental health after childbirth: A controlled trial of primary prevention of postnatal depression. Br J Clin Psychol. 2000;39(Pt 3):223-41. [pmid: 11033746].
97 Zlotnick C, Johnson S L, Miller I W, et al. Postpartum depression in women receiving public assistance: Pilot study of an interpersonal-therapy-oriented group intervention. Am J Psychiatry. 2001;158(4):638-40. [pmid: 11282702].
98 Armstrong K, Fraser J, Dadds M, et al. A randomized, controlled trial of nurse home visiting to vulnerable families with newborns. J Paediatr Child Health. 1999;35(3):237-44. [pmid: 10404442].
99 Chabrol H, Teissedre F, Saint-Jean M, et al. Prevention and treatment of post-partum depression: A controlled randomized study on women at risk. Psychol Med. 2002;32(6):1039-47. [pmid: 12214785].
100 Chen C H, Tseng Y F, Chou F H, et al. Effects of support group intervention in postnatally distressed women A controlled study in Taiwan. J Psychosom Res. 2000;49(6):395-9. [pmid: 11182431].
101 Dennis C L. The effect of peer support on postpartum depression: A pilot randomized controlled trial. Can J Psychiatry. 2003;48(2):115-24. [pmid: 12655910].
102 Fleming A S, Klein E, Corter C. The effects of a social support group on depression, maternal attitudes and behavior in new mothers. J Child Psychol Psychiatry. 1992;33(4):685-98. [pmid: 1601943].
103 Hiscock H, Wake M. Randomised controlled trial of behavioural infant sleep intervention to improve infant sleep and maternal mood. Br Med J. 2002;324(7345):1062-5. [pmid: 11991909]. [pmcid: 104332].
104 Honey K L, Bennett P, Morgan M. A brief psycho-educational group intervention for postnatal depression. Br J Clin Psychol. 2002;41(Pt 4):405-9. [pmid: 12437794].
105 Horowitz J A, Bell M, Trybulski J, et al. Promoting responsiveness between mothers with depressive symptoms and their infants. J Nurs Scholarsh. 2001;33(4):323-9. [pmid: 11775301].
106 Onozawa K, Glover V, Adams D, et al. Infant massage improves mother-infant interaction for mothers with postnatal depression. J Affect Disord. 2001;63(13):201-7. [pmid: 11246096].
107 Wisner K L, Wheeler S B. Prevention of recurrent postpartum major depression. Hosp Community Psychiatry. 1994;45(12):1191-6. [pmid: 7868100].
108 Wisner K L, Perel J M, Peindl K S, et al. Prevention of recurrent postpartum depression: A randomized clinical trial. J Clin Psychiatry. 2001;62(2):82-6. [pmid: 11247106].
109 Turk DC, Meichenbaum D, Genest M. Pain and Behavioral Medicine. New York: Guilford, 1983.
110 US Preventive Services Task Force. Screening for depression: recommendations and rationale. Ann Intern Med. 2002;136(10):760-4. [pmid: 12020145].
111 Pignone M P, Gaynes B N, Rushton J L, et al. Screening for depression in adults: a summary of the evidence for the US Preventive Services Task Force. Ann Intern Med. 2002;136(10):765-76. [pmid: 12020146].
112 Hoffbrand S, Howard L, Crawley H. Antidepressant treatment for post-natal depression. Nurs Times. 2001;97(45):35. [pmid: 11966146].
113 Cooper P, Murray L. The impact of psychological treatments of postpartum depression on maternal mood and infant development. In: Cooper P, Murray L, editor(s). Postpartum depression and child development. New York: Guilford, 1997: 201–20.
114 O'Hara M W, Stuart S, Gorman L L, et al. Efficacy of interpersonal psychotherapy for postpartum depression. Arch Gen Psychiatry. 2000;57(11):1039-45. [pmid: 11074869].