# Conclusions and Recommendations

In an effort to identify the evidence base addressing important questions on the epidemiology, screening and diagnosis, and management of perinatal depression, the Safe Motherhood Group (SMG) and the Agency for Healthcare Research and Quality (AHRQ) initially requested a feasibility study to determine whether enough high-quality evidence existed on six separate issues to support a full evidence report. After reviewing our feasibility study, ^24^ SMG and AHRQ requested an evidence report focusing on the three key questions (KQs) covered in this review.

We applied rigorous selection criteria and assessed the quality of each study, bringing a public health perspective to an area of research that traditionally has not had this focus. Our report was limited to depressive illness without psychotic symptoms, the latter complication being much less common and much more challenging to identify and manage. We made a distinction between results involving major depression alone, a discrete clinical syndrome for which treatment is clearly indicated, and results referring to patients with either major or minor depression, for which management is less clear.

This evidence report comprises a comprehensive review of all the available research. In this final chapter, we first review the major findings pertaining to each question and the strength of overall evidence about these issues; we then present some observations and recommendations about future research.

## Conclusions

### Key Question 1: Prevalence and Incidence of Perinatal Depression

For KQ 1, we identified 30 studies of generally moderate size that provide estimates of the prevalence of perinatal depression; 13 of these inquiries provide estimates of incidence. Studies were generally of good quality for reporting completeness and internal validity for bias; by contrast, they were of fair quality for precision and only poor quality for external validity and internal validity for confounding. In particular, the study populations were not representative of the racial and ethnic mix of the countries in which the studies were performed and especially not of the United States.

Our final best estimates of prevalence and incidence were somewhat lower than those reported in prior systematic reviews because we excluded studies that assessed depression based on self-report screens alone, which have been found to overestimate prevalence. Also, we separated out estimates of major and minor depression from estimates of major depression alone. Finally, we included more recent studies that use more precise criteria to identify major depression.

For major depression alone, our final combined point prevalence estimates ranged from 3.1 percent to 4.9 percent at different times during pregnancy and from 1.0 percent to 5.9 percent at different times during the first postpartum year. For major and minor depression, our final combined estimates of point prevalence ranged from 8.5 percent to 11.0 percent at different times during pregnancy and between 6.5 percent and 12.9 percent at different times during the first year postpartum. This nearly 2-fold higher rate suggests that approximately half of the women experience a major depressive episode and half a minor depressive episode at any given time. Confidence intervals surrounding all these estimates remain wide, suggesting that a fair amount of uncertainty remains in the combined estimates.

Fewer estimates were available for the incidence of depression. These limited data suggest that as many as 14.5 percent of pregnant women have a new episode of either major or minor depression during pregnancy, and 14.5 percent have a new episode during the first 3 months postpartum. Considering only major depression, 7.5 percent may have a new episode during pregnancy, with 6.5 percent having a new episode in the first 3 months postpartum.

Are the prevalence and incidence of depression during the perinatal period higher than the rates during nonchildbearing periods? We found three studies that measured the prevalence of major or minor depression and major depression alone for women at different times during these two periods . None of these estimates shows a statistically significant difference. Only one study ^20^ directly compared the incidence (new onset) of perinatal depression to that of nonchildbearing women of similar age; women at 5 weeks postpartum were more than three times as likely as the comparison group to have a new episode of major or minor depression. By 6 months postpartum, this difference had disappeared. An incidence for major depression alone was not reported.

That these estimates did not appear significantly different from those of nonchildbearing women of the same age does not reduce the dramatic burden experienced by women postpartum. Indeed, these estimates, based on the best available evidence, suggest that perinatal depression, whether major or minor depression, is a very common complication of pregnancy. Furthermore, and arguably more important, after labor and delivery this dramatically common complication, rather than primarily affecting one individual, now directly affects two: mother and child.

### Key Question 2: Accuracy of Perinatal Depression Screening Tools

For our analysis of the accuracy of screening tools (KQ 2), we identified 10 studies reporting test characteristics for English-language screeners. In general, studies were of fair to good quality, although external validity was only poor to fair. In particular, the study populations were nearly entirely white, so the accuracy of these screeners in nonwhite perinatal populations is not clear. A major limitation in the available evidence is the very small number of depressed patients involved, a fact that results in substantial imprecision in the point estimate of sensitivity and prevents one from reasonably determining an ideal cutoff point.

For depression during pregnancy, we found only one study reporting on screening accuracy in a population with 6 patients with major depression and 14 patients with either major or minor depression. For major depression, sensitivities for the Edinburgh Postnatal Depression Scale (EPDS) at all evaluated thresholds (12, 13, 14, 15) were 1.0, underscoring the markedly small number of depressed patients involved; specificities ranged from 0.79 (at EPDS ≥ 12) to 0.96 (at EPDS ≥ 15). For major or minor depression, sensitivity was much poorer (0.57 to 0.71); specificity remained fairly high (0.72 to 0.95).

For postpartum depression also, the small number of depressed patients involved in the studies precluded identifying an optimal screener or an optimal threshold for screening. Our ability to conduct a meta-analysis of the results of different studies was limited by the use of multiple cutoffs and other differences across studies that precluded a meaningful interpretation of the results. Where we were able to combine the results , the pooled estimates did not add to what one could conclude from individual studies.

For women with major depression alone, specificity for all screeners (the Beck Depression Inventory [BDI], the Postpartum Depression Screening Scale [PDSS], and the EPDS) was relatively high. This finding suggests that a positive screen was accurate in ruling major depression in; that is, the risk that a screen with one of these instruments would be falsely positive was low. By contrast, sensitivities varied much moreThe EPDS and the PDSS appeared to be more sensitive (with estimates ranging from 0.75 to 1.0 at different thresholds) than the BDI instruments (with estimates from 0.32 to 0.68), but the wide confidence intervals (CIs) overlapped nearly completely. This means that we could not say with confidence that the specificity estimates using the different tools were different.

The point estimates are consistent with what is reported for depression screeners in primary care settings. ^90^ Still, the imprecision is important to clarify. If falsely missing depression (a false negative) is worse than falsely identifying it, as may be the case with this disorder, clinicians must be able to feel confident that the screen is usually positive if the disease is there and that a negative result can help rule out the illness.

For patients with major or minor depression, results were reported for EPDS, BDI, PDSS, and the Center for Epidemiologic Studies-Depression (CES-D). Specificity estimates remained relatively high, but sensitivity results were much lower (ranging from 0.43 to 0.71) than for major depression alone. This means that the ability of the screening instrument to score women as positive for this condition when the disease is present was poorer than for major depression alone. Again, neither any particular cutoff nor any particular screening instrument performed differently from the others. No available comparators were found for primary care populations.

Our results suggest that various screening instruments can identify perinatal depression, most accurately major depression, but clinicians need to know more about the precision of individual instruments. If one assumes that the risk of a false-negative depression screen is worse than the risk of a false-positive screen, perinatal depression is a condition in which sensitivity is likely to be more important than specificity. Whether as a screen for major depression alone or for major or minor depression, specificities appear high and relatively precise. By contrast, sensitivity for identifying either category is imprecise and differs by diagnostic category. For major depression alone, point estimates are equivalent to those in primary care medical settings. For major or minor depression, however, sensitivity is quite low. At this time, these screens do not appear to be useful for identifying patients in this latter category of illness.

### Key Question 3: Screening and Treatment Outcomes

KQ 3 concerned issues of whether screening ultimately leads to improved patient outcomes. Although it is the most vital question from the public health perspective, it is the one with the most limited evidence. Indeed, the studies that we identified were not designed to test whether screening for depression (versus not screening) improved patient outcomes. Such a design would randomize patients to be screened or not to be screened and then compare subsequent outcomes. We found no studies designed in this way.

Instead, we made use of studies in which women were screened by formal depression screening or the presence of a risk factor associated with perinatal depression to identify those at risk of having a depressive illness; then, for those screening positive, the investigators compared the outcomes of women receiving a treatment intervention to those in a control group. This design tests whether, among women identified as at risk of depression by a screen, an intervention improves outcomes compared to the outcomes in a control group. This is an important intermediary step, but it does not directly test whether screening itself improves outcome compared to not screening. All the trials included are treatment studies that had a screening component (either a formal depression screening instrument, or other type of screen that identified women at risk of a depressive illness) but did not have diagnostic confirmation of depression.

We attempted to synthesize the results of the included studies quantitatively, but the study methods (screening instruments, type of intervention, intensity of intervention, outcomes measured) were so heterogeneous that a meta-analytic synthesis would not be meaningful. We also attempted to compare effect sizes to attempt an exploratory analysis of the various studies, but the data necessary to compute these were not available.

For patients whose screening results identified them as at risk of perinatal depression and for whom a subsequent intervention was provided, we identified 15 studies. Four small prenatal studies involved various psychosocial interventions. Quality was poor for three of these studies and fair for one. Overall, the effects of the interventions in these studies were not consistently superior to those in the control groups.

The 11 postpartum studies were of overall fair quality and had larger sample sizes than the prenatal trials. Study populations reflected only a limited racial and ethnic mix, and both external validity and the power to demonstrate statistically significant differences were generally poor. Again, screening tools and interventions varied considerably; the latter involved both psychosocial and pharmaceutical interventions.

Results were mixed. Of the nine trials that employed a psychosocial intervention, six studies ^98–101,^ ^103,^ ^104^ reported significant benefit for depression outcomes in the experimental group compared to those in the control group. The one RCT involving pharmacologic intervention did not show benefit relative to the control group. ^108^ Overall, the evidence available is not sufficient to draw conclusions about this key question. These results, although limited, do suggest that providing some form of psychosocial support to pregnant women at risk of having a depressive illness may decrease depressive symptoms.

## Recommendations for Future Research

The available research suggests that depression is one of the more common complications of the prenatal and postpartum periods and that fairly accurate and feasible screening measures are available. The prenatal or postpartum periods are clearly not times for nonpsychiatric clinicians to ignore depression screening, which is routinely recommended for patients seen in primary care settings. ^110,^ ^111^

Specifics of the course of a depressive illness with onset during the perinatal period, including the severe physiologic and psychological challenges unique to this period that complicate the identification and management of perinatal depression, seem to suggest that this topic would have a substantial degree of high-quality research. We were surprised by the paucity of such evidence in this area. If one assumes that perinatal depression is a significant mental health and public health problem, then larger scale studies are needed involving each of these domains. The small number and small size of relevant studies are not adequate to guide national policy.

Reflecting on the three key questions addressed in this report, we have concluded generally that the level of research warrants both improvement and expansion. The three results chapters discuss the limitations and gaps in these areas in more detail. We summarize here our suggestions for additional research efforts for the future.

For KQ 1, prevalence studies need to account better for the racial and ethnic mix of perinatal depression in the US population. We do not have good evidence about whether and, if so, how perinatal depression rates differ among various ethnic groups. The absence of information on nonwhite populations was dramatic. Better understanding any racial and ethnic variations could help clinicians know where to target screening programs and researchers know where to target studies on screening tools, and it could help researchers clarify the need for more nationally representative perinatal depression samples. Furthermore, researchers need to clarify whether the incidence of perinatal depression is greater than the incidence of depression in nonchildbearing women of similar ages.

For KQ 2, the quality grades point to several areas in which improvements in study design and conduct are needed. In particular, future studies on the test characteristics of screeners must be designed with sample size estimates that take prevalence into account and that project a reasonably precise estimate of sensitivity for the particular illness. Moreover, samples should more closely mirror the target population; specifically, subsequent studies need to provide a more representative racial and ethnic mix. In addition, studies should incorporate a range of other demographic variables that could influence screening performance, such as socioeconomic status measures, and assess the screening tools in these subpopulations.

Furthermore, as Beck and Gable did, ^71^ future research should continue to assess and directly compare multiple screening instruments. This design would provide a head-to-head comparison to allow an evaluation of which screening instrument is more accurate in the setting in which the investigations are carried out. Moreover, studies evaluating the cost-effectiveness of screening, specifically assessing the relative costs of false-negative and false-positive designation, the degree of provider burden, and patient acceptability, are needed to provide insights on how to consider target sensitivity and specificity when attempting to maximize cost-effectiveness.

Diagnosis is another area of concern. Subsequent studies should carefully consider whether to target major depression alone, for which beneficial treatments clearly exist, or the combined category that includes minor depression, a heterogeneous group for which treatment benefit is unclear. Given that the results suggest that available screening tools identify major depression alone more accurately, and noting that the general benefit of interventions is more apparent for major depression alone, we believe that an evidence-based public health perspective recommends targeting major depression alone.

Timing is another factor of future studies deserving more thought. The issue here involves both the need for more epidemiology to confirm prevalence rates at different times as well as the need to confirm what time point(s) would identify the greatest number of depressed women. The bulk of the few screening studies we identified had been conducted in the first 3 months postpartum. Our best estimates of prevalence suggest that depression may remain high for several more months.

More studies are needed to better delineate periods of peak prevalence and incidence, to include not just 3 months but also 6 weeks, 6 months, and 12 months, and subsequent screening studies need to consider testing properties of screening at these later time periods. The very small number of adequate studies currently available hampers plans for screening and intervention programs because the best time for screening, and hence the best clinic location, is not clear. If peak prevalence and incidence occur within the first 6 weeks, the obstetrics clinic is a prime place to target resources for such a program. If, however, peaks occur after this time, most postpartum women will have completed follow-up care with an obstetrician, so programs in an obstetrics clinic may be less helpful. In this case, programs targeting new mothers in family medicine, internal medicine, or pediatric clinics might be more effective.

For KQ 3, several similar or related issues emerged as well. First, studies addressing the relationship between screening and outcome need to recruit and retain sample sizes that are large enough to yield adequate power to detect relevant differences. Second, screening and outcome studies must include populations with a racial and ethnic mix that is more representative of the US populations than the work we have seen to date. Third, interventions involved should be more consistent with what we know to be evidence-based treatments for depression, ^12^ i.e., antidepressant medications ^112^ and/or psychotherapies such as cognitive behavioral therapy ^113^ or interpersonal psychotherapy. ^114^

Type of screening measures used henceforth is another major issue. Of the three KQ 3 studies rated as good, ^98,^ ^101,^ ^108^ only Dennis and colleagues used a depression screener (EPDS). ^101^ Researchers should consider developing and using standardized screening measures, and similar cutoff points, so that some elements of separate studies could be compared more readily. Screening tools with the best supporting evidence would seem to be the best candidates. While the evidence base remains quite limited and any conclusions preliminary, at this time those instruments would appear to be either the EPDS or the PDSS. For major depression alone, an EPDS cutoff of ≥ 13 or a PDSS cutoff of ≥ 81 are reasonably supported by the evidence. For major or minor depression, we found the results too inconclusive to make even a preliminary recommendation.

Finally, studies should be designed to address whether the screening process itself leads to better access to proven treatment and improved outcome relative to usual care. We support additional research on interventions per se, but we conclude that important questions remain about the impact of the screening element. Reviewing studies that used screening as a means of identifying women potentially at high risk and enrolling them in interventional studies is not a sufficient approach to answering issues about the effectiveness of screening.