# Impact of Depression Screening and Interventions on Patient Outcomes

## Introduction

In agreement with the Safe Motherhood Group and the Agency for Healthcare Research and Quality (AHRQ), we directed part of our work to Key Question (KQ) 3: Does prenatal or early postnatal screening for depressive symptoms with subsequent intervention lead to improved outcomes? That is, does screening for depression during pregnancy or the postpartum period and implementing an intervention improve outcomes related to maternal depressive symptoms.? To address KQ 3, we developed an analytic framework (Figure 19), which begins (left side) by identifying a cohort of women with unknown mood state, continues through implementation of a formal screening of the cohort either during pregnancy or in the postpartum period, and (right side) ends with studies of an intervention to assess how it may affect outcome measures of postpartum depression.

Figure 19. Causal Pathway for Key Question 3 on Screening and Treatment Outcomes

As described in this chapter, screening can be done in various settings and with various instruments (as discussed for KQ 2). Interventions are both nonpharmacologic (e.g., counseling and behavioral intervention programs aimed at mothers or, in some cases, both parents or mother-infant dyads) and pharmacologic (e.g., antidepressants). These interventions can be implemented in various outpatient settings (e.g., clinics, homes) and delivered by various types of health professionals, and they may be group efforts or one-on-one activities.

## Methods

Chapter 2 documentsthe methods we used to conduct literature searches and title and abstract or full article reviews. We did not identify any studies that specifically examined the cascade of screening-treatment-outcomes. Thus, we do not have any direct evidence pertaining to KQ3.

All the trials included for KQ3 are treatment studies that had a screening component (either a formal depression screening instrument or other type of screen that identified women at risk of a depressive illness). We included studies conducted worldwide in developed countries where the population could be generalized to pregnant and postpartum women in the United States, regardless of the language spoken. We also included both randomized controlled trials (RCTs) and prospective cohort studies. Additionally, for inclusion in KQ 3, patients were identified by a screen done either during pregnancy or during 12 months postpartum and considered to be “at risk” of having a depressive illness.

We excluded all case-control studies and studies in which patients had had a documented current depressive episode before the initial screening. Furthermore, we excluded two studies that had originally been reviewed for the feasibility study, one because it did not use any screening ^92^ and one because it had no depression severity outcome. ^93^

We attempted to synthesize the results of the included studies quantitatively, but the study methods (screening instruments, type of intervention, intensity of intervention, outcomes measured) were so heterogeneous that a combined result would have little meaning. We also attempted to compare effect sizes in an exploratory analysis of the various studies, but the data necessary to compute these were not available.

Appendix B presents the quality rating form used for articles considered for KQ 3. The total possible score for these studies was 29. We characterized studies with scores of 20 or greater as good, those with scores between 15 and 19 as fair, and those with scores of 14 and below as poor. The domains and maximum points possible for each domain are as follows:

- Reporting (domain score of 11): 10 items covering study aims, measures, patient populations, findings, and statistical presentation; each scored yes or no (1 or 0), except for an item concerning principal confounders that was scored yes, partially, or no (2, 1, or 0, respectively).
- External validity (domain score of 3): Three items relating to representativeness of populations from which people were recruited and of settings and clinicians that treat such patients; each scored yes or no (1 or 0).
- Internal validity-bias (domain score of 7): Seven items relating to issues such as blinding subjects and outcomes assessors, follow-up periods, appropriate statistical tests, and use of reliable and valid outcome measures; each scored yes, no, or unable to determine (1, 0, or 0, respectively).
- Internal validity-confounding (domain score of 6): Six items relating to sources of intervention and control groups, randomization of study subjects and concealment of allocation, adequacy of adjustments for confounding, and loss to follow-up; each scored yes, no, or unable to determine (1, 0, or 0, respectively).
- Power (domain score of 2): One item about use of power analysis to determine sample size; scored no, yes for one measure, or yes for two or more measures (0, 1, and 2, respectively).

## Results

We reviewed a total of 60 titles and abstracts or full articles for KQ 3 drawn from several searches done for the feasibility study and later for this update. Ultimately, we retained 15 studies that met our inclusion criteria. Table 17 summarizes the major characteristics of the 15 included studies, Table 18 presents the results of our quality ratings, and Table 19 shows the results of the various depression assessments made among cases and controls.

Table 17. Major characteristics of studies of screening with interventions for prenatal or postpartum depression

Author, Year | Country | Study Design | Sample Size | Setting | Type of Screening | Type of Intervention
Screening during Pregnancy
Brugha et al., 2000 ^95^ | UK | RCT | 209 | Prenatal clinic | Modified GHQ-D | Structured group prenatal preparation classes
Elliott et al., 2000 ^96^ | UK | Nonran-domized controlled trial | 98 | Prenatal clinic | Leverton Questionnaire | Structured group prenatal preparation classes
| | | | | Crown Crisp
Stamp et al., 1995 ^94^ | Australia | RCT | 129 | Prenatal clinic | Modified prenatal questionnaire | Perinatal support group
Zlotnick et al., 2001 ^97^ | US | RCT | 37 | Prenatal clinic | Screening survey | Four prenatal therapy/skills groups
Screening during Postpartum Period
Armstrong et al., 1999 ^98^ | Australia | RCT | 181 | PP hospital ward | Adverse family risk factors from Brisbane Evaluation of Needs Questionnaire | Regular home visits by child-health nurses
Chabrol et al., 2002 ^99^ | France | RCT | 859 screened | PP hospital ward | EPDS | One CBT prevention group during the delivery hospital stay followed by an at- home CBT- based program in women with major depression
| | | 258 randomized
Chen et al., 2000 ^100^ | Taiwan | RCT | 414 screened | PP hospital ward | Taiwanese BDI | Four weekly PP support group sessions
| | | 115 randomized | | Measures of support
Dennis 2003 ^101^ | Canada | RCT | 501 screened | Child immunization clinics | EPDS | Telephone-based peer support
| | | 44 randomized
Fleming et al., 1992 ^102^ | Canada | Nonrandomized controlled trial | 781 screened | PP hospital ward | EPDS | PP social support group
| | | 152 enrolled | | CES
| | | | | MAACL
Hiscock and Wake, 2002 ^103^ | Australia | RCT | 155 screened | Child-health center | EPDS | Infant sleep intervention group
| | | 99 randomized
Honey et al., 2002 ^104^ | UK | RCT | 45 randomized | Mother/baby clinic | EPDS | Psycho-educational group
Horowitz et al., 2001 ^105^ | US | RCT | 1,215 screened | Community sample of PP women | EPDS | Coached behavioral intervention to promote maternal-baby interaction
| | | 122 randomized
Onozawa et al., 2001 ^106^ | UK | RCT | 59 | PP hospital ward | EPDS | Infant massage plus support group
Wisner and Wheeler, 1994 ^107^ | US | Open trial | 23 | PP hospital ward | Prior history of PPD | Antidepressant medication
Wisner et al., 2001 ^108^ | US | RCT | 581 screened | PP hospital ward | Prior history of PPD | Antidepressant medication
| | | 56 randomized

BDI, Beck Depression Inventory; CBT, cognitive behavioral therapy; CES, Current Experience Scale; EPDS, Edinburgh Postnatal Depression Scale; GHQ-D, General Health Questionnaire Depression Score; MAACL, Multiple Affect Adjective Checklist; PP, postpartum; PPD, postpartum depression; RCT, randomized controlled trial.

Table 18. Quality rating of studies of screening with interventions for prenatal or postpartum depression

Author, Year | Reporting (11) | External Validity (3) | Internal Validity-Bias (7) | Internal Validity-Confounding (6) | Power (2) | Total Score (29)
Screening during Pregnancy
Brugha et al., 2000 ^95^ | 7 | 0 | 3 | 6 | 1 | 17
Elliott et al., 2000 ^96^ | 5 | 0 | 2 | 4 | 0 | 11
Stamp et al., 1995 ^94^ | 6 | 0 | 1 | 5 | 1 | 13
Zlotnick et al., 2001 ^97^ | 5 | 0 | 4 | 3 | 0 | 12
Screening during Postpartum Period
Armstrong et al., 1999 ^98^ | 9 | 1 | 5 | 3 | 1 | 19
Brisco et al., 1989 ^93^ | 6 | 1 | 4 | 3 | 0 | 14
Chabrol et al., 2002 ^99^ | 8 | 0 | 2 | 5 | 0 | 15
Chen et al., 2000 ^100^ | 8 | 0 | 3 | 3 | 0 | 14
Dennis, 2003 ^101^ | 9 | 2 | 5 | 6 | 0 | 22
Fleming et al., 1992 ^102^ | 6 | 0 | 3 | 2 | 0 | 11
Hiscock and Wake, 2002 ^103^ | 7 | 1 | 5 | 5 | 1 | 19
Honey et al., 2002 ^104^ | 9 | 0 | 3 | 4 | 0 | 16
Horowitz et al., 2001 ^105^ | 7 | 0 | 4 | 3 | 1 | 15
Onozawa et al., 2001 ^106^ | 10 | 0 | 3 | 3 | 0 | 16
Wisner and Wheeler, 1994 ^107^ | 8 | 0 | 3 | 1 | 0 | 12
Wisner et al., 2001 ^108^ | 7 | 0 | 6 | 4 | 1 | 18

Note: Maximum possible score in parentheses.

Table 19. Major outcomes of studies of screening and interventions for perinatal depression

Author, Year | Type of Intervention | Outcome Measures | Significant Differences between Intervention and Control Group
Screening during Pregnancy
Brugha et al., 2000 ^95^ | Structured group prenatal preparation classes | GHQ-D | No significant differences on any measure
| | EPDS
| | SCAN
Elliott et al., 2000 ^96^ | Structured group prenatal preparation classes | EPDS | Intervention group had significantly lower EPDS scores in first time mothers; no significant difference on PSE for diagnosis of major depression
| | PSE
Stamp et al., 1995 ^94^ | Perinatal support group | EPDS | No significant differences on this measure
Zlotnick et al., 2001 ^97^ | Four prenatal therapy/skills groups | BDI | Intervention group had a significantly greater change over time; at follow-up, intervention group had a significantly lower level of maternal depression
| | SCID
Screening during Postpartum Period
Armstrong et al., 1999 ^98^ | Regular home visits by child health nurses | EPDS | For secondary outcomes, intervention group had significantly lower depression scores and a positive effect on parent-infant interaction
| | PSI
| | Child health
| | HOME
Chabrol et al., 2002 ^99^ | One CBT-based prevention group during the PP hospitalization, followed by an at- home CBT- based program in women with major depression | EPDS | Intervention group had significant reductions in frequency of depressive symptoms
| | HAM-D
| | BDI
Chen et al., 2000 ^100^ | Four weekly PP support group sessions | BDI | Intervention group had significant lower rates of depression and rates of perceived stress and more interpersonal support
| | PSS
| | ISEL
Dennis, 2003 ^101^ | Telephone-based peer support | EPDS | Intervention group had significantly lower EPDS scores
Fleming et al., 1992 ^102^ | PP social support group | EPDS | No significant differences on any measure
| | CES
Hiscock et al., 2002 ^103^ | Infant sleep intervention (controlled crying) group | EPDS | Intervention group members with higher depression scores at baseline had significantly greater improvement in EPDS scores and reported improvements in sleep quality
| | Maternal and infant sleep quality
| | Maternal stress
Honey et al., 2002 ^104^ | Psycho-educational group | EPDS | Intervention group had significant reductions in depressive symptoms
Horowitz et al., 2001 ^105^ | Coached behavioral intervention to promote maternal-baby responsiveness | BDI-II | No significant differences for maternal depression; intervention group showed significantly better mother-infant responsiveness
| | DMC
Onazawa et al., 2001 ^106^ | Infant massage classes plus support group | EPDS | No significant differences for maternal depression; intervention group showed significant improvements in mother-infant interaction
| | Videotape of mother-infant interaction
Wisner and Wheeler, 1994 ^107^ | Antidepressant (nortriptyline) | Clinical interview | Intervention group had significantly lower proportion of new episodes of major depression
| | IDD
Wisner et al., 2001 ^108^ | Antidepressant (nortriptyline) | RDC | No significant differences in the rate of recurrence
| | HAM-D

BDI, Beck Depression Inventory; CBT, cognitive behavioral therapy; CES, Current Experience Scale; DMC, Dyadic Mutuality Code; EPDS, Edinburgh Perinatal Depression Scale; GHQ-D, General Health Questionnaire-Depression Subscale; HAM-D,Hamilton Depression Rating Scale; HOME, Home Observation for Measurement of the Environment; IDD, Inventory to Diagnose Depression; ISEL, Interpersonal Support Evaluation List; PSI, Parenting Stress Index; PSE, Present State Examination; PSS, Perceived Stress Scale; RDC, Research Diagnostic Criteria; SCAN, Schedule for Clinical Assessment in Neuropsychiatry; SCID, Structured Clinical Interview for Diagnosis.

The types and frequency of screening measures and the types of interventions applied varied appreciably among the studies we reviewed. Of the 15 studies retained for the full study, 4 examined intervention efforts for which screening had been done in the prenatal period; and 11 studies examined screening and interventions in the postpartum period. The remainder of this section reports on the studies in these two main categories.

### Prenatal Studies

Of the four studies examining screening, interventions, and outcomes in the prenatal period, ^94–97^ three were RCTs ^94,^ ^95,^ ^97^ and one was a nonrandomized controlled trial. ^96^ All four studies (published between 1995 and 2001) were set in prenatal clinics. Sample sizes for screening ranged from 37 to 209, for a total population of 473 women. The types of screening instruments used to identify patients with depressive symptoms differed among these studies; similarly, the outcome measures differed, although three studies used the Edinburgh Postnatal Depression Scale (EPDS) as one measure. All four studies implemented some type of psychological intervention, generally characterized as group classes or sessions relating to prenatal preparation, skills, and perinatal support. One study was considered fair; the other three were poor.

Brugha et al. screened 209 women with a modified General Health Questionnaire Depression Score (GHQ-D) to study the effect of six weekly prenatal group therapy classes called “Preparing for Parenthood” compared to routine prenatal care. ^95^ In this study, which we graded as fair, the program aimed to increase social support and problem-solving skills. Outcome measures that assessed maternal mood and depressive symptoms at 3 months postpartum included the GHQ-D (cutoff ≥ 2), the EPDS (cutoff score of > 11), and a Schedule for Clinical Assessment in Neuropsychiatry (SCAN, related to the International Classification of Diseases [ICD], version 10). Assignment to the intervention group did not significantly improve postpartum depression. On the GHQ-D, 26 percent of the intervention group and 22 percent of the control group scored at or above 2, with an adjusted odds ratio of 1.19 (95% confidence interval [CI], 0.59 to 2.37). On the EPDS, 16 percent of the intervention group and 19 percent of the control group scored above 11 ( an adjusted odds ratio of 0.83 (95% CI, 0.39 to 1.79).

In the earliest study we included in this group (1995), Stamp et al. used a study-specific, modified prenatal questionnaire as a screening instrument and assigned 129 patients to either two prenatal group classes plus one postpartum class (at 6 weeks) or routine care. ^94^ Outcome measures were the EPDS at 6 weeks and 6 months postpartum, using a cutoff point of > 12 for major depression and > 9 for major or minor depression. The intervention did not significantly reduce rates of postpartum depression on either measure. For example, at 6 weeks, 13 percent of the intervention group and 17 percent of the control group had EPDS scores greater than 12; at 6 months, the figures were 15 percent and 10 percent, respectively.

Elliott et al. screened 98 women with the Leverton Questionnaire and the depression, anxiety, and somatic subscales of the Crown Crisp Experiential Index. ^96^ The authors studied a preventive group of psychosocial intervention versus routine care; they also looked at differences between first-and second-time mothers. The structured group intervention was conducted once per month for 5 months during the prenatal period (starting at 24 weeks) and for 6 months postpartum. Outcome measures included the EPDS and the Present State Examination (PSE), as well as a self-rating questionnaire, at 3 and 12 months postpartum. For first-time mothers, the median EPDS score was significantly lower in the intervention group (Mann-Whitney one-tailed test, P = 0.005); for second-time mothers, the median EPDS did not differ significantly between the two groups. The PSE served as a formal diagnosis of depression, and the investigators reported no significant differences in diagnosis of major depression. When the authors included cases of borderline depression or “minor depression” in the analysis, first-time mothers in the intervention group were significantly less likely to have a diagnosis of depression than controls (19 percent and 39 percent, respectively, Chi-square = 2.64, one-tailed test, P < 0.05). PSE scores did not differ significantly between groups in second-time mothers.

In the only study in this category done in the United States, Zlotnick et al. used the Beck Depression Inventory (BDI) and a Diagnostic and Statistical Manual (DSM-IV) Structured Clinical Interview for Depression (SCID) as a positive screen among women of low socioeconomic status (SES). ^97^ They excluded patients who met criteria for a current episode of major depression based on the SCID. A total of 37 patients with a positive screen were assigned to either a four-session Interpersonal-Therapy-Oriented Group (given weekly) or to a usual-care group. Outcome measures included the BDI before and after the intervention and the SCID at 3 months postpartum. Women in the intervention group had a significantly greater change in their BDI scores from baseline than did those in the control group (“pre” versus “post” intervention Beck scores were 13.0 and 8.4, respectively, for the treatment group). In contrast, the control group “pre” versus “post” intervention scores were 9.2 and 11.3, respectively, suggesting that they got worse over time. The change between the intervention and the control group was significant (t-test = 3.50; df = 33; P = 0.001). In addition, women in the intervention group had a significantly decreased rate of major depression during the postpartum period as measured by the SCID at 3 months postpartum; no women in the intervention group and 33 percent of women in the usual-care group developed postpartum depression (P > 0.02).

These four small studies of programs for women identified by screening prenatally did not, collectively, produce many positive results from the various psychosocial interventions as compared with usual care. All of these studies scored poor on external validity (0 of 3 points), and two of the four had 0 of 2 points for power. The four studies did, at best, only a fair job of reporting data (from 5 to 7 of 11 points). For bias, the study scores ranged from 1 to 4 of 7 possible points; for confounding, they ranged from 3 to 5 of 6 points. Given the heterogeneity in populations, the screening instruments and cutoff points for defining “at-risk” individuals, the interventions themselves, and the outcome measures used, we cannot draw any overall conclusions about the utility of such programs.

### Postpartum Studies

Of the 11 studies examining screening and intervention outcomes only in the postpartum period, ^98–108^ eight were RCTs published between 1992 and 2003, ^98,^ ^100,^ ^101,^ ^103–106,^ ^108^ and three were controlled trials published between 1992 and 2002. ^99,^ ^102,^ ^107^ Sample sizes ranged from 23 to 1, 215, for a total population of 4,289 women.

As with the prenatal screening studies, the screening instruments used to identify patients with depressive symptoms differed among the postnatal studies, although the EPDS was used in the majority of studies and two studies by the same investigator team used “prior history of postpartum depression.” The treatment interventions also differed considerablyNine of these studies involved various behavioral and psycho-educational programs or other innovative activities (e.g., infant massage or infant sleep interventions); two involved tests of antidepressants. Unlike the prenatal studies, the settings varied from postpartum hospital wards to child-health and immunization clinics. Finally, the outcome measures also varied across these studies, but the EPDS was most commonly used (in seven studies). We graded one study good, seven fair, and three poor.

Behavioral and Psychosocial Interventions. Of the nine studies in this subgroup, one was conducted in the United States; the remainder were in Australia (two studies), Canada (two studies), the United Kingdom (not otherwise specified, two studies), and France and Taiwan (one study each). Using “number randomized or enrolled” as the metric, the sample sizes ranged from 45 to 859. We describe the studies below according to quality grade and sample size.

In a recent study rated good that randomized participants for the intervention (not screening), Dennis et al. screened 501 women recruited from child immunization clinics between 8 and 12 weeks postpartum. ^101^ Inclusion criteria included the mother's being at least 18 years of age, having a singleton birth, and delivering a full-term infant. Women were screened using the EPDS (cutoff score > 9). The 44 women with a positive screen were randomized to a “mother-to-mother” peer support telephone intervention or to routine care. The outcome measures were the EPDS at 4 and 8 weeks after randomization. The women in the intervention group had significantly lower EPDS scores than those in the control group: 15 percent of the intervention group and 52.4 percent of the control group had an EPDS > 12 at 8 weeks (P = 0.02).

In the largest of the seven studies rated fair, Chabrol et al. screened 859 women and identified 258 who were at risk based on an EPDS > 9 on day 2 or 3 postpartum. ^99^ They assigned these 258 women randomly to receive a cognitive behavioral therapy (CBT) (n = 130) intervention or to routine care (n = 128) during the postpartum hospitalization. CBT is a form of psychotherapy that actively examines how cognitions influence emotions or affect and involves active exploration, clarification, and testing of the patient's perceptions and beliefs. ^109^ Outcome measures for the prevention intervention included the EPDS (cutoff ≥ 11) taken at 4 to 6 weeks postpartum.

Women in the CBT group who continued to have positive screens on the EPDS (defined as EPDS score ≥ 11) at 4 to 6 weeks were assessed for major depression in a clinical interview using the Mini-Neuropsychiatric Interview (MINI) and DSM-IV criteria. Those with major depression were offered an at-home CBT program for five to eight additional sessions. These women were then compared with women with probable major depression in the control group at 10 to 12 weeks using the EPDS, Hamilton Depression Rating Scale (HAM-D), and the BDI. Women in the control group received one initial home visit assessment but then received only weekly telephone checks.

The study results demonstrated that women in the prevention intervention group had significant reductions in the frequency of depressive symptoms. At 4 to 6 weeks postpartum, 30.2 percent of those in the CBT group versus 48.2 percent in the control group (P = 0.0067) were still depressed (based on an EPDS score of ≥ 11). Additionally, the intensity of depressive symptoms measured by the mean score on the EPDS was significantly lower in the prevention group than in the control group: mean EPDS scores, respectively, of 8.5 (standard deviation [SD] 4) and 10.3 (SD 4.4) (t-test = 3.06, df = 209, P = 0.0024); the analyses indicate a medium effect size (ES, 0.42). At 10 to 12 weeks postpartum after completion of the home-based CBT intervention, women in the intervention group had significantly lower scores on all measures of depressive symptoms (HAM-D, BDI, EPDS) than did those in the control group. Specifically, the intervention and the control group mean scores were as follows: HAM-D, 5.7 versus 16.2 (t-test = 8.4, P < 0.0001); BDI, 4.7 versus 15.7 (t-test = 9, P < 0.0001); and EPDS, 5.9 versus 13.7 (t-test = 7.7; P < 0.0001).

Armstrong et al. screened 181 women with good literacy skills in the immediate postpartum period by asking about a history of trauma or abuse or a positive screen for adverse family characteristics on the Brisbane Evaluation of Needs Questionnaire. ^98^ Women were randomized to receive 6 months of home visits by a child-health nurse or routine primary care. Primary outcome measures involved measures of child health;, parental and family functioning (measured by the EPDS [cutoff > 12] and the Parenting Stress Index [PSI]), quality of the home environment (HOME assessment), and satisfaction with community services. All assessments were administered immediately postpartum.

If we focus primarily on scores of maternal depression and functioning at 6 weeks postpartum, women in the intervention group had significantly lower depression scores than the control group: 5.8 percent in the intervention group and 20.7 percent in the control group (P = 0.003) with EPDS > 12. Additionally, women in the intervention group had significantly lower (better) PSI scores at 6 weeks than controls (15.3 versus 38.4, P < 0.001). The investigators also reported that the total HOME score differed significantly between groups: 28.34 for the intervention group versus 25.51 for the control group (P < 0.001), providing evidence for the positive effect the intervention had on influencing parent-infant interaction and the home environment for the child.

Hiscock and Wake recruited 155 women from a child-health center at 7 to 8 months postpartum and screened with the EPDS (cutoff > 12). ^103^ Other inclusion criteria included reported child sleep problems. Of these women, 99 were considered depressed (baseline EPDS ≥ 10) and randomly assigned to either an infant sleep intervention group or a usual-care group. The infant sleep intervention comprised three private sessions (one session every 2 weeks) held at the local child-health center where sleep management plans were discussed, including an emphasis on controlled crying (where parents responded to their infants' crying at increasing time intervals, allowing the infant to fall asleep unaided). At the 10- to 12-month follow-up assessment, outcome measures included the EPDS, measures of sleep quality, and measures of maternal stress and coping.

The results of this study were mixed. Women who began with higher (worse) scores of depression at baseline had a significantly greater improvement in their EPDS scores than did those in the control group. At the 10-month follow-up, women in the intervention group had a 6.0 point decrease (95% CI, 7.5 to 4.0) in EPDS score compared to a 3.7 point decrease (95% CI, 4.9 to 2.6) in the control group (P = 0.01). At the 12-month follow-up visit, the intervention group had a 6.5 point decrease (95% CI, 7.9 to 5.1) in EPDS score compared to a 4.2 point decrease (95% CI, 5.9 to 2.5) in the control group (P = 0.04). Also, at the 10-month follow-up, women in the intervention group reported improvements in their own sleep quality, including being more likely than control mothers to rate their own sleep quality as “very good” and less likely to rate it as “very bad” (Chi square = 9.93; P = 0.02). They also reported having “enough sleep” and were less likely to have “not enough” sleep (Chi square = 8.11, P = 0.04).

Horowitz et al. screened 1,215 women at 2 to 4 weeks postpartum with the EPDS (cutoff > 10). Women with positive screens (n = 122) were randomly assigned to either an interactive coaching intervention or a control group. The coached behavioral intervention was designed to promote maternal-infant responsiveness. All women in the study (both intervention and control groups) received three home visits when their infants were 4 to 8 weeks, 10 to 14 weeks, and 14 to 18 weeks of age; the women in the intervention group practiced the coaching intervention during these visits. Outcome measures included the BDI-II for maternal depression and, secondarily, the Dyadic Mutuality Code (DMC), a measure of the level of responsiveness in the maternal-infant relationship. Responsiveness was defined as “the mother's ability to accommodate to her infant's behavior and to give it meaning through regulation of her own behavioral responses” (p. 326). The intervention and control groups did not differ significantly in terms of maternal depression scores (BDI-II) at any time period. The DMC showed a significantly better outcome for mother-infant responsiveness for the treatment group (P = 0.06).

Onozawa et al. screened 581 primiparous women with the EPDS (cutoff ≥ 13) at 4 weeks postpartum. ^106^ Of 91 women who had a positive screen, 59 agreed to participate in the study. Participants were randomized to either a 5-week infant massage class with a support group or the support group only. The 1-hour infant massage class (approved by the International Association of Infant Massage) taught parents the techniques of infant massage by encouraging parents to observe and respond to their infants' body language and cues and to adjust their touch accordingly. Outcome measures included maternal depression on the EPDS (cutoff ≥ 13) at 4 weeks and 2 months postpartum and a videotaped mother-infant interaction that assessed the mother's attitude toward the infant, the infant's response to the mother, and the overall quality of the interaction. At 14 weeks postpartum, EPDS scores had fallen for both groups (reported as a change in median EPDS score from baseline to final visit), but the intervention group demonstrated a significantly greater change in scores than did the control group (intervention group baseline of 15.0 and final visit score of 5.0, versus the control group score of 16.0 at baseline to 10.0 at the final visit; P = 0.03). Additionally, significant improvements in all aspects of mother-infant interaction as measured by the videotape were seen only in the massage group (P = 0.0004).

Honey et al. used the EPDS (cutoff > 12) to screen postpartum women recruited through mother-baby clinics but assessed at home. ^104^ The 45 women with a positive screen on the EPDS were randomly assigned to either an 8-week psycho-educational group (PEG) or to a routine care group. Outcome measures included the EPDS (cutoff > 12) after completion of the PEG and at a 6-month follow-up. At the end of the 8-week assessment interval, the women in the PEG did not differ significantly from those in the routine-care group. By contrast, at the 6-month follow-up assessment, the percentage of women scoring below the EPDS cutoff for a probable major depressive episode was significantly higher in the PEG group than in the routine-care group (65 percent versus 36 percent, Chi square = 3.75; P ≤ 0.05). An additional analysis demonstrated that the use of antidepressant medication during the study had no impact on the improvement in mood observed at the 6-month follow-up assessment.

Fleming et al. screened 781 primiparous women with full-term deliveries and no psychiatric history during their first 2 weeks postpartum using the EPDS (cutoff ≥ 13), the Current Experience Scale (CES, cutoff ≥ 35), and the Multiple Affect Adjective Checklist (MAACL, cutoff ≥ 21). ^102^ Women with a positive screen (n = 142) were assigned (not randomly) to either a postpartum social support group that included both depressed and nondepressed women or a usual-care group.

Outcome measures included the EPDS and the CES at the same cutoff scores used for screening. At the 6-week and 5-month follow-up assessments, the groups did not differ significantly with respect to rates of maternal depression, and the support groups had no apparent effect on the mothers' general affective mood. However, women in the social support group had a statistically significant increase in the number of maternal-infant interactions and noted decreased infant crying compared to women in the routine-care group.

Chen et al. screened 414 women at 3 weeks postpartum using the Taiwanese BDI (cutoff ≥ 10). ^100^ Of these, 115 women with positive screens were randomized to weekly support groups or to a routine-care group; 60 patients were available for analysis. Outcome measures included the BDI (cutoff ≥ 10), Perceived Stress Scale (PSS), and measures of interpersonal support. At the 15-week follow-up assessment, women in the intervention group had significantly lower rates of depression: 33.3 percent of the intervention group and 60.0 percent of the control group had BDI values equal to or greater than 10 (P < 0.05). The rate of perceived stress was also significantly lower in the intervention group than the control group (t-test = 3.75, P < 0.01). Finally, women receiving the intervention reported significantly more interpersonal support as measured by the Interpersonal Support Evaluation List than those in the control group (t-test = 2.81, P < 0.01).

Pharmacologic Studies. Two of the studies were psychotropic medication trials to prevent the occurrence of postpartum depression. The women were not directly screened with any instrument, but rather were included if they had a previous history of postpartum depression. The same research team conducted both of these pharmacologic trials. In the first trial, Wisner and Wheeler studied the efficacy of antidepressant treatment in women with a previous history of postpartum depression (i.e., at high risk of maternal depression but no history of psychosis or bipolar disorder). ^107^ At-risk postpartum women (n = 23), who had had at least one episode of postpartum depression were treated in an open clinical trial with the tricyclic antidepressant nortriptyline and postpartum monitoring or with postpartum monitoring only. Outcome measures included a clinical assessment of major depression and the Inventory to Diagnose Depression scale. After 3 months, study results demonstrated a significantly greater proportion of new-episode major depression in those patients who received monitoring alone than in those in the medication group (62.5 percent of those in the monitoring group; 6.7 percent in the medication group; P = 0.0086).

In a later Wisner et al. RCT, 56 women with a prior history of postpartum depression within the past 5 years but no depressive episode upon enrollment, as diagnosed by standardized research diagnostic criteria, were randomized to either a nortriptyline group or a placebo group immediately postpartum. ^108^ Outcome measures of recurrence of perinatal depression included the HAM-D and Research Diagnostic Criteria (RDC). In contrast to the earlier open-label trial, the investigators reported no difference in the rate of recurrence of depression (one-fourth) between women treated with nortriptyline and those receiving placebo (23 percent versus 24 percent, respectively).

None of the studies used treatment interventions that are recognized as the gold standard treatment for major depressive illness according to current American Psychiatric Association guidelines. These guidelines specify that the gold standard include antidepressant medication plus psychotherapy. ^12^ .

The overall quality of these 11 postpartum studies was fair; one study was rated good; two, poor. Of a possible quality score of 29, one study scored 22, seven scored between 15 and 20, and two at or below 14 (Table 18). External validity was generally poor; the majority of studies scored 0 of 3 points. The bias measure of internal validity ranged between scores of 1 and 6 (of a possible 7); 6 of 11 studies scored 4 or better. For confounding, scores ranged from 1 to 6 (of a possible 6); 6 of 11 studies scored 4 or better. Power was generally poor, reflecting the small sample sizes; 9 of 11 studies scored 0 (of a possible 2).

Only three studies had quality scores of 18 or higher: Wisner et al., ^108^ Armstrong et al., ^98^ and Dennis et al. ^101^ All three enrolled women in the postpartum period and had a fairly intensive treatment approach consisting of weekly interventions (Wisner et al. for 20 weeks, Dennis et al. for 8 weeks, and Armstrong et al. for 6 weeks). The Wisner et al. study had a pharmacologic intervention with weekly assessments of efficacy but no psychotherapeutic intervention; by contrast, the Dennis et al. and Armstrong et al. studies had weekly psychotherapeutic interventions but no pharmacologic intervention. Interestingly, although Wisner et al. treated patients for 20 weeks postpartum with antidepressant medication, their study did not have a significant result. This finding may suggest that psychosocial support and psychotherapeutic intervention are both critical as part of a treatment plan for women with postpartum depression.

## Discussion

### Conclusions

The 15 studies examined a variety of screening and treatment interventions for women identified as being at risk (sometimes at high risk) for postpartum depression. The majority of these studies focused on intervention strategies in the postpartum period; all but two dealt with a wide array of psychosocial, education, skill-building, and other mother-child behavioral activities. Generally, the more successful efforts occurred in the studies in which screening and interventions were carried out in the postpartum, not the prenatal, period. Once again, none of the studies had a treatment intervention with both psychotherapeutic and pharmacologic components that would be considered “gold standard therapy” for the treatment of major depression.

Overall, many of the studies suggest that providing the mother with some form of psychosocial program to increase maternal support or improve maternal-child interaction may decrease the rate of postpartum depression. Across the nine nonpharmacologic studies, about 20 outcomes were assessed; of these, 12 showed significant effects for the intervention group. Taking only the outcomes dealing specifically with depression, nine significant effects were reported. The two small pharmacologic trials from the same group yielded conflicting results about the impact of nortriptyline in reducing recurrence of maternal depression.

Only one study ^97^ specifically studied low SES women—a matter of some interest to the Safe Motherhood Group. Low SES women with at least one risk factor for postpartum depression who participated in weekly prenatal survival skills classes were less likely to develop postpartum depression compared to controls. This small study suggested that increasing support and parenting skills may help to decrease postpartum depression in this particular population.

### Study Limitations

This set of studies, however, has several limitations, and it can be regarded as offering, at best, only fair evidence about the utility of screening plus prevention or treatment programs or even interventions alone. Although a variety of interventions may be helpful in treating women with or at risk of perinatal depression, the available evidence does not directly address whether screening with subsequent intervention improves outcomes. Screening, in the classic sense, implies “examination of a group of usually asymptomatic individuals to detect those with a high probability of having a given disease” (italics added; http://dictionary.reference.com/search?q=screening); this meaning can be extended to using appropriate screening or diagnostic tools within populations with known risk factors. These studies provide little guidance in answering the practical question of whether clinicians should screen all women in the perinatal period (i.e., essentially an asymptomatic population with respect to depression) for risk factors or latent depression, or whether they should screen only women who have known prior histories or risk factors for depression.

The studies are generally small, with poor generalizability (especially to the heterogeneous childbearing population of the United States). We contemplated and rejected the idea of any quantitative analyses: populations, settings, and screening and outcome measures—let alone interventions—were simply too disparate for anything but qualitative synthesis.

### Future Research

To overcome some of these problems in understanding the impact of programs designed to prevent the problems of perinatal depression or to mitigate the considerable deleterious effects of this disorder on mothers, infants, and families, considerably more and better research needs to be conducted. Possibly the most important issue is for future studies to enroll adequate samples of women and, if screening is the question, to screen quite large numbers of women to produce sample sizes with adequate power to detect relevant differences between treatment and control groups in later phases of these studies. Virtually all studies appeared to be underpowered to start with, and some lost participants along the way. This deficiency hampers investigators and policymakers in making sense of, or decisions based on, much of this work.

Moreover, a greater effort should be made, at least in US-based studies, to focus on ethnic and disadvantaged populations, such as low-income women. Even if the incidence and prevalence of perinatal depression were “evenly” spread over population groups in this country, the underfunding of health care for many (e.g., lack of insurance, poor coverage of mental health benefits in insurance plans, unavailability of publicly funded services) and the more precarious economic resources and family support for some populations means that additional attention needs to be paid to them. For example, programs may need to be designed to take lack of transportation, child care, or telephone access into account.

In addition, researchers might direct attention to several other variables that appear to be important. They include first-time versus second-time mothers, maternal comorbidities and lifestyle behaviors, family structure (make-up) and available support, and status of infant at birth (e.g., full term or not, healthy or not). Another gap may be programs intended to assist the mother-father dyad or, indeed, to assist fathers in providing the emotional or physical support needed to forestall depression in new mothers.

Ideally, researchers would employ similar screening measures with similar cutoff points so that some elements of separate studies could be compared more readily. Not all of the screening instruments used appear to be sufficiently well-targeted to perinatal depression (i.e., even if they are reliable, their validity for this purpose may be called into question). Moreover, some instruments may be relatively infeasible for use in certain populations (e.g., immigrants) or in cases in which patient self-report is important and literacy may be low. For these situations, some work to calibrate well-known instruments that have been specifically designed for this disorder and that have acceptable test properties against each other might be useful. Calibrating less well-known or well-proven instruments against some agreed-upon reference (“gold”) standard instrument in this area might also be valuable. Testing these in different settings, trying to use shorter instruments, attempting to take literacy levels into account, and in other ways improving the screening armamentarium are also important steps. In that way, investigators and clinicians can have a better selection of proven screening tools for future research or clinical practice applications.

Another element warranting more clarity is the purpose of the screening-cum-intervention effort. All appear to relate to populations of women at risk of perinatal depression (particularly postpartum depression that goes beyond “maternal blues”), but the severity level of being at risk differed in these studies. Moreover, women could have had no prior history of depression (or perinatal depression) and be at risk; alternatively, they could have had some history, especially of postpartum depression, and be, essentially, at “high” risk. These distinctions did not seem to be well or consistently described across these studies. They also have implications for the goals of the interventions themselves: for example, preventing any “first episode” of depression, mitigating the effects of a first episode that is not wholly prevented, or preventing a recurrence.

Interventions tested in the future would, ideally, be those shown to have some promise so far (e.g., as reflected in some of the studies reported here). The components of the programs should be of appropriate length and intensity, and published articles should describe them thoroughly. In addition, interventions should be consistent with current evidence-based practice standards for the treatment of major depression. Multiple studies of the same interventions, perhaps at different time periods or different settings and populations, might be helpful in completing the picture of the impact of screening and interventions on occurrence or reoccurrence of perinatal depression. Finally, outcome measures should be appropriate to the research questions and preferably selected from among the more reliable, valid, and widely used instruments. These steps might help fill the gaps in this knowledge base and permit those performing systematic reviews to compare and synthesize studies more readily.