# Screening Accuracy

## Introduction

Screening for perinatal depression is an important first step in identifying women who are at risk of having perinatal depression. It is only an initial step—after a positive screen, a depressive illness must be confirmed by a follow-up diagnostic examination and determination by a clinician.

To be useful screening tools, instruments must be able to identify accurately and reliably the illness in the population of interest; they also need to rule out, accurately, persons in the population who do not have the illness. Assessment of a screening test's accuracy depends on knowing whether a disease is truly present, i.e., comparison to a reference standard. This section addresses the second Key Question (KQ) from the Safe Motherhood Group (SMG) and the Agency for Healthcare Research and Quality (AHRQ): “What is the accuracy of different screening tools for detecting depression during pregnancy and during the postpartum period?”

The two most commonly used measures of accuracy are sensitivity and specificity. Sensitivity refers to the proportion of patients with a disease who test positive (“true positives”) using a screening tool. A sensitive test is one that is usually positive in the presence of disease. In general, a highly sensitive test should be selected when the consequence of missing a disease would be a clearly bad outcome. Screens with high sensitivity are most useful to clinicians when the result is negative; negative results can help rule out a disease.

Specificity refers to the proportion of patients without a disease who test negative (“true negatives”) using the screening tool. A specific test is one that is usually negative in the absence of disease. A highly specific test, then, should be selected when false-positive results can substantially harm the patient in some way. Screens with high specificity are most useful to the clinician when the result is positive; the positive result can rule in the disease.

Screening tools have varying sensitivities and specificities as a function of which cutoff point, or threshold, clinicians and others use. The optimal cutoff depends on prevalence of disease (as explored in Chapter 3), benefits and harm of therapy, and risks and costs of administering the screening test.

## Methods

Chapter 2 provides the detailed methods we used to search and review the literature on screening instrument accuracy. In this discussion, we elaborate on some of these methods.

### Inclusion and Exclusion Criteria

Studies to be retained had to report directly or to provide data allowing us to calculate our primary outcomes of interests—sensitivity and specificity. We required that the screening instrument be compared to a reference standard for a diagnosis of depression. Reference standards could be one of two types. The first includes a clinical assessment by a mental health professional based on criteria from the Diagnostic and Statistical Manual of Mental Disorders (DSM), the Research Diagnostic Criteria (RDC), the Bedford College Checklist, ^69^ or the International Classification of Diseases (ICD). The second involves a research-based diagnosis obtained by structured or semistructured clinical interview, such as the Structured Clinical Interview for Depression (SCID), the Diagnostic Interview Schedule (DIS), the Schedule for Affective Disorders and Schizophrenia (SADS), or Goldberg's Standardized Psychiatric Interview (SPI); each of these confirms a diagnosis based on one of the above systems of criteria.

Depressive illness can be either a major depressive disorder or a minor depression. The latter is understood to be an impairing, episodic depression with clear symptoms exceeding a normal state but without severity reaching the diagnostic criteria for major depressive disorder. For this chapter, we are concerned with the ability of screening tools to detect either major depression or minor depression in a given individual (because an individual can have only one or the other of these diagnoses), so the terminology intentionally differs from that used in Chapter 3.

We excluded studies that included patients with a known current depressive illness (for whom a screen would not provide new information). Furthermore, we excluded studies on women with bipolar disorder or a primary psychotic disorder and studies in which women with diagnosed depression could not be distinguished from women with maternity blues, a transient, subthreshold cluster of depressive symptoms commonly described in up to 50 percent of postpartum women.

### Data Analysis

Our main outcomes of interest were sensitivity and specificity of the screening approaches or instruments as described in the selected articles. When calculating outcomes ourselves or doing other analyses, we used Stata, version 8. For each reported instrument and associated cutoff, we calculated sensitivity and specificity from the published data. We constructed 95% confidence intervals (CIs) using exact methods. For instruments with three or more outcome values reported, we created plots of the sensitivity or specificity with associated 95% CIs to provide a graphic description of the degree of consistency of results. In addition, where possible we estimated pooled sensitivity and specificity values using meta-analytic methods for fixed effects. We evaluated heterogeneity using the Q statistic test for homogeneity. In several circumstances, pooled estimates were impossible to calculate because of perfect estimates of sensitivity (i.e., 100 percent) with associated variance estimates equal to 0.

### Evaluation of Quality and Strength of Evidence

We developed a quality rating form for these articles on screening accuracy from criteria identified by the Cochrane Methods Working Group on Systematic Review of Screening and Diagnostic Tests. ^25^ The quality rating forms, provided in Appendix B, rated reporting, external validity, and internal validity. The senior abstractor completed the quality rating form for each article; another project team member reviewed a sample of the completed forms for accuracy and completeness.

We rated retained studies on three separate categories of quality then summed the individual category scores for a total score. The domains and maximum points possible for each domain are as follows:

- Reporting (domain score of 10): Nine items covering study aims, description of depression assessment, potential confounders described, and instrument procedures described, each scored yes or no (1 or 0), except for an item concerning principal confounders that was scored yes, partially, or no (2, 1, or 0). We considered 0 to 3 as poor, 4 to 7 as fair, and 8 to 10 as good.
- External validity (domain score of 3): Three items relating to representativeness of populations from which people were recruited and of settings and clinicians that treat such patients, each scored yes or no (1 or 0). We considered 0 or 1 as poor, 2 as fair, and 3 as good.
- Internal validity (domain score of 8): Six items relating to both bias and confounding in the use of the screen and reference standard, each scored yes or no (1 or 0), except for an item assessing whether all screens were done independently on each person, all tests done on each person but not independently, or different tests done on different persons and not randomly allocated (2, 1, or 0, respectively). We considered 0 to 2 as poor, 3 to 5 as fair, and 6 to 8 as good.

The maximum total quality score was 21. We considered 0 to 7 as poor, 8 to 14 as fair, and 15 to 21 as good.

## Results

### Study Characteristics

Our literature review of screening tools for detecting depression during pregnancy and the postpartum period identified no relevant systematic reviews. We did find 23 studies meeting our inclusion criteria. Of these, 10 were studies involving screening instruments in English; ^32,^ ^46,^ ^70–77^ 13 involved non-English screening instruments. ^31,^ ^35,^ ^42,^ ^43,^ ^50,^ ^51,^ ^78–84^

The major characteristics of these studies are summarized in Table 13 and detailed in Evidence Table 3 (Appendix C). The studies represent a wide variety of countries. Of the 10 studies using an English-language screening instrument, two were conducted in US populations, ^32,^ ^71^ six were performed in the United Kingdom, ^46,^ ^70,^ ^73–76^ and one each was conducted in Canada ^77^ and Australia. ^72^ Of the 13 studies using a non-English screening instrument, four were conducted in Chinese, ^42,^ ^43,^ ^81,^ ^82^ three were in Japanese, ^50,^ ^51,^ ^80^ and one each was in German (Austria), ^83^ Swedish, ^84^ French, ^78^ Spanish (Spain), ^35^ Norwegian, ^31^ and English/Africaans. ^79^ We will focus on the screening instruments used in the English language, given their greater relevance to our population of interest.

Table 13. Major characteristics of studies of screening for perinatal depression

Author, Year | Place/Sample Size | Depression Type and Prevalence | Screening Method(s) and Cutoffs Used | Timing of Screenings | Criterion Standard
Prenatal Period
Murray and Cox, 1990 ^46^ | UK 100 | Major depression: 6% major or minor depression: 14% | EPDS: cutoffs vary from ≥ 11 to ≥ 15 | 28 to 34 weeks GA | SPI to obtain RDC diagnosis
Postpartum Period
Ballard et al., 1994 ^70^ | UK 200 | Major depression alone: 12% | EPDS: cutoff 13 | 6 months PP | PAS to obtain RDC diagnosis
Beck and Gable, 2001 ^71^ | US 150 | Major depression alone: 12% | PDSS ≥ 81 | Between 2nd and 12th week PP | SCID-DSM-IV for DSM-IV diagnosis
| | Major or minor depression: 19% | EPDS ≥ 13
| | | BDI-II ≥ 21
Boyce et al., 1993 ^72^ | Australia 103 | Major depression alone: 9% | EPDS ≥ 13 | ≤6 months PP | DIS to obtain DSM-III-R diagnosis
| | | GHQ: NR
| | | Pitt Scales: NR
Campbell and Cohn, 1991 ^32^ | US 1,007 | Major or minor depression: 9% | CES-D | 6 to 8 weeks after delivery | Modified SADS to obtain RDC diagnosis
Cox et al., 1996 ^73^ | UK 128 | Major depression alone: 6% | EPDS ≥ 13 (primarily) but also ≥ 10, ≥ 11, ≥ 12, ≥ 14, ≥ 15 | Not reported in relationship to time of birth | SPI to obtain RDC diagnosis
| | Major or minor depression: 16%
Harris et al., 1989 ^74^ | Wales 147 | Major depression alone: 15% | BDI: ≥ 11 | 6 to 8 weeks PP | Clinical examination for DSM-III criterion
| | | EPDS: ≥ 13
Leverton and Elliott, 2000 ^75^ | England 199 | Major or minor depression: | EPDS ≥ 13 | 3 months PP | PSE with 2 standards used: Bedford College and Catego diagnosis
| | Catego: 5%; Bedford: 8%
Murray and Carothers, 1990 ^76^ | England 646 | Not provided, but data suggest major depression alone: 6% | EPDS ≥ 13 | 6 weeks PP | SPI to obtain RDC diagnosis
| | Major or minor depression: 15%
Whiffen, 1988 ^77^ | Canada 120 | Major or minor depression: 18% | BDI ≥ 10 | 6 to 8 weeks PP | SADS to obtain RDC diagnosis

BDI, Beck Depression Inventory; CES-D, Center for Epidemiological Studies-Depression scale; DIS, Diagnostic Inventory Schedule; DSM-III-R, Diagnostic and Statistical Manual of Mental Disorders, third edition, revised; DSM-IV, Diagnostic and Statistical Manual of Mental Disorders, fourth edition; EPDS, Edinburgh Postnatal Depression Scale; GA, gestational age; GHQ, General Health Questionnaire; PAS, Psychiatric Assessment Schedule; PDSS, Postpartum Depression Screening Scale; PP, postpartum; PSE, Present State Examination; RDC, Research Diagnostic Criteria; SADS, Schedule for Affective Disorders and Schizophrenia; SCID, Structured Clinical Interview for DSM-III-R; SPI, Standardized Psychiatric Interview.

Unfortunately, the racial and ethnic mix of the study populations for the studies using English language screening instruments was poorly representative of the US population (our target of interest). Of the 10 studies, only the two studies conducted in the United States reported race and ethnicity. ^32,^ ^71^ These populations were overwhelmingly Caucasian; in by far the largest study, ^32^ 100 percent of the 1,007 women enrolled were white, and, in the other, 87 percent of the women were white. ^71^

When reported, the mean age of women in these studies ranged from approximately 24 to 31 years. Of these 10 studies, only one was conducted during pregnancy. ^46^ The remaining nine studies were conducted postpartum between 2 weeks and 6 months after delivery, with most occurring between weeks 8 and 12. Individual study sizes ranged from 103 to 1,007, with an aggregate sample size of 2,800.

Studies might use one or more screening tools; the selected articles evaluated four different screening tools.

### Screening Instruments Used

The key features of the four different types of screening instruments used are summarized in Table 14. Eight studies assessed the Edinburgh Postnatal Depression Scale (EPDS); seven of these used the 10-item version, ^46,^ ^71–76^ and one used a 13-item version. ^70^ The EPDS had been developed specifically for assessing postpartum depression and relies much less than standard depression screens on somatic, or physical, questions. In its most common form, it is a 10-item self-report screening scale for postpartum depression that is specifically aimed at exploring mood symptoms in the postpartum period. ^85^ Questions on the EPDS scale are framed within the “past seven days” and the response format is frequency-based. Each item is scored on a 4-point scale (0 to 3); the minimum and maximum scores are 0 and 30, respectively. It takes less than 5 minutes to administer. The responses to the 10 items are summed to obtain a score.

Table 14. Key features of screening instruments for perinatal depression

Screening Tool | Method of Administration | Number of Items | Score Ranges | Time to Complete | Time Frame Covered
EPDS | Self-administered | 10-item* | 0–30 | < 5 minutes | In the past 7 days
| | 13-item | 0–39
BDI^†^ | Interviewer- or self-administered | 21-item | 0–63 | 5–10 minutes | Last week including today
BDI-II^†^ | Interviewer- or self-administered | 21-item | 0–63 | 5–10 minutes | During the past 2 weeks
PDSS | Self-administered | 35-item | 35–175 | 5–10 minutes | Over the past 2 weeks
CES-D | Self-administered | 20-item | 0–80 | 1–2 minutes | Past 7 days

* The 10-item EPDS is more commonly administered than the 13-item version.

† BDI and BDI-II were originally designed to be administered by an interviewer but are most often self-reported. rating

Three studies assessed the Beck Depression Inventory (BDI). ^71,^ ^74,^ ^77^ The BDI is a list of 21 symptoms and attitudes that are each rated on intensity. ^86^ Versions include the BDI, which uses “last week, including today” as the time frame for symptoms; ^86^ the BDI-II, which uses 2 weeks as the time frame for symptoms; ^87^ and the BDI-PC, which also has a 2-week time frame. ^88^ The versions used most often (BDI or BDI-II) are scored by summing the ratings that respondents give to the 21 items. Although originally designed to be administered by trained interviewers, it is most often self-administered and takes 5 to 10 minutes to complete. This instrument has been used to measure severity of depression in depressed samples and also to assess depression in general population samples. Because of its reliance on somatic symptoms, some experts worry that it may produce higher scores and more false-positive results in pregnant women than in other respondents.

One study used the Postpartum Depression Screening Scale (PDSS). ^71^ The PDSS is a 35-item Likert-type self-report instrument created specifically for new mothers that can be administered in 5 to 10 minutes. Written at a third-grade reading level, PDSS items are brief and easy to understand. Mothers respond using a 5-point scale ranging from “strongly disagree” to “strongly agree.” The test yields an overall severity score falling into one of three ranges: normal adjustment, significant symptoms of postpartum depression, and positive screen for major postpartum depression. The PDSS also provides scores for seven symptom areas: Sleeping/Eating Disturbances, Anxiety/Insecurity, Emotional Lability, Mental Confusion, Loss of Self, Guilt/Shame, and Suicidal Thoughts.

Another study used the Center for Epidemiological Studies Depression Scale (CES-D). ^32^ The CES-D was designed to measure current level of depressive symptomatology and especially depressive affect. ^89^ The 20 items were chosen from five previously used depression scales to represent all major components of depressive symptomatology, and it was designed to apply to a general population. Each item is rated on 4-point scales indicating the degree of its occurrence during the past week. The scales range from “rarely or none of the time” to “most all of the time.” The scale can distinguish between clinical groups and general community groups. It takes approximately 5 to 10 minutes to complete; scoring takes about 1 to 2 minutes. Although it is usually scored continuously, various cutoff scores for clinical depression have reasonable associations with a clinical diagnosis. A cutoff score of 16 or higher has been suggested as a positive screen for depression. ^89^

### Reference Standards Used

Investigators used a variety of strategies to confirm the diagnosis of depression. Six studies used the RDC ^65^ for depressive illness as the reference standard but employed different instruments to identify patients meeting this standard. Three studies used the Standardized Psychiatric Interview, ^46,^ ^73,^ ^76^ two studies used a version of the Schedule for Affective Disorders and Schizophrenia, ^32,^ ^77^ and one study used the Psychiatric Assessment Schedule (an adaptation of the Present State Examination). ^70^

Other reference standards were also employed. Beck and Gable used the Structured Clinical Interview for DSM IV to confirm the diagnosis of depressive illness per DSM IV criteria; ^71^ Boyce et al. used the Diagnostic Interview Schedule, based on DSM III-R criteria, as the reference standard to confirm depressive illness; ^72^ Harris et al. used a clinical assessment of whether a patient's presentation met DSM III criteria for depressive illness; ^74^ and Leverton and Elliott used the Present State Examination to identify whether patients met depressive illness criteria by either the Bedford College Criteria or the Catego criteria (based on ICD-8 criteria). ^75^

### Classifications of Depressive Illness

Investigators classified depressive illness into one of two categories that reflected how perinatal depression is described in the scientific literature: major depression alone or major or minor depression. Patients identified as major depression alone met criteria for an episode of severe depressive illness according to the standardized criteria. In this report, we refer to major depressive episodes as major depression. For major depressive disorders, clearly effective interventions have been identified in clinical trials. Seven studies provided this classification. ^46,^ ^70–74,^ ^76^

The point prevalence for major depression alone was 6 percent in the single prenatal study, ^46^ somewhat higher than the 3.1 percent “best estimate” that we discussed in Chapter 3. For the postpartum studies, the point prevalence for the six studies reporting on major depression alone ranged from 6 percent to 15.5 percent; ^70–74,^ ^76^ this frequency is somewhat higher than the postpartum results from KQ 1 showing a best estimate prevalence between 1 and 3 months postpartum of 3.8 percent and 4.7 percent, respectively.

The major or minor depression category of depressive illness requires that patients meet diagnostic criteria for either a major depressive episode or a minor depressive episode. Minor depression is an impairing yet less severe constellation of depressive symptoms ^13^ for which controlled trials have not consistently indicated that particular interventions are more effective than placebo. ^14,^ ^15^ In this report, we refer to this grouping as major or minor depression, or by the more general terms of “depression” or “depressive illness.” Seven studies classified depression in this way. ^32,^ ^46,^ ^71,^ ^73,^ ^75–77^

In the single prenatal screening study, the point prevalence of major or minor depression in the third trimester (14 percent) was greater than our best estimate from KQ 1 for this time period (8.5 percent). ^73^ For the postpartum studies, prevalence rates ranged from 5 percent to 19 percent; these figures are somewhat higher than our best estimate range for point prevalence of 9.7 percent to 12.9 percent in the first 3 months postpartum. Given that this distinction substantially affects screening accuracy at a particular cutoff, we sort the results below by these two case definitions.

### Quality Rating

Table 15 documents the details of our grading of individual studies. For reporting completeness, we rated studies as fair; they averaged 6.1 of a possible 10 points. Three studies scored in the good range (8 or above). ^32,^ ^70,^ ^72^ For external validity, studies ranged from poor to good, averaging a poor-to-fair rating of 1.6 overall (of a possible 3 points), suggesting that at best they were a fair representation of each individual study's target population. Given that only two studies (Campbell and Cohn with an external validity score of 3 ^32^ and Beck and Gable with an external validity score of 1 ^71^ ) were conducted on US populations, the generalizability of these results to our target population appears limited. For internal validity, studies scored better, ranging from 4 to 8, with an overall average in the good range (7.0). Total scores for the three categories ranged from fair to good, with an overall average of 14.7 of a possible 21 points; of these 10 studies, six scored in the good overall quality range (15 or higher).

Table 15. Quality rating of studies of screening for perinatal depression

Author, Year | Reporting (10) | External Validity (3) | Internal Validity (8) | Total Score (21)
Studies with Screener in English
Prenatal Period
Murray and Cox, 1990 ^46^ | 5 | 3 | 8 | 16
Postpartum Period
Ballard et al., 1994 ^70^ | 9 | 1 | 8 | 18
Beck and Gable, 2001 ^71^ | 6 | 1 | 8 | 15
Boyce et al., 1993 ^72^ | 8 | 3 | 5 | 16
Campbell and Cox, 1991 ^32^ | 8 | 3 | 8 | 19
Cox et al., 1996 ^73^ | 5 | 0 | 8 | 13
Harris et al., 1989 ^74^ | 5 | 2 | 6 | 13
Leverton and Elliott, 2000 ^75^ | 5 | 0 | 7 | 12
Murray and Carothers, 1990 ^76^ | 4 | 3 | 8 | 15
Whiffen, 1988 ^77^ | 6 | 0 | 4 | 10
Average | 6.1 | 1.6 | 7.0 | 14.7

Note: Maximum possible score is shown in parentheses.

### Prenatal Screening Results

One English study of 100 subjects used the10-item EPDS to screen women in their third trimester of pregnancy (Table 13). ^46^ For major depressive disorder alone (n = 6 depressed patients), sensitivity and specificity point estimates at all cutoff points (12, 13, 14, 15) were quite good, although the sensitivity estimates were imprecise (as demonstrated by the wide CIs). At all cutoff points used, sensitivity was 100 percent, and each cutoff had a wide CI from 0.54 to 1.0 (Figure 14a). Specificity varied among the different cutoff points, with means varying from 0.79 (at a cutoff of 12) up to 0.96 (at a cutoff of 15), and all CIs were more precise, reflecting the larger number of subjects (n = 94) without major depression alone (Figure 14b). At the traditional postpartum cutoff of ≥ 13, sensitivity was 100 percent and specificity was 87 percent.

Figure 14a. Sensitivity of screening by Edinburgh Postnatal Depression Scale: prenatal period, major depression alone

Figure 14b. Specificity of Edinburgh Postnatal Depression Scale: prenatal period, major depression alone

As a screening instrument for major or minor depression (n = 14 depressed patients), overall test performance was worse. Sensitivity was much lower, ranging from 0.71 (at a cutoff of 11 or greater) to 0.57 (at a cutoff of 14 or greater), and CIs remained wide (Figure 15a). Specificity remained relatively good, varying from 0.72 (cutoff of 11 or greater) to 0.95 (cutoff of 14 or greater), with reasonable precision (Figure 15b). At the same ≥ 13 cutoff, sensitivity was 64 percent and specificity was 90 percent.

Figure 15a. Sensitivity of screening by Edinburgh Postnatal Depression Scale: prenatal period, major or minor depression

Figure 15b. Specificity of screening by Edinburgh Postnatal Depression Scale: prenatal period, major or minor depression

In summary, one prenatal screening study is of good quality. However, the inclusion of only six women with major depression substantially limits conclusions about the accuracy of prenatal depression screens. Indeed, the sensitivity results at 100 percent for each cutoff dramatically underscore the small number of depressed patients involved.

Results for major or minor depression from this one study are similarly limited. Only 14 depression cases are involved. Sensitivity and specificity estimates appeared to be lower than those for major depression alone. In particular, sensitivity estimates appeared worse than those for major depression alone, but again CIs are wide.

### Postpartum Screening Results

Nine studies provided sensitivity and specificity estimates in the postpartum period (Table 16). These studies used one of four screening instruments—EPDS, BDI, PDSS, and CES-D—at a variety of cutoff points. We review the results separately for each scale for major depression alone and for major or minor depression.

Table 16. Sensitivity and specificity of perinatal depression screens

Author, Year | Cutoff (≥) | Point Estimate for Sensitivity 95% CI | Point Estimate for Specificity 95% CI
Prenatal period
EPDS, Major depression
Murray and Cox, 1990 ^46^ | 15 | 1.0 | 0.96
| | 0.54–1.0 | 0.89–0.99
| 14 | 1.0 | 0.94
| | 0.54–1.0 | 0.87–0.98
| 13 | 1.0 | 0.87
| | 0.54–1.0 | 0.79–0.93
| 12 | 1.0 | 0.79
| | 0.54–1.0 | 0.69–0.86
EPDS, Major or minor depression
Murray and Cox, 1990 ^46^ | 14 | 0.57 | 0.95
| | 0.29–0.82 | 0.89–0.99
| 13 | 0.64 | 0.90
| | 0.35–0.87 | 0.81–0.95
| 12 | 0.64 | 0.80
| | 0.35–0.87 | 0.70–0.88
| 11 | 0.71 | 0.72
| | 0.42–0.92 | 0.61–0.81
Postpartum Period
EPDS, Major depression
Ballard et al., 1994 (13-item version) ^70^ | 13 | 0.96 | 0.70
| | 0.78–1.0 | 0.51–0.85
Harris et al., 1989 ^74^ | 13 | 0.95 | 0.93
| | 0.77–1.0 | 0.87–0.97
| 10 | 1.0 | 0.82
| | 0.85–1.0 | 0.73–0.89
Beck and Gable, 2001 ^71^ | 13 | 0.78 | 0.99
| | 0.52–0.94 | 0.96–1.0
Boyce et al., 1993 ^72^ | 13 | 1.0 | 0.96
| | 0.67–1.0 | 0.89–0.99
| 10 | 1.0 | 0.89
| | 0.66–1.0 | 0.81–0.95
Cox et al., 1996 ^73^ | 13 | 0.75 | 0.84
| | 0.35–0.97 | 0.76–0.90
| 12 | 0.88 | 0.76
| | 0.47–1.0 | 0.67–0.83
| 10 | 0.88 | 0.71
| | 0.47–1.0 | 062–0.79
EPDS, Major or minor depression
Cox et al., 1996 ^73^ | 13 | 0.62 | 0.89
| | 0.38–0.82 | 0.81–0.94
Cox et al., 1996 ^73^ | 12 | 0.76 | 0.81
| | 0.53–0.92 | 0.73–0.88
Cox et al., 1996 ^73^ | 10 | 0.81 | 0.77
| | 0.58–0.95 | 0.67–0.84
Beck and Gable, 2001 ^71^ | 10 | 0.59 | 0.86
| | 0.43–0.73 | 0.78–0.92
Leverton and Elliott, 2000 ^75^ (Bedford Criteria) | 13 | 0.44 | 0.92
| | 0.38–0.82 | 0.87–0.95
Leverton and Elliott, 2000 ^75^ | 10 | 0.69 | 0.85
| | 0.41–.89 | 0.79–.0.90
BDI, Major depression
Beck and Gable, 2001 ^71^ (BDI-II) | 21 | 0.56 | 1.0
| | 0.31–0.78 | 0.97–1.0
Harris et al., 1989 ^74^ (BDI) | 21 | 0.32 | 0.99
| | 0.13–0.57 | 0.95–1.0
| 13 | 0.63 | 0.92
| | 0.38–0.84 | 0.85–0.96
| 11 | 0.68 | 0.88
| | 0.43–0.87 | 0.82–0.94
BDI, Major or minor depression
Beck and Gable, 2001 ^71^ (BDI-II) | 15 | 0.57 | 0.97
| | 0.41–0.71 | 0.92–1.0
Whiffen, 1988 ^77^ (BDI) | 10 | 0.48 | 0.86
| | 0.26–0.70 | 0.78–0.92
PDSS, Major depression
Beck and Gable, 2001 ^71^ | 81 | 0.94 | 0.98
| | 0.73–1.0 | 0.94–1.0
PDSS, Major or minor depression
Beck and Gable, 2001 ^71^ | 61 | 0.91 | 0.72
| | 0.79–0.98 | 0.62–0.80
CES-D, Major or minor depression
Campbell and Cohn, 1991 ^32^ | 16 | 0.60 | 0.92
| | 0.50–0.70 | 0.90–0.93
| 21 | 0.43 | 0.97
| | 0.33–0.54 | 0.95–0.98

BDI, Beck Depression Inventory; CES-D, Center for Epidemiological Studies - Depression Scale; CI, confidence interval; EPDS, Edinburgh Postnatal Depression Scale; PDSS, Postpartum Depression Screening Scale.

Edinburgh Postnatal Depression Scale. The EPDS was the most common tool reported, involving 1,573 patients from eight studies; ^46,^ ^70–76^ 80 patients had major depression alone, and 83 patients had major or minor depression. Murray and Carothers reported test characteristics for both major depression alone and major and minor depression together (not in Table 16), but they did not give information allowing us to calculate CIs for the results; ^76^ we address their work separately.

Major Depression Alone. Figures 16a and 16b present the sensitivity and specificity estimates for the five studies reporting on major depression alone (a total of 927 patients). ^70–74^ We show data according to the version and cutoff point used. The sensitivity graphs show the number of depressed patients; the specificity graphs use the number of nondepressed patients.

Figure 16a. Sensitivity of screening by Edinburgh Postnatal Depression Scale: postpartum period, major depression alone

Figure 16b. Specificity of screening by Edinburgh Postnatal Depression Scale: postpartum period, major depression alone

For the Ballard et al. study employing the 13-item version (n = 23 depressed women), ^70^ we used only the cutoff of ≥ 13. Mean sensitivity was 0.96 and mean specificity was 0.70, with relatively wide CIs for both point estimates.

Results for the remaining four major depression alone studies are listed below the solid line in Figures 16a and 16b. ^71–74^ All used a cutoff point of 13. Sensitivities in these studies range from 0.75 to 1.0, with very wide CIs.

Specificities ranged from 0.84 to 0.99 and appeared to be more precise than sensitivities, as indicated by the much narrower CIs. Of note, results at this threshold from these individual studies of the 10-item screen indicated that sensitivities were similar to the value reported in the one 13-item screen study, but specificities were higher with the 10-item version.

We attempted to conduct a meta-analysis of the sensitivity results from the four studies using the cutoff point of 13 or greater. The Boyce et al. study ^72^ reported a sensitivity point estimate of 1.0, thus we were unable to generate a meaningful standard error; consequently, we could not include this result in the sensitivity meta-analysis. Leaving this study out, our meta-analysis produced a sensitivity point estimate of 0.91 (95% CI, 0.84 to 0.99); the test for heterogeneity was not significant (P= 0.141). We were able to include all four studies in our meta-analysis of specificity, but heterogeneity was significant (P < 0.001), precluding a pooled specificity estimate.

One study assessed a cutoff point of ≥ 12. ^73^ It reported a sensitivity of 0.88 (with a wide CI) and a specificity of 0.76 (with a narrow CI).

Three studies reported a cutoff of ≥ 10, all producing estimates with imprecise sensitivities yet relatively precise specificities. ^72–74^ Point estimates for sensitivity ranged from 0.88 ^73^ to 1.0. ^72,^ ^74^ Because two studies reported a perfect sensitivity of 1.0, we could not determine a pooled sensitivity estimate. Specificity ranged from 0.71 to 0.89, but heterogeneity was significant (P = 0.002), precluding a pooled estimate.

Major or Minor Depression. For major or minor depression (1,343 patients), four studies ^71,^ ^73,^ ^75,^ ^76^ reported test characteristics for the 10-item EPDS (Table 16). All but Murray and Carothers ^76^ allowed a calculation of confidence intervals and are presented in Figures 17a and 17b.

Figure 17a. Sensitivity of screening by Edinburgh Postnatal Depression Scale: postpartum period, major or minor depression

Figure 17b. Specificity of screening by Edinburgh Postnatal Depression Scale: postpartum period, major or minor depression

Two studies report a cutoff score of ≥ 13. ^73,^ ^75^ Sensitivities were low (0.62 ^73^ and 0.44 ^75^ ) and imprecise (wide CIs). Specificities were high (0.89 and 0.92, respectively) and quite precise. A meta-analysis at this cutoff produced a pooled sensitivity estimate of 0.54 (95% CI, 0.39 to 0.70) without significant heterogeneity (P = 0.266) and a pooled specificity estimate of 0.91 (95% CI, 0.88 to 0.94) without significant heterogeneity (P = 0.410).

One study reported a cutoff score of 12 or greater. ^73^ Relative to a threshold of 13 or more, this score appeared to improve sensitivity and decrease specificity, with the precision remaining unchanged.

Three studies reported results with a cutoff score of ≥ 10. ^71,^ ^73,^ ^75^ Reported sensitivities ranged from 0.59 to 0.81, and specificities ranged from 0.77 to 0.88. Again, sensitivity estimates were quite imprecise, whereas specificity estimates were quite precise. A meta-analysis of these results produced a pooled sensitivity estimate of 0.68 (95% CI, 0.58 to 0.78) without significant heterogeneity (P = 0.140). Specificities could not be pooled because of significant heterogeneity (P = 0.068).

Murray and Carothers reported sensitivities and specificities at various cutoff points as estimated by logistic regression analyses on results from 646 subjects; ^76^ they addressed both major depression alone and major or minor depression. Because we could not calculate CIs from their reported results, we do not show them in Table 16; their reported test characteristics are listed in Evidence Table 4 (Appendix C). For major depression alone, their sensitivity and specificity results mirrored the other studies' point estimates in Figures 16a and 16b. For major or minor depression, although specificities were similar to those of other studies, sensitivities were slightly higher than those reported in Figures 17a and 17b. For example, at a cutoff of ≥ 10, sensitivity was reported as 0.89; at a cutoff of ≥ 13, sensitivity was 0.68.

Beck Depression Index. Three studies involving the BDI (417 patients in all) reported lower sensitivity and slightly higher specificity than did the EPDS studies. ^71,^ ^74,^ ^77^ Two studies ^71,^ ^74^ reported results for major depression only using the BDI-II and BDI, respectively (Figures 18a and 18b). Using a cutoff of ≥ 21, Beck and Gable reported a sensitivity of 0.56 and a specificity of 1.0, ^71^ Harris et al. reported a sensitivity of 0.32 and a specificity of 0.99 at this cutoff. ^74^ Harris et al. also reported test characteristics for cutoff points of ≥ 13 and ≥ 11; ^74^ these cutoff scores each produced slightly higher sensitivity and slightly lower specificity than did a cutoff of 21. Relative to the EPDS for major depression alone, Beck and Gable results showed sensitivities that remained substantially lower and specificities that appeared to be slightly higher, although wide CIs preclude a confident comparison.

Figure 18a. Sensitivity of screening by BDI: postpartum period, major depression

Figure 18b. Specificity of screening by BDI: postpartum period, major depression alone

For major or minor depression, two articles reported BDI test characteristics using different thresholds. ^71,^ ^77^ Beck and Gable, ^71^ using a cutoff of ≥ 15 on the BDI-II, reported a sensitivity of 0.57 and a specificity of 0.97. The BDI study by Whiffen employed a cutoff of ≥ 10 and reported a sensitivity of 0.48 and a specificity of 0.86. ^77^

Postpartum Depression Screening Scale. One study of the PDSS (150 patients) reported high sensitivity (0.94) and high specificity (0.98) for major depressive disorder alone at a cutoff of ≥ 80. ^71^ The investigators also reported lower sensitivity (0.91) and lower specificity (0.72) for major or minor depression using a cutoff of ≥ 60.

Center for Epidemiological Studies - Depression Scale. One study of the CES-D (1,007 patients) used two cutoff points (≥ 21 and ≥ 16). ^32^ It reported low sensitivity (0.60 and 0.43, respectively) and high specificity (0.92 and 0.97, respectively) for major or minor depression.

### Summary of Results of Screening Instrument Review

The available evidence for both major depression alone and major or minor depression together is characterized by studies including markedly low numbers of depressed patients, a narrow racial and ethnic mix, varying cutoff points, and varying reference standards. These factors combine to preclude definitive conclusions or recommendations about screening instruments or thresholds.

Screening Instruments. For major depression alone, all screening instruments investigated (EPDS, BDI, PDSS) provided similarly high degrees of specificity at various cutoffs. Because of wide CIs, however, conclusions about sensitivity are more restricted. Heterogeneity among the studies limited our ability to synthesize these results quantitatively. In most instances, we could not obtain a more precise estimate. For an EPDS cutoff of ≥ 13 for patients with major depression alone, sensitivity estimates were combined in a meta-analysis to produce a point estimate of 0.91; however, heterogeneity precluded a meta-analysis for a specificity point estimate.

The EPDS and PDSS (with point estimates ranging from 0.75 to 1.0 at various cutoffs) appeared to be more sensitive than the BDI instruments (0.32 to 0.68 at various cutoffs), but the wide CIs overlapped nearly completely. A recent meta-analysis of prevalence estimates found that, compared with structured clinical interviews, the EPDS produced statistically equivalent prevalence estimates whereas the BDI produced significantly higher estimates. ^27^ Together, these findings suggest that a positive screen with EPDS may be more clinically useful than screens with the other instruments.

For major or minor depression, sensitivity point estimates for each tool at each cutoff were consistently lower than those for major depression alone, although specificities were quite similar to those for major depression alone. We were able to synthesize EPDS results quantitatively at a cutoff of ≥ 13, producing a sensitivity point estimate of 0.54 with a wide CI (95% CI, 0.39 to 0.70) and a specificity estimate of 0.91 with a narrow CI (95% CI, 0.88 to 0.94). At an EPDS cutoff of ≥ 10, we were able to produce a pooled sensitivity estimate of 0.68 (95% CI, 0.58 to 0.78), but heterogeneity precluded a pooled analysis for specificity.

In short, estimates of specificity are relatively precise, but estimates of sensitivity are imprecise. This pattern of results prevents any substantive conclusions about the accuracy of these tools for identifying true positives. This imprecision can be attributed to the consistently low number of patients with a depression diagnosis, a fact reflected by a number of studies reporting 100 percent sensitivity, and it is a major limitation of the currently available data. Because of this imprecision, we cannot meaningfully compare sensitivities of screening instruments.

Cutoff Points. For an individual screening instrument, we cannot make any substantive conclusions about the use of a particular cutoff point. As noted above, the wide CIs for sensitivity prevent one from confidently distinguishing one sensitivity result from another. However, two further guides that bear directly on the choice of a threshold need to be considered before a particular threshold could be suggested.

First, the relative cost, or value, of errors in screening tests (false-negative compared to false-positive results) needs to be clarified. False-negative results (miss true depression) can lead to bad outcomes such as continued morbidity, costs of unnecessary tests, and similar effects. By contrast, false-positive results (identifying depression when it is not there), can lead to unnecessary time, effort, and financial cost for diagnostic workup as well as potential side effects of a treatment that is not indicated. If false-negative and false-positive results are equally bad, then a screening test should try to minimize both equally to identify the most effective cutoff.

If missing depression in a patient is worse than falsely identifying depression in a patient (i.e., a false-negative classification is worse than a false-positive one), then one would want a test that maximizes sensitivity and has the highest negative predictive value. Said another way, the preferred test would be one in which the greatest proportion of those screening negative do not have the disease. By contrast, if falsely identifying a patient as having depression (a false positive) is worse, then one would want a test that maximizes specificity and has the highest positive predictive value. Clinical intuition suggests that missing a diagnosis is worse than making an incorrect diagnosis. We could find no literature addressing the trade-off of false-positive versus false-negative diagnoses in this clinical situation.

A second important guide in choosing a cutoff is the prevalence of a disease in a particular population. Regardless of test characteristics, in populations in which the prevalence of depression is relatively high, the number of false-negative results is higher; in populations in which the prevalence is relatively low, the number of false-positive results is higher. Therefore, the choice of a test and cutoff may differ depending on whether the population has a higher prevalence of depression (e.g., a high-risk postpartum clinic) or a lower prevalence (e.g., a healthy baby clinic). As a result, these three variables—sensitivity and specificity, the predictive value of screening errors (false positives versus false negatives), and the prevalence of the disease—must be clarified before clinicians or researchers can choose a specific test and related cutoff.

The above limitations notwithstanding, the tools we have reviewed above appear to be able to identify depressive illness in pregnant and postpartum women with a degree of accuracy similar to that for depression screen results in other nonpsychiatric settings. Screening results in primary care for a combined major or minor depression group are not available, but the results in primary care settings for major depression alone are similar to those reported for perinatal depression. For example, in a synthesis of depression case-identifying instruments in primary care settings using selection criteria similar to ours, Williams et al. reported a median sensitivity for major depression of 85 percent (range, 50 percent to 97 percent), and a median specificity of 74 percent (range, 51 percent to 98 percent). ^90^ This review included both women and men, which might explain the lower measures of accuracy; female gender appears to improve the accuracy of depression screens in primary care settings. ^91^

### Interpretation of Results

The small numbers of relevant articles limits our interpretation of the results. Given that most of the articles address the EPDS, we will use this instrument as an example. Because of the reports of 100 percent sensitivity in the prenatal tests of the EPDS (underscoring the very small number of prenatal depressed patients involved), we consider application of our results only to the postpartum population, and we draw on the prevalence data reported in Chapter 3 for KQ 1. We caution that, given the low numbers of depressed patients in the postpartum studies, the sensitivity estimates are likely to be inaccurate. Also, the majority of postpartum screens were performed 6 to 8 weeks after delivery, so the examples below apply only to that time period.

For major depression alone, the estimated point prevalence for the 6- to 8-week postpartum period is 6.8 percent, although the confidence interval around this estimate is wide. EPDS screens using the most commonly cited cutoff of 13 have a sensitivity of 91 percent and a specificity of approximately 95 percent. To illustrate this scenario, consider using this tool and cutoff for 1,000 patients. This EPDS screen would produce 62 true-positive cases and 6 false-negative cases, and 47 false-positive cases and 885 true-negative cases. The positive predictive value is 57 percent, meaning that the probability that a woman with a positive screen truly has major depressive disorder is slightly more than half. The negative predictive value (i.e., the probability that a woman with a negative screen would not have depressive illness) is 99 percent.

For major or minor depression, the estimated point prevalence from KQ 1 is 11.3 percent. EPDS screens tested for this population most commonly reported a cutoff of 10. This threshold at 6 to 8 weeks postpartum has a sensitivity of 68 percent and a specificity of approximately 80 percent. For 1,000 patients, the screen would produce 77 true-positive cases and 36 false-negative results, and 177 false-positive cases and 710 true-negative cases. The positive predictive value is 30 percent, and the negative predictive value is 95 percent.

## Discussion

### Conclusions

Very little is known about the accuracy of depression screening tests in pregnant and postpartum women. The available evidence is limited in several ways. It has a very narrow racial and ethnic mix. Study samples have prevalence rates of depression that are, by design, somewhat higher than our best estimate prevalence rates from KQ 1 (which would produce a higher positive predictive value). Most important, the available data involve small numbers of depressed patients. We could not address the limits of the small numbers of depressed patients using meta-analytic procedures. Case definitions, reference standards, screening tools, and screening thresholds all varied across the studies, and the heterogeneity of study methods constrained our ability to synthesize the data and obtain pooled estimates.

Despite these limitations, the available evidence does indicate that depression screens are feasible to administer in perinatal settings. It also suggests that the estimates of sensitivity and specificity, although limited, appear equivalent to those that have been reported in primary care settings. In particular, specificity is relatively good, suggesting a relatively good positive predictive value.

### Future Research

Further studies in this area need to standardize the above parameters we have examined in this chapter (instruments and, in particular, cutoff points), involve a more representative mix of racial and ethnic groups, test the screening tools in populations with a frequency of depression more reflective of the actual prevalence, and include a larger number of depressed patients to clarify the accuracy of depression screening tools and make them more relevant to the population of interest. Given the currently available evidence, we offer six future research recommendations.

First, subsequent studies on the test characteristics of screeners must be designed with sample size estimates that take into account prevalence and that project a reasonable width of sensitivity confidence intervals for the particular illness. For example, studies would need to screen 1,000 women to identify 34 with major depression or 110 with major or minor depression. This sample size might be enough for precise estimates for women with major or minor depression as a group, but it may not be enough for precise estimates for major depression alone.

Second, the sample should represent the target population. Specifically, subsequent studies need to provide a more representative racial and ethnic mix. In addition, studies should incorporate a range of other demographic variables that could influence screening performance, such as socioeconomic status measures, and assess the screening tools in these subpopulations.

Third, as in the Beck and Gable study, ^71^ subsequent studies should assess and directly compare multiple screening instruments. This design provides a head-to-head comparison that allows researchers and clinicians to understand which screening instruments are more accurate than others in different settings.

Fourth, studies evaluating both the risks and benefits of screening, specifically assessing the relative cost of false-negatives and false-positive results, will provide insights on how to consider target sensitivity and specificity when attempting to maximize cost-effectiveness.

Fifth, subsequent depression screening studies should carefully consider whether to target major depression alone, for which beneficial treatments clearly exist, or the traditional combined category of major or minor depression, a heterogeneous group for which treatment benefit is unclear. Our results suggest that the sensitivity of screening instruments is generally greater for the major depression alone group.

Sixth, the bulk of the screening studies we reviewed were conducted in the first 3 months postpartum. Subsequent studies should examine screening not just in the first 3 months postpartum but also at 6 weeks, 6 months, and 12 months postpartum. If peak prevalence and incidence occur within the first 6 weeks, the obstetrics clinic is a prime place to target resources for such a program. If, however, peaks occur after this time, most postpartum women will have completed follow-up care with an obstetrician, so programs in an obstetrics clinic may be less helpful. In this case, it is possible that programs targeting new mothers in family medicine, internal medicine, or pediatric clinics might be more effective.

### Use in Clinical Settings

In the interim, what is a clinician to do? The best available evidence supports the conclusion that screening instruments with reasonable test characteristics appear feasible to use in a perinatal population with a depression prevalence between 5 percent and 10 percent. Given that use of the tools likely carries low risk, and that they all have reasonable specificity (and, thus, a reasonable positive predictive value), the selection of a tool would be guided by an interest in maximizing sensitivity. For the category of major or minor depression, sensitivity estimates were quite similar for all instruments. However, for major depression alone, sensitivity estimates for the EPDS and PDSS appear to be higher than those for the BDI. The standard cutoffs of ≥ 13 for the EPDS and ≥ 81 for the PDSS appear to be reasonable thresholds.

Having an instrument that can accurately identify women at risk of having perinatal depression is an important and necessary link in improving the clinical outcomes of women with perinatal depression: women who may benefit from a depression intervention first need to be recognized. Nonetheless, it remains merely an initial step. A more important question is whether screening pregnant or postpartum women to identify those at risk of having depression, and subsequently providing an intervention, ultimately leads to improved outcome. We address this key question in our next chapter.