# Prevalence and Incidence of Perinatal Depression

## Introduction

Perinatal depression is generally recognized to be a common affliction among women during pregnancy and the first postpartum year. However, estimates of the prevalence and incidence of the condition vary widely—from 5 percent to more than 25 percent of pregnant women and new mothers—depending on the assessment method, the timing of the assessment, and population characteristics. ^21,^ ^22,^ ^27^ To estimate disease burden more accurately and thereby better target and prioritize health care expenditures, we need more precise estimates of the prevalence and incidence of perinatal depression.

Two prior systematic reviews of the prevalence of perinatal depression—one for the early postpartum months and the other for pregnancy—are notable. O'Hara and Swain conducted the first meta-analysis of the prevalence of postpartum depression and investigated sources of variability in the prevalence estimates across studies. ^21^ The authors combined estimates from 59 studies in which depression had been assessed at least 2 weeks postpartum using either a clinical interview or a validated self-report measure with an established cutoff (i.e., Beck Depression Inventory [BDI] ≥ 10; Edinburgh Postnatal Depression Scale [EPDS] ≥ 13; Zung Depression Scale ≥ 48; Center for Epidemiological Studies—Depression [CES-D] scale ≥ 16). Based on a total sample of 12,810 postpartum women, they estimated the average prevalence of postpartum depression to be 13.0 percent, with a 95% confidence interval (CI) of 12.3 percent to 13.4 percent. They found that self-report measures yielded significantly higher estimates of postpartum depression than interview-based methods and that longer evaluation periods resulted in higher estimates. The number of days postpartum when the depression assessment was made and the country in which the study was conducted did not significantly affect the prevalence estimates in their analysis.

More recently, Bennett et al. conducted a meta-analysis of prevalence estimates for depression during pregnancy. ^27^ The authors combined estimates from 21 studies meeting predetermined inclusion criteria, including the assessment of depression by a structured clinical interview, the BDI, or the EPDS. Based on a total sample of 19,284 pregnant women, they estimated the prevalence of depression to be 7.4 percent (95% CI, 2.2 percent to 12.6 percent) during the first trimester, 12.8 percent (95% CI, 10.7 percent to 14.8 percent) during the second trimester, and 12.0 percent (95% CI, 7.4 percent to 16.7 percent) during the third trimester. The 95% CIs of these estimates overlap substantially, indicating that, given available evidence, the prevalence of depression during pregnancy cannot be said to differ significantly by trimester. The authors also found that, compared with structured clinical interviews, the self-report BDI produced significantly higher prevalence estimates, whereas the self-report EPDS produced statistically equivalent estimates.

Several factors point to the need for a reassessment of the prevalence of depression during pregnancy and the postpartum period at this time. First, the clinical definition of major depression has changed over time, becoming more precise. Definitions of major depression prior to the 1987 revision of the Diagnostic and Statistical Manual of Mental Disorders, Third Edition (DSM-III-R), were broader than subsequent definitions and likely included some minor depression and dysthymia. Minor depression is a proposed diagnosis for further study for which the 1994 DSM, fourth edition (DSM-IV), has defined research criteria; ^28^ however, it has not yet been added to the DSM-IV. Furthermore, DSM-IV has an even more precise definition of major depression, requiring a minimum number of depressive symptoms and functional impairment, whereas DSM-III-R required only counts of depressive symptoms. Most of the literature reviewed in the O'Hara and Swain study ^21^ (published in 1996) was published before 1994. Determining whether more recent studies affect the combined prevalence estimates and CIs is crucial to improving understanding of this disorder.

Most of the studies in Bennett et al. ^27^ (done in 2004) were published after 1994. Whether the combined prevalence estimates refer to major and minor depression together or major depression alone is not clear. The text of the article discusses major depression, but the tables clearly indicate the inclusion of minor depression.

Second, neither review distinguished between measures of the point prevalence, the percentage of the population with depression at a given point in time (e.g., at 24 weeks gestational age or 9 weeks postpartum), and measures of period prevalence, the percentage of the population with depression over a period of time (e.g., during pregnancy or from delivery to the end of the first 3 months postpartum). Both types of estimates are used for the single combined prevalence estimates, although O'Hara and Swain did test the effect of differing time points and durations for the depression assessment in a meta-regression.

Third, neither of the reviews presented evidence of the incidence of perinatal depression—the percentage of the population with depressive episodes that begin within a given period of time.

Fourth, overall prevalence estimates from both reviews are confounded by false positives because they included prevalence estimates from studies that assessed depression with self-report instruments. As mentioned above, both systematic reviews found that self-report instruments produce significantly higher prevalence estimates than do clinical interviews.

Finally, although both systematic reviews discussed prevalence estimates for women who were not pregnant and had not recently delivered a child, neither study rigorously reviewed the evidence that compares depression rates for women during pregnancy and the first postpartum year to the rates for women of a similar age during nonchildbearing times.

This chapter reviews the literature addressing Key Question (KQ) 1: What is the prevalence and incidence of depression (major and minor) during pregnancy and during the first year postpartum? Is the prevalence or incidence increased during pregnancy and the first postpartum year compared to nonchildbearing periods?

## Methods

We abstracted study features and all estimates of the prevalence and incidence of major and minor depression together and of major depression alone from the 30 included studies found through our literature searches described in Chapter 2. During the abstraction process, we graded the quality of the study based on selected study features. We then analyzed the estimates using a variety of meta-analytic methods described in this section.

### Evaluation of the Quality and Strength of the Evidence

Appendix B presents the quality rating form used for articles considered for KQ 1. The total possible score for these studies was 20 for studies without a comparison group and 25 for studies with a comparison group. For both types of studies, we considered those articles with a score of 16 or greater to be good, those with scores between 10 and 15 to be fair, and those with scores of 9 and below to be poor. The domains and maximum points possible for each domain are as follows:

- Reporting (domain score of 9): Eight items covering study aims, measures, patient populations, findings, and statistical presentation; each scored yes or no (1 or 0), except for an item concerning principal confounders that was scored yes, partially, or no (2, 1, or 0, respectively).
- External validity (domain score of 3): Three items relating to the representativeness of populations from which people were recruited and of settings and clinicians that treat such patients; each scored yes, no, or unable to determine (1, 0, or 0, respectively).
- Internal validity—bias (domain score of 3): Three items relating to issues such as validation of the depression diagnosis through clinical interview, follow-up periods, and appropriate statistical tests; each scored yes, no, or unable to determine (1, 0, or 0, respectively).
- Internal validity—confounding (domain score of 2 for studies without a comparison group and 4 for studies with a comparison group): Two items relating to sources of comparison groups, one for the adequacy of adjustments for confounding, and one for the handling of loss to follow-up; each scored yes, no, or unable to determine (1, 0, or 0, respectively).
- Precision (domain score of 3 for studies without a comparison group and 6 with a comparison group): One item relating to the number of pregnant or postpartum women assessed for depression, with scores of 3 for more than 1,000 women, 2 for 250 to 1,000 women, 1 for 30 to 250 women, and 0 for fewer than 30 women. For studies with a comparison group, a second item gave points based on the size of the smallest comparison group: a score of 3 for more than 2,000 women, 2 for 1,000 to 2,000 women, 1 for 500 to 1,000 women, and 0 for fewer than 500 women.

### Best Estimates of Prevalence and Incidence

We abstracted all estimates of the prevalence and incidence of major and minor depression together and major depression alone. We distinguished prevalence estimates by whether they were point or period estimates and both prevalence and incidence estimates by the time period covered. Time periods for point prevalence estimates were defined as trimesters during pregnancy and months during the first postpartum year. Estimates taken at different weeks of gestation but within the same trimester of pregnancy were considered as being conducted in the same time period (e.g., estimates taken week 14 through week 27 of gestation were considered the second trimester). Similarly, estimates taken at different weeks postpartum but within the same month postpartum were considered within the same time period (e.g., estimates taken during week 1 through week 4 postpartum would be considered month 1; week 5 through week 9 postpartum, month 2). Where we found two or more estimates within the same trimester of pregnancy or month postpartum, we used meta-analysis to obtain a combined estimate for that trimester or month. We then graphed the resulting estimates to determine how they changed throughout pregnancy and the first postpartum year.

We conducted similar procedures for period prevalence and incidence estimates. The relevant time periods were either single trimesters and months or multiple trimesters and months. Because we found fewer estimates of these types, however, we graphed period prevalence and incidence estimates for only the first 3 months postpartum.

We combined all estimates with the same diagnosis, estimate type, and time period using the meta command in Stata. This procedure uses the inverse-variance weighting method to calculate random effects summary estimates. It also produces (1) Q tests of the homogeneity of the estimates and (2) forest plots of the individual study and combined estimates and their CIs. To satisfy the normalcy assumptions of these methods, we first transformed the prevalence estimates into log odds estimates.

We reviewed the forest plots of the studies in each summary estimate to determine whether we could identify the source of any heterogeneity between studies. We then reran the meta-analyses excluding studies that were obvious outliers and for which we could identify the source of the bias. The new summary estimates are considered our best estimates of the prevalence and incidence of perinatal depression for the general female population in the United States.

### Analysis of Confounders

To analyze associations between the prevalence of depression and study characteristics, we conducted cumulative meta-analysis and a series of meta-regressions on the point prevalence estimates for major and minor depression together and major depression alone. In the cumulative meta-analysis, we added studies one by one, based on publication year, to produce a new combined estimate with the cumulative evidence for each year. This procedure allowed us to see trends in the estimate over time. We conducted cumulative meta-analysis on the 2-month point prevalence estimates using the metacum command in Stata.

We then used the Stata metareg command to estimate several different meta-regression models. For all models, we used the log odds as the dependent variable and included the time point at which depression was assessed and indicators for whether the study enrolled only low-risk women and only women of low socioeconomic status (SES) as explanatory variables. The time point was represented by a categorical variable with included values for the first, second, and third trimesters and the first, second, and third months postpartum. The reference category for this variable was 4 to 12 months postpartum.

We estimated seven different models. Each had a different set of additional explanatory variables:

1. No additional explanatory variables;
2. Publication year;
3. Study country, categorized as the United States (the reference category), other western countries, and Asian countries;
4. Interview type, categorized as the Schedule for Affective Disorders and Schizophrenia (SADS) (the reference category), the Structured Clinical Interview for DSM Diagnoses (SCID), and other interview types;
5. Diagnostic criteria, categorized as Research Diagnostic Criteria (RDC) (the reference category), DSM III-R, DSM IV, and other criteria;
6. Whether depression was assessed only for women who were designated as at risk based on a screening instrument; and
7. The quality rating score.

### Comparison with Other Women

To answer the second part of KQ 1, whether the prevalence and incidence of depression is higher during pregnancy and the first year postpartum compared to nonchildbearing periods, we computed odds ratios for studies with a comparison group of women of similar age during nonchildbearing times. Because the types and timing of prevalence and incidence estimates did not overlap in these studies, except for one time point, we did not conduct meta-analyses of the log odds ratios.

## Results

We found 28 prospective studies and two retrospective studies that met our inclusion criteria. Only three of the prospective studies included a comparison group of nonpregnant women of similar age. ^a^ In this section, we first describe the study characteristics and then present our analysis of the study results.

a Two studies assessed the mood of fathers in addition to the mothers. ^30,^ ^45^ We do not address the comparison of mothers and fathers in this chapter because it is beyond the scope of this study.

### Study Characteristics

The major characteristics of the 30 studies are summarized in Table 4 by study type and alphabetically within type. The 25 prospective studies without a comparison group are shown first, ^19,^ ^23,^ ^29–51^ followed by the three prospective studies with a comparison group, ^20,^ ^52,^ ^53^ and, finally, the two retrospective studies. ^54,^ ^55^ Important study characteristics include the precision or size of the studies, the representativeness of the study populations, the methods and timing used to assess the mother's mood, and the quality rating of study design. Each of these characteristics is addressed in turn below.

Table 4. Major characteristics of studies of prevalence and incidence of perinatal depression

Author, Year | Country | Sample Size | Who Interviewed | When Interviewed | Interview Type | Diagnostic Criteria
Prospective Cohort Studies without Comparison Groups
Affonso et al., 1990 ^29^ | US | 202 | All | Pregnancy & PP | SADS-PPG | RDC
Areias et al., 1996 ^30^ | Portugal | 54 | All | Pregnancy & PP | SADS | RDC
Berle et al., 2003 ^31^ | Norway | 411 | All EPDS ≥ 8 & some < 8 | PP | MINI-V4.4/ MADRS | DSM-IV
Campbell and Cohn, 1991 ^32^ | US | 1,033 | All | PP | SADS | RDC
Cooper et al., 1996 ^33^ | England | 4,964 | EPDS ≥ 8 | PP | SCID | DSM-III-R
Cox et al., 1982 ^34^ | Scotland | 105 | All | PP | SPI | Pitt's
Garcia-Esteve et al., 2003 ^35^ | Spain | 1,123 | All EPDS ≥ 9 & some < 9 | PP | SCID-NP | DSM-IV
Gotlib et al., 1989 ^36^ | Canada | 295 | All BDI ≥ 10 & some < 10 | Pregnancy & PP | SADS | RDC
Hobfoll et al., 1995 ^37^ | US | 192 | All | Pregnancy & PP | SADS | RDC
Kent et al., 1999 ^38^ | Australia | 710 | GHQ28 > 4 | PP | CIDI-A | DSM-III-R
Kitamura et al., 1993 ^39^ | Japan | 120 | All | Pregnancy | SADS/ SADS-C | RDC
Kitamura et al., 1999 ^40^ | Japan | 111 | All | Pregnancy & PP | SADS | RDC
Kumar and Robson, 1984 ^41^ | England | 196 | All | Pregnancy & PP | SPI | RDC
Lee et al., 2001 ^42^ | Hong Kong | 781 | All GHQ > 4 & some ≤ 4 | PP | Modified SCID | Modified DSM-III-R
Lee et al., 2001 ^43^ | Hong Kong | 145 | All | PP | Modified SCID | Modified DSM-III-R
Lucas et al., 2001 ^44^ | Spain | 641 | BDI > 21 | PP | Not specified | DSM-III-R
Matthey et al., 2003 ^45^ | Australia | 408 | All | PP | DIS | DSM-IV
Murray and Cox, 1990 ^46^ | England | 100 | All | Pregnancy | SPI | RDC
O'Hara et al., 1984 ^19^ | US | 99 | All | Pregnancy & PP | SADS | RDC
Pop et al., 1993 ^47^ | Netherlands | 293 | All | Pregnancy & PP | Not specified | RDC
Watson et al., 1984 ^48^ | England | 128 | All | Pregnancy & PP | SPI | ICD-9
Whiffen, 1988 ^49^ | Canada | 115 | All | PP | SADS | RDC
Yamashita et al., 2000 ^50^ | Japan | 88 | All | PP | SADS | RDC
Yonkers et al., 2001 ^23^ | US | 802 | All IDS ≥ 18 or EPDS ≥ 12 & some < 12 | PP | SCID | DSM-IV
Yoshida et al., 1997 ^51^ | England | 98 | All | PP | SADS | RDC
Prospective Studies with Comparison Groups
Cooper et al., 1988 ^52^ | England | 483 cases | All GHQ ≥ 12 & some < 12 | PP | PSE/ MADRS | PSE ID/ Catego Class
| | 313 controls
Cox et al., 1993 ^20^ | England | 232 cases | All EPDS ≥ 9 & some < 9 | PP | SPI | RDC
| | 232 controls
O'Hara et al., 1990 ^53^ | US | 182 cases | All | Pregnancy & PP | SADS | RDC
| | 179 controls
Retrospective Studies
Bryan et al., 1999 ^54^ | US | 403 | — | PP | Medical records | Diagnosis of 2 or more symptoms
Georgiopoulos et al., 2001 ^55^ | US | 342 | — | PP | Medical records | Diagnosis

BDI, Beck Depression Inventory; CIDI-A, Composite International Diagnostic Interview; DIS, Diagnostic Inventory Schedule; DSM-III-R, Diagnostic and Statistical Manual of Mental Disorders, Third Edition, Revised; DSM-IV, Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition; EPDS, Edinburgh Postnatal Depression Scale; GHQ, General Health Questionnaire; ICD-9, International Classification of Diseases, Ninth Edition; MADRS, Montgomery-Asburg Depression Rating Scale; MINI-V4.4, Mini International Neuropsychiatric Interview, Version 4.4; PP, postpartum; PSE, Present State Examination; PSE ID, PSE Index of Definition; RDC, Research Diagnostic Criteria; SADS, Schedule for Affective Disorders and Schizophrenia; SADS-C, SADS Change Version; SADS-PPG, SADS-Pregnancy and Postpartum Guidelines; SCID, Structured Clinical Interview for DSM-III-R; SCID-NP, Structured Clinical Interview for DSM-III-R, Non-Patient Version; SPI, Standardized Psychiatric Interview.

Precision. The study sample sizes ranged from 54 to 4,964 women; the median sample size was 202 women. Although all the studies had an adequate sample size to provide a prevalence estimate of 10 percent with 80 percent power at a 95% confidence level, most were not large enough to allow subgroup analyses.

The three studies with comparison groups included 313, 232, and 179 women in the comparison groups. ^20,^ ^52,^ ^53^ These sample sizes are inadequate to detect a difference as large as 5 percentage points in incidence or prevalence at 80 percent power and a 95% confidence level; a minimum sample size of more than 500 per group is required.

Representativeness. Included studies represented a wide array of developed nations, but the study subjects were not a good representation of the racial and ethnic mix of the US population (Table 4). Seven of the prospective studies were located in England; six in the United States; three in Japan; two each in Canada, Australia, and Hong Kong; and one each in the Netherlands, Norway, Portugal, and Scotland. The two retrospective studies investigated depression diagnoses documented in the Olmsted County, Minnesota, population-based databases during two different 12-month periods—the 12 months following deliveries occurring in 1993 and the 12 months following deliveries among women visiting the Olmsted County and Mayo clinics in 1997 and 1998. ^54,^ ^55^

None of the studies was designed to compare rates of depression among women of different racial and ethnic groups. Sixteen of the 30 studies did not even specify the racial and ethnic composition of the study subjects. Among the other 14 studies, 5 included only white non-Hispanic women; ^19,^ ^32,^ ^38,^ ^44,^ ^47^ two studies included only Chinese women; ^42,^ ^43^ and two others included only Japanese women. ^50,^ ^51^ The remaining five studies noted a racially mixed population, but all had a predominant race or ethnicity. In four of these studies, 73 percent to 90 percent of the women were white non-Hispanic, ^29,^ ^36,^ ^37,^ ^48^ and, in the fourth, 75 percent were Hispanic. ^23^

Depression Assessment. Our inclusion criteria required that the study use a clinical interview or assessment to validate depression diagnoses. The prospective studies differed in who received a clinical interview, the interview instrument, the diagnostic criteria used to identify a depressive episode from the interview responses, and when the interview was conducted. These differences can affect the resulting estimates of prevalence and incidence.

Eighteen of the 28 prospective studies conducted a clinical interview on all study women. The remaining 10 studies first had study subjects complete a self-report depression screening instrument, such as the EPDS, the BDI, or the General Health Questionnaire (GHQ), a broader measure designed to assess the presence of psychiatric distress related to general medical illness. These studies then administered a clinical interview to women scoring over a predetermined cutoff on the screening instrument. Seven of the 10 studies also interviewed a small sample (e.g., 10 percent) of the women scoring below the cutoff, but few of the studies used the results from these interviews to adjust the final prevalence estimates for false negatives. Most studies used low enough cutoff scores that the resulting downward bias in the estimates was minimal. The one exception was the Lucas et al. study, which used a high cutoff of 21 on the BDI and did not interview any women scoring below the cutoff or adjust the resulting prevalence rates in any way, thereby introducing a significant, uncorrected downward bias. ^44^

Different interview instruments have been developed for identifying depression diagnoses. These different instruments use different criteria for diagnosing depression. Little is known about how these different instruments and diagnostic criteria affect the prevalence and incidence estimates.

The most frequently used instrument among our studies was the SADS. This semistructured interview is widely used in clinical research and has well-established reliability and validity. ^56^ O'Hara et al. adapted the SADS for use with pregnant and postpartum women. ^19^ Twelve of the 28 prospective studies used this interview instrument.

Five of the studies used the section of the SCID that covers depressive disorders. ^57,^ ^58^ The SCID allows the interviewer to use additional questions to inquire about idioms of distress that are specific to the local context. Lee et al. used this feature of the SCID to incorporate questions about traditional Chinese customs used during the puerperium that may affect the clinical presentation of postpartum depression. ^42,^ ^43^ They also modified the instrument to identify cases of minor depression.

Five other studies used the Standardized Psychiatric Interview (SPI) of Goldberg et al. ^59^ The SPI includes 10 five-point scales that rate the severity of neurotic symptoms in the 7 days preceding the interview and a rating of 12 abnormalities observed during the interview.

Other interview instruments used include the Composite International Diagnostic Interview (CIDI-A), ^60^ the Diagnostic Interview Schedule, ^61^ the Mini International Neuropsychiatric Interview (MINI-V4.4), ^62^ the Present State Examination (PSE), ^63^ and the Montgomery and Asberg Depression Rating Scale (MADRS). ^64^

All studies that used the SADS and three of the studies that used the SPI based depression diagnosis on the RDC. ^65^ To be diagnosed with depression, women had to have reported that they felt sad, tearful, or blue for at least 2 weeks. The 2-week criterion serves to rule out women who were experiencing postpartum blues only. In addition, for a diagnosis of major depression, the women had to have reported at least three or four additional symptoms, such as sleeping disturbances, loss of appetite, fatigue, loss of interest in usual activities or the ability to concentrate, psychomotor retardation, and suicidal thoughts. Women with only two to four of these symptoms were classified as having minor depression. The RDC attempts to differentiate between normal physical effects of pregnancy and the puerperium and actual symptoms of depression.

Five of the prospective studies based diagnoses of depression on DSM-III-R criteria and four based diagnoses on DSM-IV criteria. A diagnosis of major depression based on the DSM-III-R criteria is comparable with the RDC for definite major depression. ^66^ However, the RDC includes criteria for minor depression, which, as mentioned above, received its first DSM mention in the fourth edition (DSM-IV) ^28^ as a proposed category for further study. Other criteria used for diagnoses of depression included Pitt's criteria; ^67^ the International Classification of Diseases, Ninth Edition (ICD-9); and PSE Index of Definition (PSE ID) and Catego Class. ^63^

Finally, because the prevalence and incidence of depression may not be constant throughout pregnancy and the first postpartum year, the timing of the clinical interview is also very important. Most of the studies we reviewed administered the clinical interview at multiple points in time throughout pregnancy and the first postpartum year, allowing for multiple estimates of prevalence and incidence. The 28 prospective studies provided 80 estimates of the prevalence and incidence of major and minor depression and 70 estimates of the prevalence and incidence of major depression alone. Clinical assessments of depression were taken at different points in time throughout pregnancy and the first postpartum year. Graphical presentations of the timing of each of the estimates by diagnosis and estimate type are shown in Figures 3 through 8 as follows:

Figure 3. Estimates of point prevalence of major and minor depression by time of assessment

Figure 8. Estimates of incidence of major depression by time period of assessment

- Point prevalence estimates
  42 for major and minor depression (Figure 3)
  46 for major depression alone (Figure 4)
- Period prevalence estimates
  17 for major and minor depression (Figure 5)
  12 for major depression alone (Figure 6)
- Incidence estimates
  21 for major and minor depression (Figure 7)
  12 for major depression alone (Figure 8).

Figure 4. Estimates of point prevalence of major depression by time of assessment

Figure 5. Estimates of period prevalence of major and minor depression by time period of assessment

Figure 6. Estimates of period prevalence of major depression by time period of assessment

Figure 7. Estimates of incidence of major and minor depression by time period of assessment

The numbers in parentheses in these figures are the number of estimates found in the 28 studies for that point or period of time.

For the two retrospective studies, the investigators had abstracted information on symptoms and diagnoses of depression from medical records beginning at delivery and extending to 1 year postpartum. Both studies provided only estimates of 1-year period prevalence. Bryan et al. ^54^ provided estimates of the prevalence for both major and minor depression and major depression alone, whereas Georgiopoulos et al. ^55^ provided only the prevalence of major depression alone. Bryan et al. identified a woman as having postpartum depression if any of the following criteria were found in her medical records: ^54^ (1) two notations at least 2 weeks apart of symptoms of depression; (2) a documented diagnosis of depression by a physician, psychologist, nurse practitioner, or midwife; (3) a new prescription for an antidepressant with no evidence that it was for chronic pain or for any indication other than depression; and (4) documentation of symptoms sufficient to meet the DSM-IV criteria of major depression. Georgiopoulos et al. ^55^ based their prevalence estimate solely on a documented diagnosis of postpartum depression.

Quality Rating. We show the results of the quality rating of the included articles in Table 5 by study type. Studies were rated on reporting completeness, external validity, internal validity, and precision. The average overall quality rating score, out of a possible 20 points, was 11.1 for prospective studies without comparison groups and 12.0 for the retrospective studies. For prospective studies with comparison groups, which had 25 possible points, the average overall quality score was 11.7. Thus, we would rate the overall body of evidence for the prevalence and incidence of perinatal depression as fair at best.

Table 5. Quality rating of studies of the prevalence and incidence of perinatal depression

Author, Year | Reporting (9) | External Validity (3) | Internal Validity-Bias (3) | Internal Validity-Confounding (2) | Precision (3) | Total Score (20)
Prospective Cohort Studies without Comparison Groups
Affonso et al., 1990 ^29^ | 4 | 0 | 3 | 0 | 1 | 8
Areias et al., 1996 ^30^ | 8 | 0 | 2 | 1 | 1 | 12
Berle et al., 2003 ^31^ | 5 | 0 | 2 | 0 | 2 | 9
Campbell and Cohn, 1991 ^32^ | 6 | 0 | 3 | 0 | 3 | 12
Cooper et al., 1996 ^33^ | 7 | 0 | 2 | 0 | 3 | 12
Cox et al., 1982 ^34^ | 5 | 1 | 3 | 1 | 1 | 11
Garcia-Esteve et al., 2003 ^35^ | 7 | 0 | 2 | 1 | 3 | 13
Gotlib et al., 1989 ^36^ | 5 | 2 | 1 | 1 | 2 | 11
Hobfoll et al., 1995 ^37^ | 6 | 3 | 2 | 0 | 1 | 12
Kent et al., 1999 ^38^ | 7 | 1 | 2 | 0 | 2 | 12
Kitamura et al., 1993 ^39^ | 8 | 0 | 3 | 1 | 1 | 13
Kitamura et al., 1999 ^40^ | 4 | 1 | 3 | 1 | 1 | 10
Kumar and Robson, 1984 ^41^ | 7 | 0 | 3 | 0 | 1 | 11
Lee et al., 2001 ^42^ | 6 | 2 | 2 | 1 | 1 | 12
Lee et al., 2001 ^43^ | 5 | 2 | 0 | 0 | 1 | 8
Lucas et al., 2001 ^44^ | 5 | 0 | 2 | 0 | 2 | 9
Matthey et al., 2003 ^45^ | 6 | 0 | 3 | 0 | 2 | 11
Murray and Cox, 1990 ^46^ | 6 | 0 | 3 | 0 | 1 | 10
O'Hara et al., 1984 ^19^ | 6 | 0 | 3 | 0 | 1 | 10
Pop et al., 1993 ^47^ | 7 | 1 | 3 | 0 | 2 | 13
Watson et al., 1984 ^48^ | 7 | 2 | 3 | 0 | 1 | 13
Whiffen, 1988 ^49^ | 6 | 0 | 3 | 0 | 1 | 10
Yamashita et al., 2000 ^50^ | 6 | 0 | 3 | 0 | 1 | 10
Yonkers et al., 2001 ^23^ | 8 | 0 | 2 | 2 | 2 | 14
Yoshida et al., 1997 ^51^ | 7 | 0 | 3 | 0 | 1 | 11
Average | 6.0 | 0.6 | 2.4 | 0.4 | 1.5 | 11.1
Retrospective Studies
Bryan et al., 1999 ^54^ | 8 | 3 | 2 | 1 | 2 | 16
Georgiopoulos et al., 2001 ^55^ | 2 | 2 | 1 | 1 | 2 | 8
Average | 5.0 | 2.5 | 1.5 | 1.0 | 2.0 | 12.0
Prospective Studies with Comparison Groups
Cooper et al., 1988 ^52^ | 6 | 0 | 2 | 0 | 2 | 10
Cox et al., 1993 ^20^ | 5 | 1 | 2 | 3 | 1 | 12
O'Hara et al., 1990 ^53^ | 7 | 0 | 3 | 2 | 1 | 13
Average | 6.0 | 0.3 | 2.3 | 1.7 | 1.3 | 11.7

Note: Numbers in parentheses are total possible points.

In general, studies ranked good on reporting. The 28 prospective studies, both those with and those without comparison groups, scored an average of 6.0 out of 9 possible points for reporting. The retrospective studies scored 5.0 on average. Most studies clearly described the purpose of the study, the method of assessing depression, the characteristics of the patients in the study, and the study findings. Most studies also provided adequate information to estimate the random variability in the estimates and reported actual probability values for the statistical significance of the main outcomes. Fewer studies provided the distribution of the major principal confounders and described the characteristics of patients lost to follow-up. In particular, studies often did not discuss whether the women had prior depressive episodes or obstetrical complications and frequently did not report the women's socioeconomic status or race and ethnicity. Most studies also did not specifically exclude cases of bipolar disorder or psychosis.

Virtually all prospective studies rated poor on external validity. Prospective studies without a comparison group averaged 0.8 points out of 3 possible points; those with a comparison group averaged 0.3 points. These studies seldom supplied adequate information to determine whether study subjects were representative of the patient population of the facilities from which they were recruited and whether the recruitment facilities were representative of the facilities frequented by the general population in the geographic area. In contrast, the two retrospective studies, which were conducted using the Olmsted County Health Department and Mayo Clinic databases, included the majority of all newly delivered women in the county and therefore scored an average of 2.5 points on external validity.

We separated scores for internal validity into two sets of study design characteristics: those that may bias the prevalence estimates and those that reflect possible confounding factors, which relate to the comparability of the comparison groups and whether losses of patients to follow-up were taken into consideration. The prospective studies scored high on the first measure of internal validity; the studies without a comparison group averaged 2.4 of 3 points and the studies with a comparison group averaged 2.3 points. Virtually all prospective studies assessed the mood of study women within 2 weeks of designated times during pregnancy and postpartum and applied appropriate statistical tests for measuring incidence or prevalence. However, as noted above, 10 studies introduced potential bias by not administering the clinical interview to all study women.

The retrospective studies averaged a lower 1.5 points. Diagnoses were not validated through clinical interview for all women, and Georgiopoulos et al. did not provide adequate information to determine whether they used appropriate statistical techniques to compute the prevalence estimate. ^55^

Studies with comparison groups could get 4 possible points for the internal validity confounding score. We awarded 2 additional points if the cases and controls were recruited from the same population and over the same period of time. Only two of the three prospective studies with comparison groups met these criteria. The comparison group in the Cooper et al. study comprised women interviewed by another researcher over a different time period in a different city. Study women were recruited from the appointments diary of the prenatal clinic and the delivery booking diary of the general practitioner unit of the John Radcliffe Hospital in Oxford; the comparison group was derived from a community sample of Edinburgh women of similar age but who were not pregnant and had not delivered in the previous 12 months. ^52^

By contrast, in the Cox et al. study, both cases and controls resided in the North Staffordshire Health District. ^20^ Cases were recruited from the prenatal clinic lists of the North Staffordshire Maternity Hospital; controls matching cases on marital status, number of children, and age (within 5 years) were recruited from four general practice registers. The O'Hara et al. study recruited cases from a public obstetrics and gynecology clinic and two private practices at the University of Iowa Hospitals and Clinics. ^53^ Each subject was asked to provide the names of five acquaintances similar in age, marital status, work status, and number of children. The acquaintance most similar to the subject was selected as a control.

We also gave points for the internal validity confounding measure if the investigators made adjustments or discussed the possible direction and magnitude of any biases from confounding factors and if they took the loss of patients to follow-up into account in their prevalence or incidence estimate. A minority of studies met either of these criteria, resulting in an average score on this measure of 0.4 out of 4 possible points for prospective studies without comparison groups, 1.7 for prospective studies with comparison groups, and 1.0 for the retrospective studies.

Finally, we gave 17 studies with 30 to 250 pregnant or recently delivered women a precision score of 1, 10 studies with 250 to 1,000 women a precision score of 2, and 3 studies with more than 1,000 women a precision score of 3. None of the studies had a comparison group of at least 500 women; therefore, we awarded no additional points for precision. The average precision score was 1.5 for prospective studies without comparison groups, 1.3 for prospective studies with comparison groups, and 2.0 for the retrospective studies.

In summary, the included studies generally were rated as good on reporting and internal validity for bias, poor on external validity and internal validity for confounding, and only fair on precision.

### Results from Prospective Studies

Our original estimates of point prevalence, period prevalence, and incidence rates computed from all of the estimates in the included studies are shown by time period in Table 6 for major and minor depression together and in Table 7 for major depression alone. For time periods for which we had more than one estimate, we show the combined estimate from the meta-analysis and the P-value for the Q test of homogeneity. This statistic tests the null hypothesis that the estimates come from the same distribution—that is, whether or not the studies appear statistically to measure the same phenomenon. A P-value < 0.05 suggests that they do not.

Table 6. Original estimates of prevalence and incidence of major and minor depression

Start Date | End Date | Studies | Estimate | 95% Confidence Interval | P-Value for Test of Homogeneity
Point Prevalence
| 1st trimester | 29,40,41 | 6.4% | 2.3%–16.2% | 0.002
| 2nd trimester | 19,36,37,41,53 | 11.0% | 5.7%–20.4% | 0.000
| 3rd trimester | 29,36,37,40,41,46,47 | 8.7% | 4.9%–15.0% | 0.000
| 1 week PP | 40 | 5.5% | 1.8%–12.4%
| 1 month PP | 23,29,36,40,42,47,50 | 8.8% | 6.4%–11.9% | 0.002
| 2 months PP | 31,32,35,37,43,49,53 | 11.3% | 7.7%–16.2% | 0.000
| 3 months PP | 41,42,47,50 | 12.9% | 10.6%–15.8% | 0.707
| 4 months PP | 29,47 | 4.3% | 0.6%–25.4% | 0.001
| 5 months PP | 47 | 10.6% | 7.3%–14.7%
| 6 months PP | 20 | 9.9% | 6.4%–14.5%
| 7 months PP | 41,47 | 10.6% | 7.1%–15.6% | 0.180
| 8 months PP | 47 | 6.5% | 4.0%–9.9%
| 12 months PP | 41 | 6.5% | 2.7%–12.9%
Period Prevalence
Conception | 2nd trimester | 30 | 9.3% | 3.1%–20.3%
Conception | Birth | 30,39,41 | 18.4% | 14.3%–23.3% | 0.931
2nd trimester | 3rd trimester | 36 | 10.2% | 7.0%–14.2%
Birth | 1 month PP | 50 | 13.6% | 7.3%–22.6%
Birth | 2 months PP | 19,32,45 | 8.9% | 6.8%–11.7% | 0.135
Birth | 3 months PP | 30,50,51 | 19.2% | 10.7%–31.9% | 0.016
Birth | 5 months PP | 34 | 29.1% | 20.6%–38.9%
Birth | 6 months PP | 20 | 13.8% | 9.6%–18.9%
Birth | 8 months PP | 47 | 20.8% | 16.3%–25.9%
Birth | 12 months PP | 30 | 53.7% | 39.6%–67.4%
Incidence
Conception | 1st trimester | 39,41 | 11.3% | 7.8%–16.3% | 0.757
Conception | 2nd trimester | 30 | 5.8% | 1.2%–16.0%
Conception | Birth | 30,39 | 14.5% | 8.1%–24.4% | 0.192
1st trimester | 2nd trimester | 41 | 2.7% | 0.6%–7.6%
2nd trimester | 3rd trimester | 36,41 | 2.2% | 1.1%–4.1% | 0.627
2nd trimester | 2 months PP | 37 | 12.5% | 7.9%–18.5%
Birth | 1 month PP | 36,42,50 | 7.8% | 3.6%–16.1% | 0.003
Birth | 2 months PP | 19 | 10.3% | 5.1%–18.1%
Birth | 3 months PP | 30,41,42,50,51 | 14.5% | 10.9%–19.2% | 0.142
Birth | 6 months PP | 20 | 11.1% | 7.3%–16.0%
Birth | 12 months PP | 30 | 49.0% | 34.4%–63.7%

Table 7. Original estimates of prevalence and incidence of major and minor depression

Start Date | End Date | Studies | Estimate | 95% Confidence Interval | P-Value for Test of Homogeneity
Point Prevalence
| 1st trimester | 29,40,41 | 2.4% | 0.7%–8.2% | 0.032
| 2nd trimester | 19,37,48,53 | 6.4% | 3.7%–11.0% | 0.029
| 3rd trimester | 29,37,40,46,47 | 3.4% | 1.8%–6.4% | 0.116
| 1 week PP | 40 | 0.0% | 0.0%–3.2%
| 1 month PP | 23,42,44,50 | 2.8% | 1.5%–5.5% | 0.000
| 2 months PP | 31,33,35,37,42,48,49 | 6.8% | 3.8%–11.9% | 0.000
| 3 months PP | 42,44,50 | 3.8% | 2.4%–6.1% | 0.010
| 4 months PP | 29,47 | 2.3% | 1.1%–4.9% | 0.435
| 5 months PP | 47 | 2.1% | 0.8%–4.4%
| 6 months PP | 20,38,44,52 | 4.2% | 2.1%–8.7% | 0.000
| 7 months PP | 47 | 3.1% | 1.4%–5.8%
| 8 months PP | 47 | 1.0% | 0.2%–3.0%
| 9 months PP | 44 | 0.0% | 0.0%–0.7%
| 12 months PP | 44,52 | 1.3% | 0.0%–56.6% | 0.206
Period Prevalence
Conception | Birth | 39 | 12.7 | 7.1%–20.4%
1st trimester | Birth | 48 | 9.4% | 4.9%–15.8%
Birth | 1 month PP | 50 | 5.7% | 1.9%–12.8%
Birth | 2 months PP | 19,32, | 6.5% | 5.2%–8.2% | 0.516
Birth | 3 months PP | 50,51 | 7.1% | 4.1%–11.7% | 0.626
Birth | 5 months PP | 34 | 12.6% | 6.9%–20.6%
Birth | 6 months PP | 20 | 6.5% | 3.7%–10.4%
Birth | 8 months PP | 47 | 6.8% | 4.2%–10.4%
Birth | 12 months PP | 44,48 | 6.6% | 0.5%–51.7% | 0.000
Incidence
Conception | Birth | 30,39,48 | 7.5% | 3.8%–14.2% | 0.116
2nd trimester | 2 months PP | 37 | 3.0% | 1.0%–6.8%
Birth | 1 month PP | 23,42,50 | 3.9% | 2.9%–5.4% | 0.429
Birth | 2 month PP | 48 | 8.1% | 4.0%–14.4%
Birth | 3 months PP | 42,50,51 | 6.5% | 4.2%–9.6% | 0.767
Birth | 12 months PP | 30 | 30.6% | 18.3%–45.4%

The results of these tests indicate that considerable heterogeneity exists across the studies included in many of the pooled estimates, particularly among the point prevalence estimates. Therefore, we first discuss the results of our analysis of outliers and then discuss the results of the revised meta-analyses. We finish this section by presenting the findings from the studies with comparison groups of nonchildbearing women.

Outliers. In a review of the forest plots of the meta-analyses of the prevalence and incidence estimates, we found estimates from several studies consistently to be outliers for all time periods at which they assessed the women's mood. Two studies included only women at low risk of depression. ^29,^ ^32^ Affonso et al. ^29^ included only primigravida women with a viable fetus who were married or living with the infant's father and who had no recent depression episodes. Campbell and Cohn ^32^ included only primiparous women who delivered full-term, single infants without major complications and who were Caucasian, married, over 17 years of age, and had at least a high school education. The estimates from these studies were consistently lower than the estimates from the other studies.

Two additional studies included only women of lower socioeconomic status. ^23,^ ^37^ These studies generally provided higher estimates of depression prevalence and incidence than the other studies.

The Lucas et al. study included only women who screened positive for depression on the BDI. ^44^ The cutoff used (> 21) was so high that the bias from false negatives produced consistently lower prevalence estimates compared to the other studies.

Finally, because of its size, the Cooper et al. study dominated the combined 2-month point prevalence estimate for major depression alone. ^33^ However, the 15.3 percent estimated point prevalence from this study is outside the 95% CI of the combined estimate for major and minor depression. The purpose of the study was not to produce a prevalence estimate but rather to develop a predictive index for postpartum depression. Furthermore, many of the clinical interviews were conducted by telephone and the article did not state whether a clinician or lay person conducted the interview. Thus, the procedures for assessing depression in this study may have introduced significant bias in the prevalence estimate.

We reran the meta-analyses excluding these six studies to produce “best estimates” of the prevalence of perinatal depression. The final best estimates are shown in Table 8 for major and minor depression together and in Table 9 for major depression alone.

Table 8. Best estimates of prevalence and incidence of major and minor depression

Start Date | End Date | Studies | Estimate | 95% Confidence Interval | P-Value for Test of Homogeneity
Point Prevalence
| 1st trimester | 40,41 | 11.0% | 7.6%–15.8% | 0.383
| 2nd trimester | 19,36,41,53 | 8.5% | 6.6%–10.9% | 0.921
| 3rd trimester | 36,40,41,46,47 | 8.5% | 6.5%–11.0% | 0.235
| 1 week PP | 40 | 5.5% | 1.8%–12.4%
| 1 month PP | 23,36,40,42,47,50 | 9.7% | 7.7%–12.3% | 0.060
| 2 months PP | 31,35,43,49,53 | 10.6% | 8.7%–13.0% | 0.121
| 3 months PP | 41,42,47,50 | 12.9% | 10.6%–15.8% | 0.707
| 4 months PP | 47 | 10.6% | 7.3%–14.7%
| 5 months PP | 47 | 10.6% | 7.3%–14.7%
| 6 months PP | 20 | 9.9% | 6.4%–14.5%
| 7 months PP | 41,47 | 10.6% | 7.1%–15.6% | 0.180
| 8 months PP | 47 | 6.5% | 4.0%–9.9%
| 12 months PP | 41 | 6.5% | 2.7%–12.9%
Period Prevalence
Conception | 2nd trimester | 30 | 9.3% | 3.1%–20.3%
Conception | Birth | 30,39,41 | 18.4% | 14.3%–23.3% | 0.931
2nd trimester | 3rd trimester | 36 | 10.2% | 7.0%–14.2%
Birth | 1 month PP | 50 | 13.6% | 7.3%–22.6%
Birth | 2 months PP | 19,45 | 9.6% | 8.0%–11.4% | 0.362
Birth | 3 months PP | 30,50,51 | 19.2% | 10.7%–31.9% | 0.016
Birth | 5 months PP | 34 | 29.1% | 20.6%–38.9%
Birth | 6 months PP | 20 | 13.8% | 9.6%–18.9%
Birth | 8 months PP | 47 | 20.8% | 16.3%–25.9%
Birth | 12 months PP | 30 | 53.7% | 39.6%–67.4%
Incidence
Conception | 1st trimester | 39,41 | 11.3% | 7.8%–16.3% | 0.757
Conception | 2nd trimester | 30 | 5.8% | 1.2%–16.0%
Conception | Birth | 30,39 | 14.5% | 8.1%–24.4% | 0.192
1st trimester | 2nd trimester | 41 | 2.7% | 0.6%–7.6%
2nd trimester | 3rd trimester | 36,41 | 2.2% | 1.1%–4.1% | 0.627
Birth | 1 month PP | 36,42,50 | 7.8% | 3.6%–16.1% | 0.003
Birth | 2 months PP | 19 | 10.3% | 5.1%–18.1%
Birth | 3 months PP | 30,41,42,50,51 | 14.5% | 10.9%–19.2% | 0.142
Birth | 6 months PP | 20 | 11.1% | 7.3%–16.0%
Birth | 12 months PP | 30 | 49.0% | 34.4%–63.7%

NOTE: Best estimates reflect the single or combined estimate at each point or period of time remaining after estimates with obvious, identifiable biases have been dropped.

PP, postpartum.

Table 9. Best estimates of prevalence and incidence of major depression

Start Date | End Date | Studies | Estimate | 95% Confidence Interval | P-Value for Test of Homogeneity
Point Prevalence
| 1st trimester | 40,41 | 3.8% | 1.0%–12.6% | 0.092
| 2nd trimester | 19,48,53 | 4.9% | 3.1%–7.4% | 0.752
| 3rd trimester | 40,46,47 | 3.1% | 1.1%–8.1% | 0.038
| 1 week PP | 40 | 0.0% | 0.0%–3.2%
| 1 month PP | 40,42,47,50 | 3.8% | 2.2%–6.4% | 0.204
| 2 months PP | 31,35,43,48,49,53 | 5.7% | 3.8%–8.7% | 0.001
| 3 months PP | 41,42,47,50,52 | 4.7% | 3.6%–6.1% | 0.658
| 4 months PP | 47 | 2.4% | 1.0%–4.9%
| 5 months PP | 47 | 2.1% | 0.8%–4.4%
| 6 months PP | 20,52 | 5.6% | 2.4%–12.1% | 0.028
| 7 months PP | 47 | 3.1% | 1.4%–5.8%
| 8 months PP | 47 | 1.0% | 0.2%–3.0%
| 12 months PP | 52 | 3.9% | 2.3%–6.1%
Period Prevalence
Conception | Birth | 39 | 12.7% | 7.1%–20.4%
1st trimester | Birth | 48 | 9.4% | 4.9%–15.8%
Birth | 1 month PP | 50 | 5.7% | 1.9%–12.8%
Birth | 2 months PP | 19 | 8.1% | 3.6%–15.3%
Birth | 3 months PP | 50,51 | 7.1% | 4.1%–11.7% | 0.626
Birth | 5 months PP | 34 | 12.6% | 6.9%–20.6%
Birth | 6 months PP | 20 | 6.5% | 3.7%–10.4%
Birth | 8 months PP | 47 | 6.8% | 4.2%–10.4%
Birth | 12 months PP | 48 | 21.9% | 15.1%–30.0%
Incidence
Conception | Birth | 30,39,48 | 7.5% | 3.8%–14.2% | 0.116
Birth | 1 month PP | 42,50 | 5.2% | 3.1%–8.9% | 0.819
Birth | 2 months PP | 48 | 8.1% | 4.0%–14.4%
Birth | 3 months PP | 42,50,51 | 6.5% | 4.2%–9.6% | 0.767
Birth | 12 months PP | 30 | 30.6% | 18.3%–45.4%

NOTE: Best estimates reflect the single or combined estimate at each point or period of time remaining after estimates with obvious, identifiable biases have been dropped.

PP, postpartum.

Point Prevalence. We show the best estimates for the point prevalence of major and minor depression graphically in Figure 9. This figure graphs the mean estimate and corresponding 95% CI for each trimester of pregnancy and month postpartum in the first year following delivery. The number of studies that we used to compute the estimate and the P-value for the Q test of homogeneity among the studies are shown above each estimate. For points in time for which no numbers are shown, we found only a single estimate.

Figure 9. Best estimates of point prevalence of major and minor depression

As shown in Figure 9, prevalence in the first trimester is 11.0 percent but drops to 8.5 percent in the second and third trimesters. Following delivery, prevalence of major and minor depression begins to rise and is highest in the third month at 12.9 percent. In the fourth through seventh month postpartum, prevalence declines slightly, staying in the range of 9.9 percent to 10.6 percent, after which it declines to 6.5 percent. However, all of these estimates have broad 95% CIs, suggesting that a considerable amount of uncertainty remains in the precise values of the estimates and that the differences in the estimates over time may be attributed to chance or to uncontrolled factors. We cannot say with certainty from these data that perinatal depression is higher at any particular trimester during pregnancy or month in the first postpartum year.

The best estimates for the point prevalence of major depression alone (Figure 10) are more variable and no more precise than those for major and minor depression together. Episodes of major depression comprise less than half of all cases of depression in the perinatal period, except during three seemingly peak times. As shown in Figure 10, the prevalence of major depression is highest in the second trimester (4.9 percent), 2 months postpartum (5.7 percent), and 6 months postpartum (5.6 percent). However, the 95% CIs for these estimates are very wide and overlap those at other times. Thus, we cannot say with certainty that major depression peaks at these points in time. Furthermore, the tests for homogeneity show that considerable heterogeneity persists among studies in the combined estimates.

FIgure 10. Best estimates of point prevalence of major depression

Period Prevalence. The many fewer estimates of period prevalence allow us to say little about the period prevalence for major and minor depression. As shown in Tables 8 and 9, the best estimates suggest that as many as 18.4 percent of pregnant women are depressed during their pregnancy (i.e., from conception to birth), with as many as 12.7 percent having an episode of major depression. Furthermore, as many as 19.2 percent of new mothers may have major or minor depression in the first 3 months following delivery (Table 8), with as many as 7.1 percent having major depression (Table 9).

However, all estimates have wide 95% CIs. Moreover, as shown in Figure 11, the best estimates of different durations are not consistent over longer periods of time. We would expect the period prevalence for major and minor depression from birth to 2 months postpartum to be higher than the period prevalence from birth to 1 month postpartum and the period prevalence for major depression from birth to 3 months postpartum to be higher than the period prevalence from birth to 2 months postpartum, but we do not see these patterns.

Figure 11. Best estimates of period prevalence of depression

Incidence. We also found few estimates of the incidence of depression—the percentage of women with depressive episodes that begin during pregnancy or the first year postpartum. The studies we found suggest that as many as 14.5 percent of pregnant women have a new episode of major or minor depression during pregnancy, and 14.5 percent have a new episode during the first 3 months postpartum (Table 8). Considering major depression alone, 7.5 percent of women may have a new episode during pregnancy and 6.5 percent during the first 3 months after delivery (Table 9). Figure 12 shows that, although the incidence estimates for major and minor depression in the first 3 months postpartum follow the expected upward trend, the incidence estimates of major depression alone do not.

Figure 12. Best estimates of incidence of major and minor depression

### Analysis of Confounders

The results of the cumulative meta-analysis are graphed in Figure 13. They clearly show the impact of the more precise diagnostic criteria in more recent studies. For both major and minor depression together (left panel) and major depression alone (right panel), the cumulative combined 2-month point prevalence estimate drifts downward as more recent studies are added. Thus, the more precise criteria in the more recent studies identify fewer women as depressed. However, we did not find a statistically significant effect of the year of publication in our meta-regression.

Figure 13. Cumulative meta-analysis for point prevalence of depression at 2 months postpartum

We provide the estimated coefficients, their standard errors, and P-values from the different meta-regression models in Table 10 for major and minor depression together and in Table 11 for major depression alone. We have bolded coefficients significantly different from zero at the α = 0.05 level. The results for major and minor depression show large, positive coefficients for the 2-month postpartum and 3-month postpartum time periods compared to the 4- to 12-month postpartum period (Table 10). These findings suggest a higher prevalence of depression during these 2 months. However, the coefficients are both significant only in the equation that includes diagnostic criteria (Model 5, Table 10). The 2-month postpartum time period is also large and positive for major depression alone, but significant only in the equations including diagnostic criteria (Model 5, Table 11) and whether only women who screened positive for depression were interviewed (Model 6, Table 11). None of the coefficients for the trimesters of pregnancy is statistically significant, suggesting that the prevalence of depression during pregnancy is similar to that during the last three quarters of the first postpartum year.

Table 10. Meta-regression results for log odds of a diagnosis of major and minor depression

Explanatory Variables | Model
| 1 | 2 | 3 | 4 | 5 | 6 | 7
Constant | -2.291 (0.149) | -2.159 (0.174) | -2.564 (0.339) | -2.189 (0.218) | -2.273 (0.098) | -2.276 (0.151) | -2.125 (0.626)
| P = 0.000 | P = 0.000 | P = 0.000 | P = 0.000 | P = 0.000 | P = 0.000 | P = 0.001
1st trimester vs. | 0.065 (0.322) | 0.068 (0.316) | 0.064 (0.337) | 0.032 (0.310) | 0.064 (0.238) | 0.056 (0.324) | 0.042 (0.336)
4 to 12 months PP | P = 0.840 | P = 0.830 | P = 0.850 | P = 0.917 | P = 0.788 | P = 0.863 | P = 0.901
2nd trimester vs. | 0.080 (0.244) | 0.029 (0.242) | 0.182 (0.274) | -0.004 (0.260) | 0.012 (0.166) | 0.091 (0.246) | 0.065 (0.252)
4 to 12 months PP | P = 0.744 | P = 0.903 | P = 0.508 | P = 0.989 | P = 0.943 | P = 0.711 | P = 0.798
3rd trimester vs. | -0.014 (0.229) | -0.011 (0.224) | -0.009 (0.235) | -0.065 (0.226) | -0.075 (0.156) | -0.007 (0.230) | -0.028 (0.237)
4 to 12 months PP | P = 0.953 | P = 0.960 | P = 0.971 | P = 0.775 | P = 0.630) | P = 0.976 | P = 0.904
1 month PP vs. | -0.115 (0.222) | -0.033 (0.226) | -0.109 (0.242) | -0.029 (0.237) | 0.147 (0.160) | -0.054 (0.240) | -0.120 (0.226)
4 to 12 months PP | P = 0.606 | P = 0.883 | P = 0.652 | P = 0.902 | P = 0.357 | P = 0.822 | P = 0.594
2 months PP vs. | 0.336 (0.211) | 0.426 (0.216) | 0.379 (0.223) | 0.404 (0.226) | 0.377 (0.167) | 0.361 (0.214) | 0.323 (0.219)
4 to 12 months PP | P = 0.110 | P = 0.049 | P = 0.089 | P = 0.073 | P = 0.024 | P = 0.092 | P = 0.139
3 months PP vs. | 0.346 (0.255) | 0.400 (0.252) | 0.339 (0.273) | 0.425 (0.245) | 0.377 (0.175) | 0.354 (0.256) | 0.342 (0.258)
4 to 12 months PP | P = 0.175 | P = 0.113 | P = 0.214 | P = 0.082 | P = 0.031 | P =00.167 | P = 0.185
Low risk | -1.436 (0.271) | -1.494 (0.271) | -1.195 (0.389) | -1.529 (0.269) | -1.230 (0.195) | -1.474 (0.277) | -1.457 (0.278)
| P = 0.000 | P = 0.000 | P = 0.002 | P = 0.000 | P = 0.000 | P = 0.000 | P = 0.000
Low SES | 0.753 (0.204) | 0.818 (0.204) | 0.988 (0.331) | 0.772 (0.192) | 1.083 (0.149) | 0.737 (0.206) | 0.774 (0.219)
| P = 0.000 | P = 0.000 | P = 0.003 | P = 0.000 | P = 0.000 | P = 0.000 | P = 0.000
Publication year | — | -0.018 (0.013) | — | — | — | — | —
| | P = 0.170
Other western countries vs. US | — | — | 0.273 (0.305) | — | — | — | —
| | | P = 0.371
Asian countries vs. US | — | — | 0.285 (0.349) | — | — | — | —
| | | P = 0.414
SCID vs. SADS | — | — | — | -0.489 (0.202) | — | — | —
| | | | P = 0.015
Other interview type vs. SADS | — | — | — | -0.098 (0.174) | — | — | —
| | | | P = 0.574
DSM III-R vs. RDC | — | — | — | — | -0.113 (0.188) | — | —
| | | | | P = 0.548
DSM IV vs. RDC | — | — | — | — | -0.381 (0.190) | — | —
| | | | | P = 0.045
Other diagnostic criteria vs. RDC | — | — | — | — | -1.487 (0.268) | — | —
| | | | | P = 0.000
Interviewed women with positive screens only vs. all | — | — | — | — | — | -0.096 (0.140) | —
| | | | | | P = 0.490
Quality score | — | — | — | — | — | — | -0.014 (0.051)
| | | | | | | P = 0.783

Notes: Estimated coefficients are shown along with their standard errors in parentheses and the P -value for a test of statistically significant differences from zero. P-values shown in bold type are significant at the < 0.05 level.

DSM III-R, Diagnostic and Statistical Manual of Mental Disorders, Third Edition; DSM IV, Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition; PP, postpartum; RDC, Research Diagnostic Criteria; SADS, Schedule for Affective Disorders and Schizophrenia; SCID, Structured Clinical Interview for DSM-IV; SES, socioeconomic status.

Table 11. Meta-regression results for log odds of a diagnosis of major depression

Explanatory Variables | Model
| 1 | 2 | 3 | 4 | 5 | 6 | 7
Constant | -3.206 (0.209) | -3.299 (0.272) | -3.447 (0.515) | -3.010 (0.373) | -3.419 (0.191) | -3.454 (0.239) | -1.677 (0.871)
| P = 0.000 | P = 0.000 | P = 0.000 | P = 0.000 | P = 0.000 | P = 0.000 | P = 0.054
1st trimester vs. | 0.052 (0.516) | 0.033 (0.523) | -0.180 (0.558) | -0.086 (0.558) | 0.271 (0.447) | 0.278 (0.512) | -0.085 (0.514)
4 to 12 mos PP | P = 0.920 | P = 0.950 | P = 0.747) | P = 0.877 | P = 0.545 | P = 0.587 | P = 0.868
2nd trimester vs. | 0.375 (0.384) | 0.424 (0.399) | 0.471 (0.466) | 0.245 (0.444) | 0.517 (0.315) | 0.634 (0.392) | 0.339 (0.376)
4 to 12 mos PP | P = 0.329 | 0.288 | P = 0.312 | P = 0.582 | P = 0.101 | P = 0.105 | P = 0.368
3rd trimester vs. | -0.272 (0.410) | -0.277 (0.415) | -0.372 (0.426) | -0.351 (0.436) | -0.052 (0.354) | -0.012 (0.417) | -0.379 (0.406)
4 to 12 mos PP | P = 0.507 | P = 0.503 | P = 0.382 | P = 0.421 | P = 0.883 | P = 0.976 | P = 0.350
1 month PP vs. | 0.021 (0.356) | -0.033 (0.377) | -0.185 (0.409) | -0.168 (0.415) | -0.073 (0.290) | 0.060 (0.342) | 0.035 (0.349)
4 to 12 mos PP | P = 0.954 | P = 0.929 | P = 0.651 | P = 0.686 | P = 0.800 | P = 0.861 | P = 0.920
2 mos PP vs. | 0.557 (0.291) | 0.533 (0.300) | 0.538 (0.304) | 0.377 (0.356) | 0.573 (0.257) | 0.613 (0.279) | 0.465 (0.289)
4 to 12 mos PP | P = 0.056 | P = 0.076 | P = 0.077 | P = 0.290 | P = 0.026 | P = 0.028 | P = 0.107
3 mos PP vs. | 0.231 (0.342) | 0.228 (0.347) | 0.097 (0.364) | 0.139 (0.364) | 0.159 (0.273) | 0.279 (0.328) | 0.180 (0.336)
4 to 12 mos PP | P = 0.499 | 0.510 | P = 0.791 | P = 0.703 | P = 0.561 | P = 0.395 | P = 0.592
Low risk | -1.501 (0.671) | -1.436 (0.687) | -1.045 (0.822) | -1.537 (0.695) | -1.340 (0.609) | -1.384 (0.658) | -1.915 (0.702)
| P = 0.025 | P = 0.036 | P = 0.204 | P = 0.027 | P = 0.028 | P = 0.036 | P = 0.006
Low SES | 0.459 (0.323) | 0.428 (0.333) | 0.759 (0.497) | 0.379 (0.345) | 0.498 (0.262) | 0.432 (0.308) | 0.636 (0.331)
| P = 0.155 | P = 0.199 | P = 0.126 | P = 0.273 | P = 0.057 | P = 0.161 | P = 0.054
Publication year | — | 0.010 (0.020) | — | — | — | — | —
| | P = 0.604
Other western countries vs. US | — | — | 0.238 (0.470) | — | — | — | —
| | | P = 0.612
Asian countries vs. US | — | — | 0.602 (0.533) | — | — | — | —
| | | P = 0.258
SCID vs. SADS | — | — | — | 0.112 (0.332) | — | — | —
| | | | P = 0.736
Other interview type vs. SADS | — | — | — | -0.201 (0.306) | — | — | —
| | | | P = 0.511
DSM III-R vs. RDC | — | — | — | — | 0.815 (0.241) | — | —
| | | | | P = 0.001
DSM IV vs. RDC | — | — | — | — | -0.198 (0.356) | — | —
| | | | | P = 0.578
Other diagnostic criteria vs. RDC | — | — | — | — | 0.414 (0.218) | — | —
| | | | | P = 0.058
Interviewed women with positive screens only vs. all | — | — | — | — | — | 0.441 (0.222) | —
| | | | | | P = 0.047
Quality score | — | — | — | — | — | — | -0.132 (0.073)
| | | | | | | P = 0.072

Notes: P-values shown in bold type are significant at the < 0.05 level.

DSM III-R, Diagnostic and Statistical Manual of Mental Disorders, Third Edition; DSM IV, Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition; PP, postpartum; RDC, Research Diagnostic Criteria; SADS, Schedule for Affective Disorders and Schizophrenia; SCID, Structured Clinical Interview for DSM-IV; SES, socioeconomic status.

The low-risk indicator has a statistically significant, negative coefficient for both sets of diagnoses, as expected (Tables 10 and 11). Low SES has a statistically significant, positive coefficient only for major and minor depression together (Table 10). The latter result suggests that the prevalence of major depression is similar among SES groups but that minor depression may be more prevalent among lower SES groups.

The meta-regression results also suggest that prevalence can vary by the clinical instrument and diagnostic criteria used to assess depression. The SCID instrument defined fewer women with major and minor depression than did the SADS interview (Table 10), but the coefficient for this variable is not significant in the equation for major depression alone (Table 11), suggesting that the difference is in the identification of women with minor depression. DSM-IV and other diagnostic criteria (e.g., Pitt, ICD-9) defined fewer women as depressed than did the RDC in the equation for major and minor depression (Table 10), and DSM-III-R and other criteria defined significantly more women as suffering from major depression than did the RDC (Table 11).

Finally, studies with higher quality rating scores have lower log odds, suggesting lower prevalence of depression, but the coefficient of this variable is only marginally significant (P = 0.072) in the equation for major depression alone (Model 7, Table 11) and is not significant in the equation for major and minor depression together (Model 7, Table 10). No statistically significant results were found for study country or whether the study interviewed only women who screened positive for depression, although the signs of the coefficients for these variables are as predicted.

### Comparison with Other Women

The three prospective studies with comparison groups of women of similar age in nonchildbearing periods had adequate data to compute 13 estimates of the relative prevalence and incidence of depression. The estimated odds ratios and corresponding 95% CIs are shown in Table 12.

Table 12. Odds ratios for studies with comparison groups of women during nonchildbearing periods

Diagnosis Estimate Type Author, Year | Time Period | Odds Ratio | 95% Confidence Interval
Major and Minor Depression
Point
O'Hara et al., 1990 ^53^ | 2nd trimester | 1.41 | 0.61–3.26
O'Hara et al., 1990 ^53^ | 9 weeks PP | 1.37 | 0.67–2.83
Cox et al., 1993 ^20^ | 6 months PP | 1.00 | 0.54–1.84
Period
Cox et al., 1993 ^20^ | Birth to 6 months PP | 1.04 | 0.61–1.76
Incidence
Cox et al., 1993 ^20^ | Birth to 5 weeks PP | 3.26* | 1.17–9.06
Cox et al., 1993 ^20^ | Birth to 6 months PP | 1.48 | 0.77–2.82
Major Depression
Point
O'Hara et al., 1990 ^53^ | 2nd trimester | 1.28 | 0.47–3.51
O'Hara et al., 1990 ^53^ | 9 weeks PP | 1.33 | 0.45–3.90
Cooper et al., 1988 ^52^ | 3 months PP | 0.85 | 0.33–2.17
Cox et al., 1993 ^20^ | 6 months PP | 1.00 | 0.37–2.71
Cooper et al., 1996 ^33^ | 6 months PP | 1.53 | 0.65–3.58
Cooper et al., 1996 ^33^ | 12 months PP | 0.50 | 0.17–1.46
Period
Cox et al., 1993 ^20^ | 6 months PP | 1.16 | 0.54–2.51

* Statistically significant at P < 0.05.

PP, postpartum.

None of the odds ratios for prevalence, which covered different time periods in the first postpartum year, indicated a statistically significant difference. In addition, the National Comorbidity Survey fielded in 1990-1992 found a 5.9 percent current 30-day prevalence of major depressive episodes among women ages 15 to 54 years using the CIDI instrument and DSM-III-R criteria. ^68^ This finding is approximately equivalent to our best 1-month postpartum period prevalence of 5.7 percent and to the point prevalence at 2 months and 6 months postpartum (5.7 percent and 5.6 percent, respectively) shown in Table 9. Thus, the evidence indicates no difference in the prevalence of postpartum depression among pregnant or newly delivered women and women at other times in their childbearing years.

The single estimate of the incidence of major and minor depression (Table 12) shows a significant 3-fold difference in the odds of having a new episode of major or minor depression among women in their first 5 weeks postpartum compared to women who were not pregnant and had not recently given birth. ^20^ However, by 6 months postpartum, the difference in the incidence had narrowed and was no longer significant (Table 12).

### Results from Retrospective Studies

The prevalence estimates from the retrospective studies measure something different than the prospective studies. In the prospective studies, all study women recruited from prenatal clinics or maternity wards were screened and interviewed for depression. Thus, all (or nearly all) women with depression in the populations so defined are identified. In the retrospective studies, only those women with depression detected through the course of medical contacts during the year were identified.

The two retrospective studies that met our inclusion criteria provided estimates of the period prevalence of major depression in the first postpartum year. The first study conducted in 1993 found that 1.2 percent of postpartum women in Olmsted County, Minnesota, had a major depressive episode during their first postpartum year and that 2.5 percent had a major or minor episode. ^54^ These rates are significantly below the 3-month period prevalence of 7.1 percent for major depression alone and the 19.2 percent for major and minor depression reported in Tables 8 and 9.

In 1997-1998, universal screening for depression with the EPDS at the 6-week postpartum visit was implemented in Olmsted County. As a result, the prevalence of a diagnosis of major depression among postpartum women rose to 10.7 percent, suggesting that the screening score posted in medical charts led clinicians to become more aware of their patients' mental state. ^55^

## Discussion

We found 30 studies providing estimates of the prevalence of perinatal depression but only 13 providing estimates of the incidence of the disorder. The studies were generally of moderate size—too small for reliable subgroup analyses. Furthermore, the study populations were typically restricted to a local community or geographic region served by one provider or a small number of providers of obstetrical services and were not representative of the racial and ethnic mix of the countries in which the studies were conducted. Other confounders included the risk status of women at study entry, their socioeconomic status, the interview methods, and the diagnostic criteria used to identify cases.

Combining point prevalence estimates of depression assessed at the same point in time and distinguishing whether they included minor depression, we found that the best estimates of the point prevalence of major and minor depression ranged from 8.5 percent to 11.0 percent at different times during pregnancy and from 6.5 percent to 12.9 percent at different times during the first year postpartum. Including only major depression, the best point prevalence estimates ranged from 3.1 percent to 4.9 percent at different times during pregnancy and from 1.0 percent to 5.9 percent at different times during the first postpartum year.

Period prevalence estimates show that as many as 19.2 percent of women have a depressive episode during the first 3 months postpartum, with as many as 7.1 percent having a major depressive episode during this time. Most of these episodes began following delivery. Incidence estimates show that, during the same 3-month period, 14.5 percent of women had a new depressive episode with as many as 6.5 percent having a major depressive episode. However, all of these estimates have wide 95% CIs, indicating that the amount of uncertainty in their precise values is considerable.

Our best estimates of prevalence and incidence were somewhat lower than those found in prior systematic reviews because we excluded studies that assessed depression based on self-report screens alone, which tend to overestimate prevalence. In addition, we separate out estimates of major and minor depression from estimates of major depression alone and estimates of point prevalence from estimates of period prevalence. Finally, we include more recent studies that use more precise criteria to identify major depression.

We found that the available evidence does not support the hypothesis that the prevalence of depression is higher during pregnancy or in the first year postpartum compared to nonchildbearing times. A single study suggested that the incidence of new depressive episodes (major and minor) is greater in the first 5 weeks postpartum than at other times. ^20^

Nevertheless, pregnancy and the early postpartum period provide opportunities to screen for depression through regular prenatal and postpartum physician contacts. Because the poor outcomes of suffering from depression during the perinatal period can be farther reaching—affecting not only the woman but her newborn child and other family members—it behooves us to investigate the efficacy of screening and treatment programs for these women.