# Introduction

Depressive disorders are ubiquitous and remarkably impairing; they occur throughout the lifespan. Lifetime prevalence rates of depression from community-based surveys range from 4.9 percent to 17.1 percent. ^1–3^ Gender plays an important role in the prevalence rates of depression; women report a history of major depression at nearly twice the rate of men. ^4^ In particular, women of childbearing age are at high risk for major depression. ^2,^ ^3,^ ^5^ Pregnancy and new motherhood may increase the risk of depressive episodes.

Depression is the leading cause of disease-related disability among women in the world. ^6^ It can have devastating consequences, not only for the women experiencing it but also for the women's children and family. ^7–9^ For example, Stein and colleagues found that the mother-child interactions of depressed mothers and their children were of lower quality than those of nondepressed mothers, ^10^ and Flynn et al. found that maternal depression was related to both missed pediatric appointments and greater use of emergency department services. ^11^ A review of other research in this area points out that parental depression has been linked to raised levels of psychiatric disturbances among children and to greater child insecurity in attachment relationships. ^7,^ ^8^

The importance of detecting and treating perinatal depression has only recently been recognized. Perinatal depression encompasses major and minor depressive episodes that occur either during pregnancy or within the first 12 months following delivery. Major depression is a distinct clinical syndrome for which treatment is clearly indicated, ^12^ whereas the definition and management of minor depression are less clear. Minor depression is an impairing yet less severe constellation of depressive symptoms ^13^ for which controlled trials have not consistently indicated whether particular interventions are more effective than placebo. ^14,^ ^15^ In this report, we address major depressive episodes alone, which we refer to as major depression, as well as a broader grouping of major or minor depression, which we refer to as such or by the more general terms “depression” or “depressive illness.” We necessarily rely on the specific definitions of minor depression used by the different authors of the reviewed studies.

Another mental disorder that can occur in the perinatal period is postpartum psychosis. Unlike postpartum depression, postpartum psychosis is a relatively rare event with an estimated incidence of 1.1 to 4.0 cases per 1,000 deliveries. ^16^ The onset of postpartum psychosis is usually acute, within the first 2 weeks of delivery, and appears to be more common in women with a strong family history of bipolar or schizoaffective disorder. ^17^ Postpartum psychosis is an important disorder in its own right, but it is not addressed specifically in this report.

Perinatal depression, major or minor, often goes unrecognized because many of the discomforts of pregnancy and the puerperium are similar to symptoms of depression. ^18,^ ^19^ The onset of major depression is believed to be impressively common in the postpartum period; researchers have found a 3-fold increase in the onset of major or minor depression in the first 5 weeks postpartum compared to women of similar age, marital status, and parity at nonchildbearing times. ^20^ However, the precise levels of the prevalence and incidence of perinatal depression are uncertain. Published estimates of the rate of major or minor depression in the postpartum period range widely—from 5 percent to more than 25 percent of new mothers—depending on the assessment method, the timing of the assessment, and population characteristics. ^21–23^

Although many screening instruments have been developed or modified to detect major or minor depression in pregnant and newly delivered women , the evidence on their screening accuracy relative to a reference standard has yet to be systematically reviewed and assessed. ^24^ Evidence on the effectiveness of screening all pregnant women and providing a preventive intervention to those scoring at high risk has also not been systematically investigated and evaluated. ^24^

To address these gaps, the Agency for Healthcare Research and Quality (AHRQ) in collaboration with the Safe Motherhood Group (SMG) commissioned the RTI International-University of North Carolina (RTI-UNC) Evidence-based Practice Center (EPC) to conduct a systematic evidence review on three questions related to perinatal depression. These questions (provided in Table 1) address the prevalence and incidence of perinatal depression, the accuracy of screening instruments for perinatal depression, and the effectiveness of interventions for women who are found to be at high risk for developing perinatal depression.

Table 1. Key questions for the evidence report on perinatal depression

Key Question
1 | What is the incidence and prevalence of depression (major or minor) during pregnancy and during the postpartum period? Is it increased during pregnancy and the postpartum period compared to nonchildbearing periods?
2 | What is the accuracy of different screening tools for detecting depression during pregnancy and the postpartum period?
3 | Does prenatal or early postnatal screening for depressive symptoms with subsequent intervention lead to improved outcomes?

We show a simple schematic of the causal pathway for the screening and treatment of perinatal depression and the links addressed by the three study questions in Figure 1. For all three questions, we begin with a general population of pregnant or postpartum women. The first key question addresses the percentage of this population diagnosed with depression at various points and periods of time throughout pregnancy and the first postpartum year—that is, the prevalence and incidence of the disorder. Prevalence and incidence can be measured in different ways and may vary by population characteristics. We synthesize available evidence on prevalence and incidence measured in a similar manner at or over the same general period of time and analyze the impact of selected population and study characteristics. Studies with a comparison group of women of similar age during nonchildbearing periods are also reviewed to determine whether the prevalence or incidence of depression increases during pregnancy and the first postpartum year.

Figure 1. Causal pathway for the screening and treatment of perinatal depression

The second key question addresses the accuracy of different screening instruments for postpartum depression—that is, how well different instruments detect pregnant or postpartum women who have depression (sensitivity) and pregnant and postpartum women who do not have depression (specificity). We identify and abstract English-language and non-English-language studies of various cutoff scores for a variety of commonly used instruments but review only the English-language studies.

Finally, we review studies that provide evidence on whether interventions can reduce the prevalence and incidence of perinatal depression for women who are screened and found to be at high risk for the disorder. We also summarize evidence in these studies on the effect of screening with subsequent intervention on other health outcomes for the woman and her infant. This third question addresses whether the screening process itself ultimately leads to improved outcomes for perinatal depression. Studies had to use some form of screening to identify women for testing interventions involving a technique to address psychological status in the woman and had to have an outcome measured related to depression severity.

In this report, we provide the results of our systematic search and review of the published literature for evidence addressing these questions. In conducting this study, our intent was to answer the questions using the most reliable evidence available, obtain a sense of the strength of the available evidence, and identify gaps in the knowledge base that require further research. We follow a discussion of our general approach and methods in Chapter 2 with discussions of each of the question-specific methods and findings (Chapters 3, 4, and 5). In Chapter 6, we discuss our main conclusions, comment on the state of the evidence, and offer an agenda for future research studies. Appendix A presents the exact search strings for the electronic database searches. Appendix B contains copies of our quality rating forms. Appendix C presents the evidence tables, Appendix D provides a list of excluded articles, and Appendix E provides acknowledgments.