# Appendix E. Acknowledgments

## Acknowledgments

This study was supported by Contract 290-02-0016 from the Agency for Healthcare Research and Quality (AHRQ), Task Order No. 4. We acknowledge the continuing support of Kenneth Fink, MD, MGA, MPH, Director of the AHRQ Evidence-Based Practice Center (EPC) Program, and Marian James, PhD, the AHRQ Task Order Officer for this project.

The investigators deeply appreciate the considerable support, commitment, and contributions of the EPC team staff at RTI International and the University of North Carolina (UNC). From UNC, we thank EPC Co-Director, Timothy S. Carey, MD, MPH; EPC Literature Search Specialist, B. Lynn Whitener, PhD; and Research Assistant Leah Randolph, MA. We also express our gratitude to Loraine Monroe, EPC word processing specialist, Debra Bost, EPC editor, and Kathleen Mohar, Manager, Publications Specialist Group at RTI International.

### Technical Expert Advisory Group

We extend our appreciation to the members of our Technical Expert Advisory Group (TEAG), who provided advice and input during our research process. The RTI-UNC EPC team solicited the views of TEAG members from the beginning of the project. TEAG members also provided insights into and reactions to work in progress and advice on substantive issues and overlooked areas of research. TEAG members participated in refining the analytic framework and key questions and discussing the preliminary assessment of the literature, including inclusion/exclusion criteria and methods for data synthesis. The TEAG was both a substantive resource and a “sounding board” throughout the study. It was also the body from which expertise was formally sought at several junctions. TEAG members are listed below:

- Jeffrey Kuller, MD
- Associate Professor
- Division of Maternal-Fetal Medicine
- Duke University Medical Center

- Michael W. O'Hara, PhD
- Professor
- University of Iowa

- Susan F. Meikle, MD, MSPH
- Center for Outcomes and Evidence
- Agency for Healthcare Research and Quality

- Katherine L. Wisner, MD, MS
- Director
- Women's Behavioral HealthCARE
- Professor of Psychiatry, Obstetrics and Gynecology and Reproductive Sciences and Epidemiology
- University of Pittsburgh Medical Center

### Peer Reviewers

We gratefully acknowledge the following individuals who reviewed the initial draft of this report and provided us with constructive feedback. External reviewers comprised clinicians, researchers, representatives of professional societies, and potential users of the report. We would also like to extend our appreciation to David Atkins, MD, MPH from AHRQ for contributing peer review comments. Our peer review panel also includes all members of the TEAG. Peer review was a separate duty for these individuals and not part of their commitment as TEAG members. All are active professionals in the field. The peer reviewers were asked to provide comments on the content, structure, and format of the evidence report and to complete a checklist. The peer reviewers' comments and suggestions formed the basis of our revisions to the evidence report. Acknowledgments are made with the explicit statement that this does not constitute endorsement of the report.

Individuals

- Cheryl Beck, DNSc, CNM, FAAN
- Professor
- School of Nursing
- University of Connecticut

- Diana Dell, MD, FACOG
- Women's Behavioral Health Program
- Department of Obstetrics and Gynecology
- Duke University Medical Center

- Judith Lumley, MD
- Centre for Mother's and Children's Health
- La Trobe University
- Carlton, Victoria, Australia

Organizations

- Shoshana Bennett, PhD
- Postpartum Support International

- Janet Chapin, RN, MPH
- American College of Obstetricians and Gynecologists

- Ruth Johnson, CNM
- American College of Nurse-Midwives

- Marlene Freeman, MD
- American Psychiatric Association

- Gwen Gjerdingen, MD, MS
- American Association of Family Physicians

- Sheila M. Marcus, MD
- American Psychiatric Association

- Laura J. Miller, MD
- American Psychiatric Association

- Darrel A. Regier, MD, MPH
- American Psychiatric Association

- Kimberly A. Yonkers, MD
- American Psychiatric Association