# Appendix D. Excluded Articles

Abramowitz J S, Schwartz S A, Moore K M, et al. Obsessive-compulsive symptoms in pregnancy and the puerperium: A review of the literature. J Anxiety Disord. 2003;17(4):461-78. [pmid: 12826092].
Affonso D D, Mayberry L J, Lovett S, et al. Pregnancy and postpartum depressive symptoms. J Womens Health. 1993;2(2):157-64.
Affonso D D, Arizmendi T G. Disturbances in post-partum adaptation and depressive symptomatology. J Psychosom Obstet Gynaecol. 1986;5(1):15-32.
Areias M E, Kumar R, Barros H, et al. Comparative incidence of depression in women and men, during pregnancy and after childbirth. Validation of the Edinburgh Postnatal Depression Scale in Portuguese mothers. Br J Psychiatry. 1996;169(1):30-5. [pmid: 8818365].
Areias M E, Kumar R, Barros H, et al. Correlates of postnatal depression in mothers and fathers. Br J Psychiatry. 1996;169(1):36-41. [pmid: 8818366].
Beck C T. Postpartum depression predictors inventory--revised. Adv Neonatal Care. 2003;3(1):47-8. [pmid: 12882181].
Beck C T. Recognizing and screening for postpartum depression in mothers of NICU infants. Adv Neonatal Care. 2003;3(1):37-46. [pmid: 12882180].
Beck C T, Gable R K. Comparative analysis of the performance of the Postpartum Depression Screening Scale with two other depression instruments. Nurs Res. 2001;50(4):242-50. [pmid: 11480533].
Beck C, Gable R. Postpartum depression screening scale: Spanish version. Nurs Res. 2003;52(5):296-306. [pmid: 14501544].
Beeghly M, Olson K L, Weinberg M K, et al. Prevalence, stability, and socio-demographic correlates of depressive symptoms in Black mothers during the first 18 months postpartum. Matern Child Health J. 2003;7(3):157-68. [pmid: 14509411].
Bijl R V, van Zessen G, Ravelli A. Psychiatric morbidity among adults in The Netherlands: The NEMESIS-Study. II. Prevalence of psychiatric disorders. Netherlands Mental Health Survey and Incidence Study. Ned Tijdschr Geneeskd. 1997;141(50):2453-60. [pmid: 9555131].
Brugha T S, Wheatley S, Taub N A, et al. Pragmatic randomized trial of antenatal intervention to prevent post-natal depression by reducing psychosocial risk factors. Psychol Med. 2000;30(6):1273-81. [pmid: 11097068].
Caravale B, Allemand F, Libenson M H. Factors predictive of seizures and neurologic outcome in perinatal depression. Pediatr Neurol. 2003;29(1):18-25. [pmid: 13679117].
Carro M G, Grant K E, Gotlib I H, et al. Postpartum depression and child development: An investigation of mothers. Dev Psychopathol. 1993;5(4):567-79.
Chan S, Levy V. Postnatal depression: A qualitative study of the experiences of a group of Hong Kong Chinese women. J Clin Nurs. 2004;13(1):120-3. [pmid: 14687304].
Cooper P J, Campbell E A, Day A, et al. Non-psychotic psychiatric disorder after childbirth. A prospective study of prevalence, incidence, course and nature. Br J Psychiatry. 1988;152:799-806. [pmid: 3167466].
Cooper P J, Murray L, Hooper R, et al. The development and validation of a predictive index for postpartum depression. Psychol Med. 1996;26(3):627-34. [pmid: 8733220].
Cox J L, Holden J M, Sagovsky R. Detection of postnatal depression. Development of the 10-item Edinburgh Postnatal Depression Scale. Br J Psychiatry. 1987;150:782-6. [pmid: 3651732].
Cutrona C E. Causal attributions and perinatal depression. J Abnorm Psychol. 1983;92(2):161-72. [pmid: 6863731].
Demyttenaere K, Lenaerts H, Nijs P, et al. Individual coping style and psychological attitudes during pregnancy and predict depression levels during pregnancy and during postpartum. Acta Psychiatr Scand. 1995;91(2):95-102. [pmid: 7778476].
Dennis C. Can we identify mothers at risk for postpartum depression in the immediate postpartum period using the Edinburgh Postnatal Depression Scale?. J Affect Disord. 2004;78(2):163-9. [pmid: 14706728].
Eberhard-Gran M, Tambs K, Opjordsmoen S, et al. A comparison of anxiety and depressive symptomatology in postpartum and non-postpartum mothers. Soc Psychiatry Psychiatr Epidemiol. 2003;38(10):551-6. [pmid: 14564383].
Edwards M, Waldorf M. Reclaiming Birth: History and heroines of American Childbirth Reform. 1984: The Crossing Press, 1984: 4–6.
Ellison M, Hall J. Social stigma and compounded losses: Quality-of-life issues for multiple-birth families. Fertil Steril. 2003;80(2):405-14. [pmid: 12909506].
Evins G G, Theofrastous J P, Galvin S L. Postpartum depression: A comparison of screening and routine clinical evaluation. Am J Obstet Gynecol. 2000;182(5):1080-2. [pmid: 10819833].
Feggetter G, Cooper P, Gath D. Non-psychotic psychiatric disorders in women one year after childbirth. J Psychosom Res. 1981;25(5):369-72. [pmid: 6977026].
Fergusson D M, Horwood L J, Thorpe K. Changes in depression during and following pregnancy. ALSPAC Study Team. Study of Pregnancy and Children. Paediatr Perinat Epidemiol. 1996;10(3):279-93. [pmid: 8822771].
Ghubash R, Abou-Saleh M T, Daradkeh T K. The validity of the Arabic Edinburgh Postnatal Depression Scale. Soc Psychiatry Psychiatr Epidemiol. 1997;32(8):474-6. [pmid: 9409163].
Gilman S E, Kawachi I, Fitzmaurice G M, et al. Family disruption in childhood and risk of adult depression. Am J Psychiatry. 2003;160(5):939-46. [pmid: 12727699].
Greene S M, Nugent J K, Wieczorek Deering D E, et al. The patterning of depressive symptoms in a sample of first-time mothers. Ir J Psychol. 1991;12(2):263-75.
Guedeney A, Doleans M C, Huot-Marchand M. Early screening of withdrawal reaction in the Maternal and Infant Welfare Protection program. Arch Pediatr. 2003;10(Suppl 1):131s-3s. [pmid: 14509771].
Guedeney N, Fermanian J, Guelfi J D, et al. The Edinburgh Postnatal Depression Scale (EPDS) and the detection of major depressive disorders in early postpartum: Some concerns about false negatives. J Affect Disord. 2000;61(12):107-12. [pmid: 11099748].
Harris B, Fung H, Johns S, et al. Transient postpartum thyroid dysfunction and postnatal depression. J Affect Disord. 1989;17(3):243-9. [pmid: 2529292].
Harris B, Johns S, Fung H, et al. The hormonal environment of post-natal depression. Br J Psychiatry. 1989;154:660-7. [pmid: 2597859].
Hobfoll S E, Ritter C, Lavin J, et al. Depression prevalence and incidence among inner-city pregnant and postpartum women. J Consult Clin Psychol. 1995;63(3):445-53. [pmid: 7608357].
Holt W J. The detection of postnatal depression in general practice using the Edinburgh postnatal depression scale. N Z Med J. 1995;108(994):57-9. [pmid: 7885649].
Honey K L, Bennett P, Morgan M. Predicting postnatal depression. J Affect Disord. 2003;76(13):201-10. [pmid: 12943950].
Kessler R C, McGonagle K A, Zhao S, et al. Lifetime and 12-month prevalence of DSM-III-R psychiatric disorders in the United States. Results from the National Comorbidity Survey. Arch Gen Psychiatry. 1994;51(1):8-19. [pmid: 8279933].
Kessler R C, Zhao S, Blazer D G, et al. Prevalence, correlates, and course of minor depression and major depression in the National Comorbidity Survey. J Affect Disord. 1997;45(12):19-30. [pmid: 9268772].
Kitamura T, Shima S, Sugawara M, et al. Psychological and social correlates of the onset of affective disorders among pregnant women. Psychol Med. 1993;23:967-75. [pmid: 8134520].
Kurki T HVRRMHYO. Depression and anxiety in early pregnancy and risk for preeclampsia. Obstet Gynecol. 2000;95(4):487-90. [pmid: 10725477].
Leavitt JW. Brought to Bed: Childbearing in America 1750 to 1950. New York: Oxford University Press, 179–86.
Lee D, Yip A, Chan S, et al. Postdelivery screening for postpartum depression. Psychosom Med. 2003;65(3):357-3361. [pmid: 12764207].
Leopold K, Zoschnick L. Postpartum depression. Female Pat. 1997;22:40-9.
Leverton TJ, Elliott SA. Transition to parenthood groups: A preventive intervention for perinatal depression? In: van Hall EV, Evereard W, eds. The free woman: woman's health in the 1990s. Invited papers of the 9th international conference of psychosomatic obstetrics and gynecology. Vol. 479–486. Lancaster, Pa: Parthenon Press, 1989.
McGill H, Burrows V L, Holland L A, et al. Postnatal depression: A Christchurch study. N Z Med J. 1995;108(999):162-5. [pmid: 7753510].
McKenry P C, Browne D H, Kotch J B, et al. Mediators of depression among low-income, adolescent mothers of infants: A longitudinal perspective. J Youth Adolescence. 1990;19(4):327-47.
McMahon C, Barnett B, Kowalenko N, et al. Postnatal depression, anxiety and unsettled infant behaviour. Aust N Z J Psychiatry. 2001;35(5):581-8. [pmid: 11551272].
Meager I, Milgrom J. Group treatment for postpartum depression: A pilot study. Aust N Z J Psychiatry. 1996;30(6):852-60. [pmid: 9034477].
Morris-Rush J K, Freda M C, Bernstein P S. Screening for postpartum depression in an inner-city population. Am J Obstet Gynecol. 2003;188(5):1217-9. [pmid: 12748483].
Muzik M, Klier C, Rosenblum K, et al. Are commonly used self-report inventories suitable for screening postpartum depression and anxiety disorders?. Acta Psychiatr Scand. 2000;102(1):71-3. [pmid: 10892613].
Neugebauer R. Rate of depression in the puerperium. Br J Psychiatry. 1983;143:421-2. [pmid: 6626863].
Nott P N. Extent, timing and persistence of emotional disorders following childbirth. Br J Psychiatry. 1987;151:523-7. [pmid: 3447669].
O'Hara ME, Zekoski EM. Postpartum depression, a comprehensive review. Motherhood and Mental Illness 2. Butterworth & Co. Ltd, 1988: 17–63.
Okano T, Nomura J, Kumar R, et al. An epidemiological and clinical investigation of postpartum psychiatric illness in Japanese mothers. J Affect Disord. 1998;48(23):233-40. [pmid: 9543214].
Owen P J, Lazarus J H. The treatment of post-partum thyroid disease. J Endocrinol Invest. 2003;26(4):290-1. [pmid: 12841533].
Peindl K S, Wisner K L. Successful recruitment strategies for women in postpartum mental health trials. J Psychiatr Res. 2003;37(2):117-25. [pmid: 12842165].
Pfost K S, Lum C U, Stevens M J. Femininity and work plans protect women against postpartum dysphoria. Sex Roles. 1989;21(56):423-31.
Philipps L H, O'Hara M W. Prospective study of postpartum depression: 4 1/2-year follow-up of women and children. J Abnorm Psychol. 1991;100(2):151-5. [pmid: 2040765].
Posmontier B, Horowitz J A. Postpartum practices and depression prevalences: Technocentric and ethnokinship cultural perspectives. J Transcult Nurs. 2004;15(1):34-43. [pmid: 14768414].
Posner N A, Unterman R R, Williams K N, et al. Screening for postpartum depression: An antepartum questionnaire. J Reprod Med. 1997;42:207-15. [pmid: 9131493].
Priest S R, Henderson J, Evans S F, et al. Stress debriefing after childbirth: A randomised controlled trial. Med J Aust. 2003;178(11):542-5. [pmid: 12765500].
Rahman A, Iqbal Z, Harrington R. Life events, social support and depression in childbirth: Perspectives from a rural community in the developing world. Psychol Med. 2003;33(7):1161-7. [pmid: 14580070].
Rees W D. Parental depression before and after childbirth. An assessment with the Beck Depression Inventory. J R Coll Gen Pract. 1971;21(102):26-31. [pmid: 5560492]. [pmcid: 2156256].
Schaper A, Rooney B, Kay N, et al. Use of the Edinburgh Postnatal Depression Scale to identify postpartum depression in a clinical setting. J Reprod Med. 1994;39(8):620-4. [pmid: 7996526].
Shakespeare J, Blake F, Garcia J. A qualitative study of the acceptability of routine screening of postnatal women using the Edinburgh Postnatal Depression Scale. Br J Gen Pract. 2003;53(493):614-9. [pmid: 14601337]. [pmcid: 1314675].
Sharp D J. Validation of the 30-item General Health Questionnaire in early pregnancy. Psychol Med. 1988;18(2):503-7. [pmid: 3399597].
Shimizu Y, Kaplan B. Postpartum depression in the United States and Japan. J Cross-Cultural Psychol. 1987;18(1):15-30.
Silver L. Postnatal depression: An overview. J Fam Health Care. 2003;13(6):144-5. [pmid: 14753116].
Teissedre F, Chabrol H. Detecting women at risk for postnatal depression using the Edinburgh Postnatal Depression Scale at 2 to 3 days postpartum. Can J Psychiatry. 2004;49(1):51-4. [pmid: 14763678].
Thorpe K, Dragonas T, Golding J. The effects of psychosocial factors on the mother's emotional well-being. J Reprod Infant Psychol. 1992;10(4):205.
Troutman B R, Cutrona C E. Nonspychotic post partum depression among adolescent mothers. J Abnorm Psychol. 1990;99:69-78. [pmid: 2307769].
Verkerk G J, Pop V J, Van Son M J, et al. Prediction of depression in the postpartum period: A longitudinal follow-up study in high-risk and low-risk women. J Affect Disord. 2003;77(2):159-66. [pmid: 14607393].
Wang S Y, Jiang X Y, Jan W C, et al. A comparative study of postnatal depression and its predictors in Taiwan and mainland China. Am J Obstet Gynecol. 2003;189(5):1407-12. [pmid: 14634578].
Webster J, Pritchard M, Creedy D, et al. A simplified predictive index for the detection of women at risk for postnatal depression. Birth. 2003;30(2):101-8. [pmid: 12752167].
Whiffen V E. Screening for postpartum depression: A methodological note. J Clin Psychol. 1988;44(3):367-71. [pmid: 3384962].
Whiffen V. Vulnerability of postpartum depression: A prospective multivariate study. J Abnorm Psychol. 1988;97(4):467-74. [pmid: 3204233].
Wickberg B, Hwang C. Counselling of postnatal depression: A controlled study on a population based Swedish sample. J Affect Disord. 1996;39(3):209-16. [pmid: 8856425].
Yonkers K A, Ramin S M, Rush A J, et al. Onset and persistence of postpartum depression in an inner-city maternal health clinic system. Am J Psychiatry. 2001;158(11):1856-63. [pmid: 11691692].