# Appendix C. Evidence Tables

## Perinatal Depression List of Acronyms

Adj | adjusted
B | Bedford
BDI | Beck Depression Inventory
BDI-II | Beck Depression Inventory - II
C | Catego
CCEI | Crown-Crisp Experiental Index
CES | Current Experience Scale
CES-D | Center for Epidemiological Studies - Depression Scale
CI | confidence interval
CIDI-A | Composite International Diagnostic Interview - Auto
Dept | department
DIS | diagnostic interview schedule
DMC | Dyadic Mutality Code
DSM-III | Diagnostic and Statistical Manual for Mental Disorders, Third Edition
DSM-III-R | Diagnostic and Statistical Manual for Mental Disorders, Third Edition - Revised
DSM-IV | Diagnostic and Statistical Manual for Mental Disorders, Fourth Edition
dx | diagnosis
EPDS | Edinburgh Postnatal Depression Scale
GA | gestational age
GHQ | General Health Questionnaire
GHQ-D | General Health Questionnaire - Depression
GP | general practitioner
GP/psych | general practitioner/psychiatrist
HDRS | Hamilton Depression Rating Scale
HMO | health maintenance organization
HOME | Home Observation for Measurement of Environment
hr(s) | hour(s)
HS | high school
ICD-9 | International Classification of Diseases, Ninth Edition
IDD-10 | International Classification of Disease, Tenth Edition
IDS | Inventory of Depressive Symptomology
LQ | Leverton Questionnaire
MAACL | Multiple Affect Adjective Check List
MADRS | Montgomery and Asberg Depression Rating Scale
MDE | major depressive episode
MINI | Mini International Neuropsychiatric Interview
MINI-V4.4 | Mini International Neuropsychiatric Interview, Version 4.4
mo(s) | month(s)
NA | not applicable
NICU | Neonatal Intensive Care Unit
No. | number
NPV | negative predictive value
NR | not reported
NS | not significant
Ob-Gyn | obstretrics and gynecology
OR | odds ratio
PAS | Psychiatric Assessment Schedule
PDSS | Postpartum Depression Screening Scale
PEG | Psycho Educational Group
PP | Postpartum
PPG | Postpartum Guidelines
PSE | Present State Examination
PSE-ID | Present State Examination - Index of Definition
RCT | randomized controlled trials
RDC | research diagnostic criteria
SADS | Schedule for Affective Disorders and Schizophrenia
SADS-C | Schedule for Affective Disorders and Schizophrenia - Change version
SADS-L | Schedule for Affective Disorders and Schizophrenia - Long
SCAN | Schedules for Clinical Assessment in Neuropsychiatry
SCID | Structured Clinical Interview for DSM-IV
SCID-German | Structured Clinical Interview for DSM-IV - German
SCIP-NP | Structured Clinical Interview for DSM-III-R - non-patient
SCLR-90 | Symptom checklist Revised - 1990
SD | standard deviation
Sensi | sensitivity
Speci | specificity
SIDS | Sudden Infant Death Syndrome
SPI | Standardized Psychiatric Interview
SRQ | self-reported questionnaire
TSH | thyroid stimulating hormone
UK | United Kingdom
Univ. | University
USA | United States of America
vs. | versus
wk(s) | week(s)
yr(s) | year(s)

Evidence Table1 . Key Question 1: Study design for studies of the prevalence and incidence of perinatal depression

Author, Year Quality rating | Study Characteristics | Population Description | Depression Measure | Type of Estimate | Time Period of Estimate | Diagnoses Included | Confounders | No. Depressed / Total No. (%)
Prospective Studies without Comparison Groups | | | | Prospective Cohort Studies without Comparison Groups
Author | Study design | Population | Diagnoses | Point | 10 to 14 wks GA | Major and minor | Low risk | 3/202 (1.5%)
Affonso et al., 1990 | Prospective cohort | Women recruited from 3 HMO clinics at their 1st prenatal care visit | Major and minor | | 10 to 14 wks GA | Major | Low risk | 2/202 (1.0%)
Quality rating | Sample size | Age | Interview subjects | | 30 to 32 wks GA | Major and minor | Low risk | 1/202 (0.5%)
8 | 202 women | Mean: 30 yrs | All study women | | 30 to 32 wks GA | Major | Low risk | 0/202 (0.0%)
| Place | Range: 20 to 40 yrs | Clinical instrument | | 1 to 2 wks PP | Major and minor | Low risk | 3/202 (1.5%)
| California | Race/ethnicity | SADS modified for PPG | | 1 to 2 wks PP | Major | Low risk | 2/202 (1.0%)
| | White: 76% | Diagnostic criteria | | 14 wks PP | Major and minor | Low risk | 3/202 (1.5%)
| | Black: 8% | RDC | | 14 wks PP | Major | Low risk | 0/202 (0.0%)
| | Asian: 6% | Interview times
| | Hispanic: 6% | 10 to 14 wks GA, 30 to 32 wks GA, 1 to 2 wks PP, and 14 wks PP
| | Other: 4%
| | Inclusion/exclusion criteria
| | Included: Primigravida, viable fetus, married or living with the infant's father, and no depression episode 12 mos prior to pregnancy.
| | Excluded: Those with a depression episode within the past 2 yrs if younger than 20 or within the past 5 yrs if over 20 and those undergoing therapy for 3 continuous mos
Author | Study design | Population | Diagnoses | New episode | During pregnancy | Major and minor | NR | 5/52 (9.6%)
Areias et al., 1996 | Prospective cohort | Pregnant women recruited from 2 prenatal clinics | Major, minor, and intermittent | | During pregnancy | Major | NR | 2/52 (3.8%)
Quality rating | Sample size | Age | Interview subjects | | 0 to 6 mos GA | Major and minor | Intermittent dx | 3/52 (5.8%)
12 | 54 women and 42 husbands/partners | Mean: 25 yrs | All study women | | 0 to 3 mos PP | Major and minor | NR | 12/49 (24.5%)
| Place | Range: 17 to 38 yrs | Clinical instrument | | 4 to 12 mos PP | Major and minor | NR | 12/46 (26.0%)
| Portugal | Race/ethnicity | SADS or SADS-L | | 0 to 12 mos PP | Major and minor | NR | 24/49 (49.0%)
| | NR | Diagnostic criteria | | 0 to 12 mos PP | Major | NR | 15/49 (30.6%)
| | Inclusion/exclusion criteria | RDC | Period | During pregnancy | Major and minor | Intermittent dx | 9/54 (16.7%)
| | Included: Primiparous women ≤ 24 wks GA at entry | Interview times | | 0 to 6 mos GA | Major and minor | Intermittent dx | 5/54 (9.3%)
| | Excluded: Women with inadequate education to complete the questionnaire | 6 mos GA and 12 mos PP. A subset of 24 women were also interviewed at 3 mos PP | | 0 to 3 mos PP | Major and minor | Intermittent dx | 17/54 (31.5%)
| | | | | 4 to 12 mos PP | Major and minor | Intermittent dx | 20/54 (37.0%)
| | | | | 0 to 12 mos PP | Major and minor | Intermittent dx | 29/54 (53.7%)
Author | Study design | Population | Diagnoses | Point | 6 to 12 wks PP | Major and minor | EPDS ≥ 9 | 41/411 (10.0%)
Berle et al., 2003 | Prospective cohort | Women attending routine PP visits 6 to 12 wks PP | Major and minor | | 6 to 12 wks PP | Major | EPDS ≥ 9 | 27/411 (6.6%)
Quality rating | Sample size | Age | Interview subjects
9 | 411 women | Mean depressed: 30 yrs | All women scoring ≥ 8 on the EPDS and every 10th woman scoring < 8
| Place | Mean nondepressed: 29.8 yrs | Clinical instrument
| Norway | Race/ethnicity | MINI-V4.4 and the MADRS
| | NR | Diagnostic criteria
| | Inclusion/exclusion criteria | DSM-IV
| | None | Interview times
| | | 6 to 12 wks PP
Author | Study design | Population | Diagnoses | Point | 6 to 8 wks PP | Major and minor | Low risk | 57/1,033 (5.5%)
Campbell and Cohn, 1991 | Prospective cohort | Women who delivered at Magee-Women's Hospital from 7/1986 to 7/1990 | Major and minor | Period | 0 to 6 to 8 wks PP | Major and minor | Low risk | 96/1,033 (9.3%)
Quality rating | Sample size | Age | Interview subjects | | 0 to 6 to 8 wks PP | Major | Low risk | 36/1,033 (3.5%)
12 | 1033 women | Mean depressed: 28.5 (SD 3.6) yrs | All study women
| Place | Mean nondepressed: 28.8 (SD 3.6) yrs | Clinical instrument
| Pennsylvania | Race/ethnicity | Modified version of SADS via telephone
| | White: 100% | Diagnostic criteria
| | Inclusion/exclusion criteria | RDC plus had to have depressed mood for ≥ 2 wks and ≥ 3 other symptoms
| | Included: Primiparous women who delivered full-term, single infants without major complications and who were Caucasian, married, 18+ yrs of age, and had at least a high school education. | Interview time
| | Excluded: Women with adopted or stepchildren at home | 6 to 8 wks PP
Author | Study design | Population | Diagnoses | Point | 6 to 10 wks PP | Major | EPDS ≥ 8 | 756/4,954 (15.3%)
Cooper et al., 1996 | Prospective cohort | Women attending the prenatal clinic at the Rosie Maternity Hospital over a 3-yr period | Major
Quality rating | Sample size | Age | Interview subjects
12 | 4,954 women | Mean: 28.2 (SD 4.9) yrs | EPDS mailed at 5 wks PP; women scoring above the cutoff on the EPDS were contacted by telephone. Initially, the cutoff was set at 7 but was changed to 8 and later to 9.
| Place | Race/ethnicity | Clinical instrument
| England | NR | Multiparous women were assessed by telephone and primiparous women were assessed in person with the SCID
| | Inclusion/exclusion criteria | Diagnostic criteria
| | Included: All women in 1st 24 mos of the study and only primiparous women in the last 12 mos of the study | DSM-III-R
| | | Interview time
| | | 6 to 10 wks PP
Author | Study design | Population | Diagnoses | Period | 1 wk to 3 to 5 mos PP | Major and minor | NR | 30/103 (29.1%)
Cox et al., 1982 | Prospective cohort | Women who attended prenatal clinics at the Simpson Memorial Maternity Pavilion from 1/1978 to 11/1979 | Major and minor | | 1 wk to 3 to 5 mos PP | Major | NR | 13/103 (12.6%)
Quality rating | Sample size | Age | Interview subjects
11 | 105 women | Mean: 26 yrs | All study women
| Place | Race/ethnicity | Clinical instrument
| Scotland | NR | SPI
| | Inclusion/exclusion criteria | Diagnostic criteria
| | Included: Women who resided in Edinburgh, were < 20 wks gestation at entry, and delivered a live infant | Pitt's criteria
| | Excluded: Women with language difficulties | Interview times
| | | At 1st visit to clinic; at or about 35 wks GA; within 10 days of delivery; within 3 to 5 mos of delivery
Author | Study design | Population | Diagnoses | Point | 6 wks | Major and minor | EPDS ≥ 9 | 100/1123(8.9%)
Garcia-Esteve et al., 2003 | Prospective cohort | Women attending routine PP checkups at 6 wks PP at the public Maternity Hospital of Barcelona | Major and minor | | 6 wks | Major | EPDS ≥ 9 | 36/1123 (3.2%)
Quality rating | Sample size | Age | Interview subjects
13 | 1123 women | Mean depressed: 29.8 yrs | Women scoring ≥ 9 on the EPDS and a random 10% sample of those scoring < 9
| Place | Mean nondepressed: 30.2 yrs | Diagnostic instrument
| Barcelona, Spain | Race/ethnicity | Modified SCID-NP
| | NR | Diagnostic criteria
| | Inclusion/exclusion criteria | DSM-IV
| | Included: Spanish-speaking women | Interview time
| | Excluded: Those suffering from mourning or organic depression | 6 wks PP
Author | Study design | Population | Diagnoses | New episode | 24 to 36 wks GA | Major and minor | BDI ≥ 10 | 5/270 (1.9%)
Gotlib et al., 1989 | Prospective cohort | Participants were recruited from a consecutive series of pregnant patients through the obstetrics department of a large, urban hospital and from the private practices of more than 15 physicians | Major and minor | | 36 wks GA to 4 wks PP | Major and minor | BDI ≥ 10 | 10/285 (3.5%)
Quality rating | Sample size | Age | Interview subjects | Point | 24 wks GA | Major and minor | BDI ≥ 10 | 27/295 (9.2%)
11 | 295 women | Mean: 27.8 (SD 3.4) yrs | All women with BDI ≥ 10 and 34 women with BDI < 10 | | 36 wks GA | Major and minor | BDI ≥ 10 | 24/295 (8.0%)
| Place | Range: 18 to 40 yrs | Clinical instrument | | 4 wks PP | Major and minor | BDI ≥ 10 | 20/295 (6.8%)
| Canada | Race/ethnicity | Shortened version of SADS via telephone by a clinical psychologist | | 4 wks PP | Major and minor | Adj for BDI | 38/295 (13%)
| | White: 90% | Diagnostic criteria | Period | 24 to 36 wks GA | Major and minor | BDI ≥ 10 | 30/295 (10.2%)
| | Inclusion/exclusion criteria | RDC
| | None | Interview times
| | | 24 and 36 wks GA and 4 wks PP
Author | Study design | Population | Diagnoses | New episode | 2nd or 3rd trimester to 7 to 9 wks PP | Major and minor | Low income | 21/168 (12.5%)
Hobfoll et al., 1995 | Prospective cohort | Women were recruited over 2.5 yrs from a randomly selected sample of the patient population meeting study criteria at 3 obstetrics clinics for low-income women in a mid-sized Midwestern city | Major and minor | | 2nd or 3rd trimester to 7 to 9 wks PP | Major | Low income | 5/168 (3.0%)
Quality rating | Sample size | Age | Interview subjects | Point | 2nd trimester | Major and minor | Low income | 53/192 (27.6%)
12 | 192 women | Mean: 24.5 (SD 5.1) yrs | All study women | | 2nd trimester | Major | Low income | 22/192 (11.5%)
| Place | Range: 17 to 40 yrs | Clinical instrument | | 3rd trimester | Major and minor | Low income | 47/192 (24.5%)
| Ohio | Race/ethnicity | Modified version of the SADS | | 3rd trimester | Major | Low income | 8/192 (4.2%)
| | African American: 27% | Diagnostic criteria | | 7 to 9 wks PP | Major and minor | Low income | 45/192 (23.4%)
| | European American: 73% | RDC | | 7 to 9 wks PP | Major | Low income | 14/192 (7.3%)
| | Inclusion/exclusion criteria | Interview times
| | Included: 17 to 40 yrs of age, 16 to 24 wks GA at entry, free of serious medical complications, and of either African American or European American descent | During the 2nd and 3rd trimesters and at 7 to 9 wks PP
Author | Study design | Population | Diagnoses | Point | 6 mos PP | Major | GHQ28 > 4 only | 67/710 (9.4%)
Kent et al., 1999 | Prospective cohort | Women were randomly selected from the Western Australian Midwives' Notification System database | Major
Quality rating | Sample size | Age | Interview subjects
12 | 710 women | Range: 20 to 45 yrs | All women with GHQ28 > 4
| Place | Race/ethnicity | Clinical instrument
| Australia | White: 100% | CIDI-A
| | Inclusion/exclusion criteria | Diagnostic criteria
| | Included: Caucasian women aged 20 to 45 yrs at 4.5 to 5.5 mos PP who were residents of Perth and had no traumatic birth events | DSM-III-R
| | Excluded: Women with pre-existing thyroid disease, PP thyroid dysfunction on thyroid medication prior to entry, and women with normal TSH but low free T_4_ | Interview time
| | | 6 mos PP
Author | Study design | Population | Diagnoses | New episode | During pregnancy | Major and minor | NR | 19/108 (17.6%)
Kitamura et al., 1993 | Prospective cohort | Women were recruited from patients at a prenatal clinic in the obstetrics department of a general hospital on 2 given days per wk | Major and minor | | During pregnancy | Major | NR | 13/108 (12.0%)
Quality rating | Sample size | Age | Interview subjects | | 1st trimester | Major and minor | NR | 13/108 (12.0%)
13 | 120 women | Mean: 27.9 (SD 4.6) yrs | All study women | Period | During pregnancy | Major and minor | NR | 21/110 (19.1%)
| Place | Range: 17 to 42 yrs | Clinical instrument | | During pregnancy | Major | NR | 14/110 (12.7%)
| Japan | Race/ethnicity | SADS and SADS-C administered by a psychiatrist
| | NR | Diagnostic criteria
| | Inclusion/exclusion criteria | RDC
| | Excluded: Women > 12 wks GA | Interview times
| | | Early (when fetal heart beat was 1st confirmed) and late (about 34 wks GA) pregnancy
Author | Study design | Population | Diagnoses | Point | 1st trimester | Major and minor | NR | 10/111 (9.0%)
Kitamura et al., 1999 | Prospective cohort | Women attending a prenatal clinic at a general hospital in an industrial city between 8/1984 and 2/1986 | Major and minor | | 1st trimester | Major | NR | 7/111 (6.3%)
Quality rating | Sample size | Age | Interview subjects | | 3rd trimester | Major and minor | NR | 9/102 (8.8%)
10 | 111 women | Mean: 28 (SD 5) yrs | All study women | | 3rd trimester | Major | NR | 4/102 (3.9%)
| Place | Range: 17 to 42 yrs | Clinical instrument | | 5 days PP | Major and minor | NR | 5/91 (5.5%)
| Japan | Race/ethnicity | SADS administered by a psychiatrist | | 5 days PP | Major | NR | 0/91(0.0%)
| | NR | Diagnostic criteria | | 1 mo PP | Major and minor | NR | 7/101 (6.9%)
| | Inclusion/exclusion criteria | RDC | | 1 mo PP | Major | NR | 3/101 (3.0%)
| | Included: > 12 wks GA and planning to give birth in another hospital | Interview times
| | | 1st and 3rd trimesters, on the 5th day PP, and 1 mo PP
Author | Study design | Population | Diagnoses | New episode | Preconception to 12 wks GA | Major and minor | NR | 12/112 (10.7%)
Kumar and Robson, 1984 | Prospective cohort | Primiparous women booked at a prenatal clinic. Additional primiparous and multiparous women meeting other criteria above were enrolled from PP wards after delivery | Major and minor | | 12 wks GA to 24 wks GA | Major and minor | NR | 3/113 (2.7%)
Quality rating | Sample size | Age | Interview subjects | | 24 wks GA to 36 wks GA | Major and minor | NR | 3/114 (2.6%)
11 | 119 entering during pregnancy and 77 entering PP | Mean: 28 yrs | All study women | | 3rd trimester to12 wks PP | Major and minor | NR | 15/114 (13.2%)
| Place | Range: 19 to 40 yrs | Clinical instrument | Point | 12 wks GA | Major and minor | NR | 15/119 (12.5%)
| England | Race/ethnicity | SPI | | 12 wks GA | Major | NR | 1/119 (0.8%)
| | NR | Diagnostic criteria | | 24 wks GA | Major and minor | NR | 9/119 (7.6%)
| | Inclusion/exclusion criteria | RDC | | 36 wks GA | Major and minor | NR | 7/119 (5.9%)
| | Included: Primiparous women who were < 12 to 14 wks GA, married or had stable common-law partners, had spent 5 of previous 10 yrs in Britain, and resided within a reasonable distance of central London | Interview times | | 12 wks PP | Major and minor | NR | 16/114 (14.0%)
| | | Within a 4-wk base period at entry, 12 wks, and 1 yr PP; subjects rated as “cases” during 1st trimester were also followed up at 24 or 36 wks GA, and those rated as cases at 12 wks PP were interviewed at 1 yr | | 12 wks PP | Major | NR | 3/114 (2.6%)
| | | | | 28 wks PP | Major and minor | NR | 15/112 (13.4%)
| | | | | 1 yr PP | Major and minor | NR | 7/108 (6.5%)
| | | | Period | During pregnancy | Major and minor | NR | 22/119 (18.5%)
Author | Study design | Population | Diagnoses | New episode | 0 to 1 mo PP | Major and minor | GHQ > 4 | 9.4% (SE 2.0)
Lee et al., 2001 | Prospective cohort | Women recruited from consecutive patients admitted to the prenatal booking clinic of the Prince of Wales Hospital for their 1st prenatal visit | Major and minor | | | | Chinese only
Quality rating | Sample size | Age | Interview subjects | | 0 to 1 mo PP | Major | GHQ > 4 | 5.0% (SE 2.0)
12 | 781 women | Mean: 29.0 (SD 4.9) yrs for women assessed at 3 mos | Women with GHQ ≥ 5 and a random sample of women with GHQ < 5 | | | | Chinese only
| Place | Mean: 29.2 (SD 4.9) yrs for women not assessed at 3 mos | Clinical instrument | | 0 to 3 mos PP | Major and minor | GHQ > 4 | 10.4% (SE 2.8)
| Hong Kong | Race/ethnicity | SCID | | | | Chinese only
| | Chinese: 100% | Diagnostic criteria | | 0 to 3 mos PP | Major | GHQ > 4 | 5.6% (SE 2.0)
| | Inclusion/exclusion criteria | DSM-III-R | | | | Chinese only
| | Excluded: Women who were not of Chinese ethnicity or were not permanent residents of Hong Kong | Interview time | Point | 1 mo PP | Major and minor | GHQ > 4 | 10.3% (SE 2.8)
| | | 3 mos PP | | | | Chinese only
| | | | | 1 mo PP | Major | GHQ > 4 | 5.5% (SE 2.0)
| | | | | | | Chinese only
| | | | | 3 mos PP | Major and minor | GHQ > 4 | 11.2% (SE 2.8)
| | | | | | | Chinese only
| | | | | 3 mos PP | Major | GHQ > 4 | 6.1% (SE 2.0)
| | | | | | | Chinese only
Author | Study design | Population | Diagnoses | Point | 6 wks PP | Major and minor | Chinese only | 17/145 (11.7%)
Lee et al., 2001 | Prospective cohort | Women admitted to the PP wards of the Prince of Wales Hospital over a 3-mo period | Major and minor | | 6 wks PP | Major | Chinese only | 8/145 (5.5%)
Quality rating | Sample size | Age | Interview subjects
12 | 145 women | Mean: 29 yrs | All study women
| Place | Range: 16 to 42 yrs | Clinical instrument
| Hong Kong | Race/ethnicity | Chinese version of SCID
| | Chinese: 100% | Diagnostic criteria
| | Inclusion/exclusion criteria | DSM-III-R
| | Excluded: Non-Chinese women and those without permanent residency rights in Hong Kong | Interview time
| | | 6 wks PP
Author | Study design | Population | Diagnoses | Point | 1 mo PP | Major | BDI > 21 | 3/605 (0.5%)
Lucas et al., 2001 | Prospective cohort | Consecutive series of healthy Caucasian women recruited between their 36th wk of pregnancy and 4th day PP at a university hospital from 3/1993 to 6/1997 | Major | | 3 mos PP | Major | BDI > 21 | 5/552 (0.9%)
Quality rating | Sample size | Age | Interview subjects | | 6 mos PP | Major | BDI > 21 | 3/574 (0.5%)
9 | 641 women | Mean: 28 (SD 4.6) yrs | Women with BDI > 21 | | 9 mos PP | Major | BDI > 21 | 0/431 (0.0%)
| Place | Range: 17 to 42 yrs | Clinical instrument | | 12 mos PP | Major | BDI > 21 | 0/444 (0.0%)
| Spain | Race/ethnicity | Clinical evaluation by psychiatrist with unspecified instrument | Period | 0 to 1 yr PP | Major | BDI > 21 | 11/641 (1.7%)
| | White: 100% | Diagnostic criteria
| | Inclusion/exclusion criteria | DSM-III-R
| | Excluded: Women with concurrent autoimmune disease and previous thyroid disease | Interview times
| | | 1, 3, 6, 9, and 12 mos PP
Author | Study design | Population | Diagnoses | Period | 0 to 6 wks PP | Major and minor | NR | 21/216 (9.7%)
Matthey et al., 2003 | Prospective cohort | 1st-time mothers were recruited from prenatal classes in a public hospital | Major and minor | Sample 1
Quality rating | Sample size | Age | Interview subjects | Period | 0 to 6 wks PP | Major and minor | NR | 9/192 (4.7%)
11 | Sample 1: 216 | Sample 1: | All study women | Sample 2
| Sample 2: 192 | Mean: 27.2 (SD 4.2) yrs | Clinical instrument
| Place | Range: 18 to 41 yrs | DIS
| Australia | Sample 2: | Diagnostic criteria
| | Mean: 27.5 (SD 3.5) yrs | DSM-IV
| | Range: 19 to 38 yrs | Interview time
| | Race/ethnicity | 6 wks PP
| | NR
| | Inclusion/exclusion criteria
| | None
Author | Study design | Population: | Diagnoses | Point | 3rd trimester | Major and minor | NR | 14/100 (14.0%)
Murray and Cox, 1990 | Prospective cohort | Convenience sample of women attending the prenatal clinic of the North Staffordshire Maternity Hospital | Major and minor | | 3rd trimester | Major | NR | 6/100 (6.0%)
Quality rating | Sample size | Age | Interview subjects
10 | 100 women | Mean: 24.6 yrs | All study women
| Place | Race/ethnicity | Clinical instrument
| England | NR | Modified SPI
| | Inclusion/exclusion criteria | Diagnostic criteria
| | Included: Women 28 to 34 wks GA | RDC
| | | Interview time
| | | 3rd trimester
Author | Study design | Population | Diagnoses | New episode | 0 to 9 wks PP | Major and minor | NR | 10/97 (10.3%)
O'Hara et al., 1984 | Prospective cohort | Women recruited in the 2nd trimester of pregnancy from a public ob-gyn clinic and 2 private practices at the Univ. of Iowa Hospital and Clinics | Major and minor | Point | 2nd trimester | Major and minor | NR | 9/99 (9.1%)
Quality rating | Sample size | Age | Interview subjects | | 2nd trimester | Major | NR | 6/99 (6.1%)
10 | 99 women | Mean: 26.5 (SD 4.2) yrs | All study women | Period | 0 to 9 wks PP | Major and minor | NR | 12/99 (12.1%)
| Place | Race/ethnicity | Clinical instrument | | 0 to 9 wks PP | Major | NR | 8/99 (8.1%)
| Iowa | White: 98% | Modified SADS
| | Inclusion/exclusion criteria | Diagnostic criteria
| | Included: Married and 18+ yrs of age | RDC
| | | Interview times
| | | 2nd trimester and 9 wks PP
Author | Study design | Population | Diagnoses | Point | 32 wks GA | Major and minor | NR | 21/293 (7.2%)
Pop et al., 1993 | Prospective cohort | Caucasian women registered for prenatal care between 11/1988 and 4/1989 in a semi-urban, semi-rural area | Major and minor | | 4 wks PP | Major and minor | NR | 27/293 (9.2%)
Quality rating | Sample size | Age | Interview subjects | | 10 wks PP | Major and minor | NR | 41/293 (14.0%)
13 | 293 women | Multipara mean: 30.5 yrs | All study women | | 16 wks PP | Major and minor | NR | 31/293 (10.6%)
| Place | Primipara mean: 27.4 yrs | Clinical interview | | 22 wks PP | Major and minor | NR | 31/293 (10.6%)
| The Netherlands | Race/ethnicity | NR | | 28 wks PP | Major and minor | NR | 26/293 (8.9%)
| | White: 100% | Diagnostic criteria | | 34 wks PP | Major and minor | NR | 19/293 (6.5%)
| | Inclusion/exclusion criteria | RDC | | 32 wks GA | Major | NR | 3/293 (1.0%)
| | None | Interview times | | 4 wks PP | Major | NR | 6/293 (2.0%)
| | | 32 wks GA and 4, 10, 16, 22, 28, and 34 wks PP | | 10 wks PP | Major | NR | 12/293 (4.1%)
| | | | | 16 wks PP | Major | NR | 7/293 (2.4%)
| | | | | 22 wks PP | Major | NR | 6/293 (2.0%)
| | | | | 28 wks PP | Major | NR | 9/293 (3.1%)
| | | | | 34 wks PP | Major | NR | 3/293 (1.0%)
| | | | Period | 0 to 34 wks PP | Major and minor | NR | 61/293 (20.8%)
| | | | | 0 to 34 wks PP | Major | NR | 20/293 (6.8%)
Author | Study design | Population | Diagnoses | New episode | 1st trimester to birth | Major | NR | 7/123 (5.7%)
Watson et al., 1984 | Prospective cohort | Women who attended a prenatal clinic in South London inner-city area for the 1st time between 9/1977 and 9/1978 | Major | | 0 to 6 wks PP | Major | NR | 10/123 (8.1%)
Quality rating | Sample size | Age | Interview subjects | Point | 16 wks GA | Major | NR | 5/128 (3.9%)
13 | 128 women | Multipara mean: 28 yrs | All study women | | 6 wks PP | Major | NR | 15/128 (11.7%)
| Place | Primipara mean: 24 yrs | Clinical instrument | Period | 1st trimester to birth | Major | NR | 12/128 (9.4%)
| England | Race/ethnicity | SPI | | 0 to 1 yr PP | Major | NR | 28/128 (21.9%)
| | UK origin: 94 (73%) | Diagnostic criteria
| | West Indian origin: 17 (13%) | ICD-9
| | Other: 18 (14%) | Interview times
| | Inclusion/exclusion criteria | 16 wks of GA and 6 wks PP
| | Excluded: Those who spoke insufficient English, were past the 24th wk of pregnancy, or were planning to move out of the area in the near future
Author | Study design | Population | Diagnostic criteria | Point | 6 to 8 wks PP | Major and minor | NR | 19/115 (16.5%)
Whiffen, 1988 | Prospective cohort | Women were recruited during their 3rd trimester through public health prenatal classes | Major and minor | | 6 to 8 wks PP | Major | NR | 7/115 (6.1%)
Quality rating | Sample size | Age | Interview subjects
10 | 115 women | Mean: 28.1 (SD 3.9) yrs | All study women
| Place | Race/ethnicity | Clinical instrument
| Canada | NR | Modified version of the SADS
| | Inclusion/exclusion criteria | Diagnostic criteria
| | Included: Primiparous, 18+ yrs old, intending to deliver in a hospital, involved in a marital or common-law relationship, and at low risk for complications | RDC
| | Excluded: Women with inadequate English language skills | Interview times
| | | 35 wks GA and 6 to 8 wks PP
Author | Study design | Population | Diagnoses | New episode | 0 to 3 wks PP | Major and minor | NR | 12/88 (13.6%)
Yamashita et al., 2000 | Prospective cohort | Consecutive patients admitted for delivery to the maternity ward of Kyushu Univ. Hospital from 12/1994 to 12/1996 | Major and minor | | 0 to 3 wks PP | Major | NR | 5/88 (5.7%)
Quality rating | Sample size | Age | Interview subjects | | 0 to 3 mos PP | Major and minor | NR | 15/88 (17.0%)
10 | 88 women | Mean: 31 yrs | All study women | | 0 to 3 mos PP | Major | NR | 7/88 (8.0%)
| Place | Range: 19 to 41 yrs | Clinical instrument | Point | 3 wks PP | Major and minor | NR | 12/88 (13.6%)
| Japan | Race/ethnicity | SADS via telephone by psychiatrists | | 3 wks PP | Major | NR | 5/88 (5.7%)
| | Asian: Assumed 100% | Diagnostic criteria | | 3 mos PP | Major and minor | NR | 9/88 (10.2%)
| | Inclusion/exclusion criteria | RDC | | 3 mos PP | Major | NR | 6/88 (6.8%)
| | None | Interview times | Period | 0 to 3 wks PP | Major and minor | NR | 12/88 (13.6%)
| | | 3 wks and 3 mos PP | | 0 to 3 wks PP | Major | NR | 5/88 (5.7%)
| | | | | 0 to 3 mos PP | Major and minor | NR | 15/88 (17.0%)
| | | | | 0 to 3 mos PP | Major | NR | 7/88 (8.0%)
Author | Study design | Population | Diagnoses | New episode | 0 to 1 mo PP | Major | Multiethnic | 26/776 (3.3%)
Yonkers et al., 2001 | Prospective cohort | Consecutive patients who came for their initial PP appointments on selected days at 4 publicly funded inner-city community maternal health clinics | Major and minor | | | | Low income | With all lost to followup not depressed
Quality rating | Sample size | Age | Interview subjects | | | | IDS ≥ 18 or EPDS ≥ 12
14 | 802 women | Mean: 24.2 (SD 5.6) yrs | Women with IDS ≥ 18 or EPDS ≥ 12 and the 1st 42 participants who screened negative for depressive symptoms. Also 50 randomly selected patients who did not go to the clinics at the appointed times were screened by telephone to investigate whether depressed women are less likely to keep their clinic appointments | | 0 to 1 mo PP | Major | Multiethnic | 42/776 (5.4%)
| Place | Race/ethnicity | Clinical instrument | | | | Low income | With all lost to followup depressed
| Texas | White non-Hispanic: 20 (2%) | SCID | | | | IDS ≥ 18 or EPDS ≥ 12
| | African American: 162 (20%) | Diagnostic criteria | Point | 1 mo PP | Major and minor | Multiethnic | 58/802 (7.2%)
| | Hispanic: 604 (75%) | DSM-IV | | | | Low income | With all lost to followup not depressed
| | Asian: 5 (<1%) | Interview times | | | | IDS ≥ 18 or EPDS ≥ 12
| | Other: 11(1%) | 4 to 5 wks PP | | 1 mo PP | Major | Multiethnic | 52/802 (6.5%)
| | Inclusion/exclusion criteria | | | | | Low income | With all lost to followup not depressed
| | Included: Had completed their pregnancies or miscarried | | | | | IDS ≥ 18 or EPDS ≥ 12
| | | | | 1 mo PP | Major | Multiethnic | 68/802 (8.5%)
| | | | | | | Low income | With all lost to followup depressed
| | | | | | | IDS ≥ 18 or EPDS ≥ 12
| | | | | 1 mo PP | Major | African American | 11/162 (6.8%)
| | | | | | | Low income | With all lost to followup not depressed
| | | | | | | IDS ≥ 18 or EPDS ≥ 12
| | | | | 1 mo PP | Major | African American | 20/162 (12.3%)
| | | | | | | Low income | With all lost to followup depressed
| | | | | | | IDS ≥ 18 or EPDS ≥ 12
| | | | | 1 mo PP | Major | Hispanic | 29/604 (4.8%)
| | | | | | | Low income | With all lost to followup not depressed
| | | | | | | IDS ≥ 18 or EPDS ≥ 12
| | | | | 1 mo PP | Major | Hispanic | 45/604 (7.4%)
| | | | | | | Low income | With all lost to followup depressed
| | | | | | | IDS ≥ 18 or EPDS ≥ 12
Author | Study design | Population | Diagnoses | New episode | 0 to 3 mos PP | Major and minor | NR | 12/98 (12.2%)
Yoshida et al., 1997 | Prospective cohort | Recruited from prenatal classes for pregnant Japanese women and an advertisement inserted in a maternity guidebook for pregnant Japanese women | Major and minor | | 0 to 3 mos PP | Major | NR | 6/98 (6.1%)
Quality rating | Sample size | Age | Interview subjects | Period | 0 to 3 mos PP | Major and minor | NR | 12/98 (12.2%)
11 | 98 women | Mean: 30.0 (SD 2.7) yrs | All study women | | 0 to 3 mos PP | Major | NR | 6/98 (6.1%)
| Place | Race/ethnicity | Clinical instrument
| England | Japanese: 100% | Japanese translation of the SADS administered by a Japanese psychiatrist
| | Inclusion/exclusion criteria | Diagnostic criteria
| | Included: Pregnant Japanese women living in London | RDC
| | | Interview times
| | | 3 mos PP
Prospective Studies with Comparison Groups | | | | Prospective Studies with Comparison Groups
Author | Study design | Population | Diagnoses | Point | 3 mos PP | Major | (1) | 10/460 (2.2%)
Cooper et al., 1988 | Prospective cohort study with comparison group | Cases were recruited from the appointments diary of the prenatal clinic and the delivery booking diary of the General Practitioner Unit at the John Radcliffe Hospital; every 2nd woman identified was approached. Comparison sample was derived from a community sample of Edinburgh women | Major | cases | 6 mos PP | Major | (1) | 17/442 (3.8%)
Quality rating | Sample size | Age | Interview subjects | | 12 mos PP | Major | (1) | 6/462 (1.3%)
10 | 483 cases and 313 controls | Cases mean: 27.2 yrs | At about 34 wks GA, all cases were assessed using the GHQ. At 3 mos PP, psychiatric Diagnoses were validated for a random sample of cases, all cases with GHQ ≥ 12, and sample of cases with GHQ < 12. At 6 mos PP, all GHQ ≥ 12 cases and PSE cases from 3-mo interview were reinterviewed. At 12 mos, a random sample of women, all GHQ ≥ 12 cases from prenatal, 3- and 6-mo PP periods, a subsample of GHQ < 12 and all 3- and 6-mo PSE cases were reinterviewed | Point | 3 mos PP | Major | (1) | 8/313 (2.6%)
| Place | Comparison sample mean: 28.8 yrs | Clinical instrument | controls | 6 mos PP | Major | (1) | 8/313 (2.6%)
| England | Race/ethnicity | PSE/MADRS | | 12 mos PP | Major | (1) | 8/313 (2.6%)
| | NR | Diagnostic criteria
| | Inclusion/exclusion criteria | PSE ID/Cartego class
| | Included: Cases had to reside in Oxford City and have an expected delivery date in 9-mo recruitment window; comparison women had to be 16 to 40 yrs of age, not currently pregnant, and not pregnant in previous 12 mos | Interview times
| | | 3, 6, and 12 mos PP
Author | Study design | Population | Diagnoses | New | 0 to 5 wks PP | Major and minor | EPDS ≥ 9 | 16/225 (7.1%)
Cox et al., 1993 | Prospective case/control | The index group comprised random samples of women from the prenatal clinic lists of the North Staffordshire Hospital and women who had not been seen in a prenatal clinic identified from the birth register. The control-group women were recruited from 4 general practice age/sex registers and were 16 to 45 yrs of age, not currently pregnant, and had NR birth in the previous 12 mos | Major and minor | cases | 0 to 6 mos PP | Major and minor | EPDS ≥ 9 | 25/225 (11.1%)
Quality rating | Sample size | Age | Interview subjects | Point | 6 mos PP | Major and minor | EPDS ≥ 9 | 21/232 (9.1%)
12 | 232 cases and 232 controls | Case mean: 25.4 (SD 5.2) yrs | Women with EPDS ≥ 9 and a sample of women with EPDS < 9 | cases | 6 mos PP | Major and minor | (2) | 23/232 (9.9%)
| Place | Controls mean: 27.2 (SD 4.7) yrs | Clinical instrument | | 6 mos PP | Major | EPDS ≥ 9 | 8/232 (3.5%)
| England | Race/ethnicity | SPI during home visit | Period | 0 to 6 mos PP | Major and minor | EPDS ≥ 9 | 32/232 (13.8%)
| | NR | Diagnostic criteria | cases | 0 to 6 mos PP | Major | EPDS ≥ 9 | 15/232 (6.5%)
| | Inclusion/exclusion criteria | RDC | New | 0 to 5 wks PP | Major and minor | EPDS ≥ 9 | 5/218 (2.3%)
| | None | Interview time | controls | 0 to 6 mos PP | Major and minor | EPDS ≥ 9 | 17/218 (7.8%)
| | | 6 mos PP | Point | 6 mos PP | Major and minor | EPDS ≥ 9 | 19/232 (8.2%)
| | | | controls | 6 mos PP | Major and minor | (2) | 23/232 (9.9%)
| | | | | 6 mos PP | Major | EPDS ≥ 9 | 8/232 ((3.5%)
| | | | Period | 0 to 6 mos PP | Major and minor | EPDS ≥ 9 | 31/232 (13.4%)
| | | | controls | 0 to 6 mos PP | Major | EPDS ≥ 9 | 13/232 (5.6%)
Author | Study design | Population | Diagnoses | Point | 2nd trimester | Major and minor | NR | 14/182 (7.7%)
O'Hara, 1990 | Prospective case/control | Women recruited from a public ob-gyn clinic and 2 private practices at the Univ. of Iowa Hospitals and Clinics. Each subject was asked to provide the names of 5 acquaintances who were similar in age, marital status, work status, and had a similar number of children. The acquaintance most similar to the subjects was selected as a control | Major and minor | cases | 2nd trimester | Major | NR | 9/182 (4.9%)
Quality rating | Sample size | Age | Interview subjects | | 9 wks PP | Major and minor | NR | 19/182 (10.4%)
13 | 182 cases and 179 controls | Case mean: 27.02 (SD 4.71) yrs | All study women | | 9 wks PP | Major | NR | 8/182 (4.4%)
| Place | Controls mean: 27.51 (SD 5.04) yrs | Clinical instrument | Point | 2nd trimester | Major and minor | NR | 10/179 (5.6%)
| Iowa | Race/ethnicity | SADS and SADS-L | controls | 2nd trimester | Major | NR | 7/179 (3.9%)
| | NR | Diagnostic criteria | | 9 wks PP | Major and minor | NR | 14/179 (7.8%)
| | Inclusion/exclusion criteria | RDC | | 9 wks PP | Major | NR | 6/179 (3.4%)
| | Included: 18+ yrs of age | Interview times
| | | 2nd trimester and at 34 wks GA, 3, 6, and 9 wks PP
Retrospective Studies | | | | Retrospective Studies
Author | Study design | Population | Diagnoses | New episode | 0 to 1 yr PP | Major and minor | NR | 10/398 (2.5%)
Bryan et al., 1999 | Retrospective chart review | Random sample of Olmsted County residents who gave birth in the county between 1/1/1993 and 12/31/1993 | Major and minor | Period | 0 to 1 yr PP | Major and minor | NR | 15/403 (3.7%)
Quality rating | Sample size | Age | Clinical assessment | | 0 to 1 yr PP | Major | NR | 5/403 (1.2%)
16 | 403 women | < 19 yrs: 8 (2%) | Information on symptoms and diagnoses of depression were abstracted from medical records for 1 yr PP. Depression defined by
| Place | 19 to 32 yrs: 265 (65.8%) | • 2 notations at least 2 wks apart of symptoms of depression
| Minnesota | 33+ yrs: 130 (32.2%) | • documented diagnosis of depression by a medical provider
| | Race/ethnicity | • a new prescription for antidepressant with no evidence that it was for an indication other than depression
| | NR | • documentation of symptoms sufficient to meet the DSM-IV criteria for major depression
| | Inclusion/exclusion criteria
| | Excluded: Women whose pregnancies terminated prior to 24 wks GA and non-Olmsted County residents at the time of delivery; women with preexisting depression without substantial remission prior to delivery
Author | Study design | Population | Diagnoses | Period | 0 to1 yr PP | Major | NR | 10.7% (weighted for the entire population)
Georgiopoulos et al., 2001 | Population-based prospective study with retrospective record review | Residents of Olmstead County, MN, visiting Olmstead Medical Center or Mayo Clinic in 1997 to 1998 who scored ≥ 10 in the routine EPDS screening project and a sample of women scoring < 10 with an indication of suicidal ideation | Major
Quality rating | Sample size | Age | Clinical assessment
8 | 342 women | Mean: 29 yrs | Documented diagnosis of PP depression in medical records during 1 yr PP
| Place | Range: 16 to 46 yrs
| Minnesota | Race/ethnicity
| | NR
| | Inclusion/exclusion criteria
| | None

Notes: Bolded numbers were computed from reported numbers.

(1) Different subsamples of women (random, GHQ ≥ 12, GHQ < 12) interviewed at different time periods; rates were based on cases with a Catego class of retarded depression and were adjusted for the full sample.

(2) Corrected for loss to followup by applying the positive predictive value to the EPDS high scorers who could not be interviewed and the negative predictive value to the EPDS low scorers not interviewed.

Evidence Table 2. Key Question 2: Studies of screening tools for detecting depression during pregnancy and first year postpartum: Abstract form results (English)

Author, Year | Study Characteristics | Population Description | Criterion Standard | Diagnosis | Screening Method | Prevalence | | | | Sensit. | Specific. | Likelihood Ratio
Quality rating | | | | | | No. Screened & Diagnosed | | | | % | % | + | -
| | | | | | 15.5%
Author | Sample size | Age | Instrument | | Instrument | Screened | | Diagnosed
Ballard et al., 1994 | 200 | Mean: 28.8 yrs | PAS (adaptation of PSE) | Major | EPDS | + | - | + | - | 95.7 | 71 | 3.3 | 0.06
Quality rating | Place | Race/ethnicity | Diagnostic criteria | | Cutoff scores | 31 | 22 | 23 | 30
18 | UK | NR | RDC | | ≥13
| Recruitment setting | Inclusion/exclusion criteria | Timing
| Maternity hospital | Included: Married or cohabitating mothers | Within 2 wks of date that completed EPDS questionnaire was received - approximately 6 mos PP
| | Excluded: Lack of English language skills
| | | | | | 12%
Author | Sample size | Age | Instrument | | Instrument | Screened | | Diagnosed
Beck and Gable, 2001 | 150 | Mean: 31 yrs | SCID conducted by nurse psychotherapist | Major | PDSS | + | - | + | - | 94 | 98 | 47 | 0.061
Quality rating: | Place | Range: 18 to 46 yrs | Diagnostic criteria | | Cutoff scores | 20 | 130 | 18 | 132
15 | US | Race/ethnicity | DSM-IV | | ≥81
| Recruitment setting | Caucasian: 87% | Timing | | | 12%
| • Childbirth classes | Black: 8% | Immediately following completion of screening Instruments between 2 and 12 wks PP | | Instruments | Screened | | Diagnosed
| • Newspaper advertisements | Hispanic: 4% | | Major | EPDS | + | - | + | - | 78 | 99 | 78 | 0.222
| | Asian: 1% | | | Cutoff scores | 15 | 135 | 18 | 132
| | Inclusion/exclusion criteria | | | ≥ 13
| | Included: Women 2 to 12 wks PP, 18+ yrs of age, able to read English, delivered live, healthy infant | | | | 12%
| | | | | Instrument | Screened | | Diagnosed
| | | | Major | BDI-II | + | - | + | - | 56 | 100 | 0 | 0.44
| | | | | Cutoff scores | 10 | 140 | 18 | 132
| | | | | ≥21
| | | | | | 19%
| | | | | Instrument | Screened | | Diagnosed
| | | | Major or minor | BDI-II | + | - | + | - | 59 | 88 | 4.9 | 0.47
| | | | | Cutoff scores | 42 | 108 | 46 | 104
| | | | | ≥10
| | | | | | 19%
| | | | | Instrument | Screened | | Diagnosed
| | | | Major or minor | BDI-II | + | - | + | - | 57 | 97 | 19 | 0.44
| | | | | Cutoff scores | 29 | 121 | 46 | 104
| | | | | ≥15
| | | | | | 19%
| | | | | Instrument | Screened | | Diagnosed
| | | | Major or minor | PDSS | + | - | + | - | 91 | 72 | 3.25 | 0.13
| | | | | Cutoff scores | NR | NR | 46 | 104
| | | | | ≥ 61
| | | | | | 8.7%
Author | Sample size | Age | Instrument | | Instrument | Screened | | Diagnosed
Boyce et al., 1993 | 103 | Mean: 28.4 yrs | DIS administered by a psychologist | Major | EPDS | + | - | + | - | 100 | 96 | 2.50 | NA
Quality rating | Place | Race/ethnicity | Diagnostic criteria | | Cutoff scores | 13 | 90 | 9 | 94
16 | Australia | NR | DSM-III-R | | ≥13
| Recruitment setting | Inclusion/exclusion criteria | Timing | | | 8.7%
| Mother's Advisory Clinics | Included: ≤ 6 mos PP | Mean: 12 wks PP (SD 6.8 wks) | | Instrument | Screened | | Diagnosed
| | Excluded: Puerperal psychosis | Median: 10 wks PP | Major | EPDS | + | - | + | - | 100 | 89 | 9.09 | NA
| | | Range: 2 to 29 wks | | Cutoff scores | 19 | 84 | 9 | 94
| | | Time lag between screening and gold standard NR | | ≥ 13
| | | | | | 9%
Author | Sample size | Age | Instrument | | Instrument | Screened | | Diagnosed
Campbell and Cohn, 1991 | 1007 | NR | Modified SADS | Major | CES-D | + | - | + | - | 43.5 | 96.7 | 14.3 | 0.59
Quality rating | Place | Race/ethnicity | Diagnostic criteria | | Cutoff scores | 70 | 937 | 92 | 915
19 | USA | Caucasian: 100% | RDC | | ≥21
| Recruitment setting | Inclusion/exclusion criteria | Timing | | | 9%
| Women who delivered in urban tertiary women's hospital | Included: Primiparous; full-term, singleton delivery; Caucasian; married; at least 18 yrs of age; at least HS education | 6 to 8 wks PP (same time as screening) | | Instrument | Screened | | Diagnosed
| | Excluded: Major delivery complications, adoptive or stepchildren in the home | | Major | CES-D | + | - | + | - | 59.8 | 91.6 | 7.11 | 0.44
| | | | | Cutoff scores | 132 | 875 | 92 | 915
| | | | | ≥ 16
| | | | | | 6.25%
Author | Sample size | Age | Instrument | | Instrument | Screened | | Diagnosed
Cox et al., 1996 | 128 | Mean: 27.2 yrs | SPI | Major | EPDS | + | - | + | - | 75 | 84 | 4.7 | 0.30
Quality rating | Place | Race/ethnicity | Diagnostic criteria | | Cutoff scores | 25 | 103 | 8 | 120
13 | UK | NR | RDC | | ≥13
| Recruitment setting | Inclusion/exclusion criteria | Timing | | | 6.25%
| PP women recruited from GP age/sex registries | None | Occurred subsequent to initial EPDS but exact timing NR | | Instrument | Screened | | Diagnosed
| | | | Major | EPDS | + | - | + | - | 88 | 76 | 3.7 | 0.16
| | | | | Cutoff scores | 36 | 92 | 8 | 120
| | | | | ≥ 12
| | | | | | 6.25%
| | | | | Instrument | Screened | | Diagnosed
| | | | Major | EPDS | + | - | + | - | 88 | 77 | 3.0 | 0.17
| | | | | Cutoff scores | 42 | 86 | 8 | 120
| | | | | ≥ 10
| | | | | | 16.41%
| | | | | Instrument | Screened | | Diagnosed
| | | | Major or minor | EPDS | + | - | + | - | 62 | 89 | 5.6 | 0.43
| | | | | Cutoff scores | 25 | 103 | 21 | 107
| | | | | ≥ 13
| | | | | | 16.41%
| | | | | Instrument | Screened | | Diagnosed
| | | | Major or minor | EPDS | + | - | + | - | 76 | 81 | 4.0 | 0.30
| | | | | Cutoff scores | 36 | 92 | 21 | 107
| | | | | ≥ 12
| | | | | | 16.41%
| | | | | Instrument | Screened | | Diagnosed
| | | | Major or minor | EPDS | + | - | + | - | 81 | 77 | 3.5 | 0.25
| | | | | Cutoff scores | 42 | 86 | 21 | 107
| | | | | ≥ 10
| | | | | | 15%
Author | Sample size | Age | Instrument | | Instrument | Screened | | Diagnosed
Harris et al., 1989 | 147 | Mean: 24.6 yrs | Raskin 3 Area Scale for Depression and MADRS conducted by experienced psychiatrist | Major | EPDS | + | - | + | - | 95 | 93 | 13.57 | 00.54
Quality rating | Place | Race/ethnicity | Diagnostic criteria | | Cutoff scores | 21 | 105 | 22 | 104
13 | Wales | NR | DSM-III | | ≥13
| Recruitment setting | Inclusion/exclusion criteria | Timing | | | 15%
| Prior study of women delivering at Caerphilly Miners' Hospital | Included: Women with (n = 65) and without (n = 82) autoimmune thyroid disorder | 6 wks PP the clinical interview was conducted at the PP followup visit; screening instruments were completed subsequently at home and mailed back within 2 wks | | Instrument | Screened | | Diagnosed
| | Excluded: All other thyroid disorders | | Major | EPDS | + | - | + | - | 100 | 82 | 3.6 | 0.0
| | | | | Cutoff scores | 41 | 85 | 22 | 104
| | | | | ≥10
| | | | | | 15%
| | | | | Instrument | Screened | | Diagnosed
| | | | Major | BDI | + | - | + | - | 32 | 99 | 32 | 0.69
| | | | | Cutoff scores | NR | NR | 19 | 110
| | | | | ≥21
| | | | | | 15%
| | | | | Instrument | Screened | | Diagnosed
| | | | Major | BDI | + | - | + | - | 63 | 92 | 7.9 | 0.40
| | | | | Cutoff scores | NR | NR | 19 | 110
| | | | | ≥13
| | | | | | 15%
| | | | | Instrument | Screened | | Diagnosed
| | | | Major | BDI | + | - | + | - | 68 | 88 | 5.67 | 0.364
| | | | | Cutoff scores | 26 | 103 | 19 | 110
| | | | | ≥11
| | | | | | C: 5%
| | | | | | B: 8%
Author | Sample size | Age | Instrument | | Instrument | Screened | | Diagnosed | | C: 70 | C: 93 | C: 9.45 | C: 0.32
Leverton and Elliott, 2000 | 199 | NR | PSE conducted by a psychiatrist | Major or minor | EPDS | + | - | + | - | B: 44 | B: 92 | B: 5.50 | B: 0.61
Quality rating | Place | Race/ethnicity | Diagnostic criteria | | Cutoff scores | C: 21 | C: 178 | C: 10 | C: 189
13 | England | NR | One classification determined by Bedford (B) College criteria (gives diagnosis consistent with current MDE criteria and a “borderline depression” diagnosis consistent with minor depression) and another by Catego (C) diagnoses | | ≥13 | B: 21 | B: 178 | B: 16 | B: 183
| Recruitment setting | Inclusion/exclusion criteria | Timing | | | C: 5%
| Prenatal clinic | Included: Women expecting their 1st or 2nd child and designated as vulnerable on the Leverton Questionnaire for vulnerability | 3 mos PP | | | B: 8%
| | | | | Instrument | Screened | | Diagnosed
| | | | Major or minor | EPDS | + | - | + | -
| | | | | Cutoff scores | C: 39 | C: 160 | C: 10 | C: 189 | C: 90 | C: 84 | C: 5.62 | C: 0.12
| | | | | ≥10 | B: 39 | B: 160 | B: 16 | B: 183 | B: 69 | B: 85 | B: 4.60 | B: 0.36
| | | | | | NR
Author | Sample size | Age | Instrument | | Instrument | Screened | | Diagnosed
Murray and Carothers, 1990 | 646 | NR | SPI | Major and minor | EPDS | + | - | + | - | 73.1 | 97.5 | 29.2 | 0.28
Quality Rating | Place | Race/ethnicity | Diagnostic criteria | | Cutoff scores | NR | NR | NR | NR
15 | England | NR | RDC | | ≥14
| Recruitment setting | Inclusion/exclusion criteria | Timing | | | NR
| PP wards | Included: 20 to 40 yrs of age, married or cohabitating, primiparous, healthy infant | Interview conducted presumably a couple of wks later than EPDS, which was conducted at 6 wks PP | | Instrument | Screened | | Diagnosed
| | | | Major and minor | EPDS | + | - | + | - | 81.1 | 95.7 | 18.9 | 0.20
| | | | | Cutoff scores | NR | NR | NR | NR
| | | | | ≥13
| | | | | | NR
| | | | | Instrument | Screened | | Diagnosed
| | | | Major and minor | EPDS | + | - | + | - | 88.0 | 92.5 | 13.5 | 0.24
| | | | | Cutoff scores | NR | NR | NR | NR
| | | | | ≥12
| | | | | | 6%
Author | Sample size | Age | Instrument | | Instrument | Screened | | Diagnosed
Murray and Cox, 1990 | 100 | Mean: 24.6 yrs | SPI | Major | EPDS | + | - | + | - | 100 | 96 | 25.0 | 0.0
Quality rating | Place | Race/ethnicity | Diagnostic criteria | | Cutoff scores | 10 | 90 | 6 | 94
16 | UK | NR | RDC | | ≥ 15
| Recruitment setting | Inclusion/exclusion criteria | Timing | | | 6%
| Prenatal clinic of a large maternity hospital | Included: All women between 28 and 34 wks GA | 28 to 34 wks GA | | Instrument | Screened | | Diagnosed
| | | | Major | EPDS | + | - | + | - | 100 | 94 | 16.6 | 0.0
| | | | | Cutoff scores | 12 | 88 | 6 | 94
| | | | | ≥ 14
| | | | | | 6%
| | | | | Instrument | Screened | | Diagnosed
| | | | Major | EPDS | + | - | + | - | 100 | 87 | 7.7 | 0.0
| | | | | Cutoff scores | 18 | 82 | 6 | 94
| | | | | ≥ 13
| | | | | | 6%
| | | | | Instrument | Screened | | Diagnosed
| | | | Major | EPDS | + | - | + | - | 100 | 79 | 4.8 | 0.0
| | | | | Cutoff scores | 26 | 74 | 6 | 94
| | | | | ≥ 12
| | | | | | 14%
| | | | | Instrument | Screened | | Diagnosed
| | | | Major or minor | EPDS | + | - | + | - | 57 | 95 | 11.4 | 0.45
| | | | | Cutoff scores | 21 | 79 | 14 | 86
| | | | | ≥ 14
| | | | | | 14%
| | | | | Instrument | Screened | | Diagnosed
| | | | Major or minor | EPDS | + | - | + | - | 64 | 90 | 6.4 | 0.4
| | | | | Cutoff scores | 28 | 72 | 14 | 86
| | | | | ≥ 13
| | | | | | 14%
| | | | | Instrument | Screened | | Diagnosed
| | | | Major or minor | EPDS | + | - | + | - | 64 | 80 | 3.2 | 0.45
| | | | | Cutoff scores | 40 | 60 | 14 | 86
| | | | | ≥ 12
| | | | | | 14%
| | | | | Instrument | Screened | | Diagnosed
| | | | Major or minor | EPDS | + | - | + | - | 71 | 72 | 2.5 | 0.40
| | | | | Cutoff scores | 48 | 52 | 14 | 86
| | | | | ≥ 11
| | | | | | 17.5%
Author | Sample size | Age | Instrument | | Instrument | Screened | | Diagnosed
Whiffen 1988 | 120 | Mean: 28 yrs | SADS | Major or minor | BDI | + | - | + | - | 47.6 | 85.9 | 3.38 | 0.61
Quality rating | Place | Race/ethnicity | Diagnostic criteria | | Cutoff scores | 24 | 96 | 21 | 99
10 | Ontario, Canada | NR | RDC | | ≥ 9
| Recruitment setting | Inclusion/exclusion criteria | Timing
| Public health prenatal classes | Included: 18 yrs of age or older, married or common-law, low risk for pregnancy complications, primiparous | 7.6 days (± 5.9) after screening, which was conducted 6 to 8 wks PP

Evidence Table 3. Key Question 2: Studies of screening tools for detecting depression during pregnancy and first year postpartum: Abstract form results (non-English)

Author, Year | Study Characteristics | Population Description | Criterion Standard | Diagnosis | Screening Method | Prevalence | | | | Sensit. | Specific. | Likelihood Ratio
Quality Rating | | | | | | No. Screened & Diagnosed | | | | % | % | + | -
| | | | | | 6.6%
Author | Sample size | Age | Instrument | | Instrument | Screened | | Diagnosed
Berle et al., 2003 | 411 | Mean: 30.2 yrs | MINI-V4.4 and MADRS | Major | EPDS (Norwegian version) | + | - | + | - | 56 | 89 | 5.09 | 0.49
Quality rating | Place | Race/ethnicity | Diagnostic criteria | | Cutoff scores | 57 | 354 | 27 | 384
13 | Norway | NR | DSM-IV | | ≥13
| Recruitment setting | Inclusion/exclusion criteria | Timing | | | 6.6%
| PP clinics | None | 6 to 12 wks PP | | Instrument | Screened | | Diagnosed
| | | | Major | EPDS (Norwegian version) | + | - | + | - | 78 | 82 | 4.33 | 0.27
| | | | | Cutoff scores | 90 | 321 | 27 | 384
| | | | | ≥12
| | | | | | 6.6%
| | | | | Instrument | Screened | | Diagnosed
| | | | Major | EPDS (Norwegian version) | + | - | + | - | 96 | 75 | 3.84 | 5.33
| | | | | Cutoff scores | 122 | 289 | 27 | 384
| | | | | ≥11
| | | | | | 10%
| | | | | Instrument | Screened | | Diagnosed
| | | | Major or minor | EPDS (Norwegian version) | + | - | + | - | 0.83 | 0.83 | 3.1 | 0.32
| | | | | Cutoff scores | 53 | 44 | 41 | 59
| | | | | ≥11
| | | | | | 10%
| | | | | Instrument | Screened | | Diagnosed
| | | | Major or minor | EPDS (Norwegian version) | + | - | + | - | 0.49 | 0.95 | 18 | 0.14
| | | | | Cutoff scores | 59 | 39 | 41 | 59
| | | | | ≥13
| | | | | | 10%
| | | | | Instrument | Screened | | Diagnosed
| | | | Major or minor | EPDS (Norwegian version) | + | - | + | - | 0.95 | 0.51 | 19.3 | 0.10
| | | | | Cutoff scores | 72 | 26 | 41 | 59
| | | | | ≥9
| | | | | | 3.5%
Author | Sample size | Age | Instrument | | Instrument | Screened | | Diagnosed
Garcia-Esteve et al., 2003 | 1123 | NR | SCIP-NP | Major | EPDS (Spanish version): 10/11 | + | - | + | - | 86.1 | 95.4 | 14.6 | 0.15
Quality rating | Place | Race/ethnicity | Diagnostic criteria | | Cutoff scores | 44 | 280 | 36 | 288
18 | Spain | NR | DSM-III-R | | ≥13
| Recruitment setting | Inclusion/exclusion criteria | Timing | | | 3.5%
| Public maternity hospital | Included: Women attending routine PP checkup | 6 wks PP | | Instrument | Screened | | Diagnosed
| | Excluded: Not fluent in Spanish, mourning, organic depression | | Major | EPDS (Spanish version): 10/11 | + | - | + | - | 91.7 | 94.1 | 15.5 | 0.09
| | | | | Cutoff scores | 50 | 274 | 36 | 288
| | | | | ≥12
| | | | | | 3.5%
| | | | | Instrument | Screened | | Diagnosed
| | | | Major | EPDS (Spanish version): 10/11 | + | - | + | - | 100 | 91.8 | 12.2 | NA
| | | | | Cutoff scores | 60 | 264 | 36 | 288
| | | | | ≥ 11
| | | | | | 3.5%
| | | | | Instrument | Screened | | Diagnosed
| | | | Major | EPDS (Spanish version): 10/11 | + | - | + | - | 100 | 88.8 | 4.7 | NA
| | | | | Cutoff scores | 68 | 256 | 36 | 288
| | | | | ≥10
| | | | | | 5.7%
| | | | | Instrument | Screened | | Diagnosed
| | | | Major or minor | EPDS (Spanish version): 10/11 | + | - | + | - | 62.0 | 98.1 | 32.7 | 0.39
| | | | | Cutoff scores | 66 | 258 | 100 | 224
| | | | | ≥13
| | | | | | 5.7%
| | | | | Instrument | Screened | | Diagnosed
| | | | Major or minor | EPDS (Spanish version): 10/11 | + | - | + | - | 70.0 | 97.3 | 25.9 | 0.31
| | | | | Cutoff scores | 76 | 248 | 100 | 224
| | | | | ≥12
| | | | | | 5.7%
| | | | | Instrument | Screened | | Diagnosed
| | | | Major or minor | EPDS (Spanish version): ≥ 10 | + | - | + | - | 79.0 | 95.5 | 17.6 | 0.22
| | | | | Cutoff scores | 89 | 245 | 100 | 224
| | | | | ≥11
| | | | | | 5.7
| | | | | Instrument | Screened | | Diagnosed
| | | | Major or minor | EPDS (Spanish version): ≥ 9 | + | - | + | - | 89.0 | 99.3 | 14.6 | 0.02
| | | | | Cutoff scores | 104 | 220 | 100 | 224
| | | | | ≥ 10
| | | | | | 51.7%
Author | Sample size | Age | Instrument | | Instrument | Screened | | Diagnosed
Guedeney and Fermanian, 1998 | 87 | Mean: 30.4 yrs | PSE | Major or minor | EPDS (French version) | + | - | + | - | 60 | 97 | 20 | 0.41
Quality rating | Place | Race/ethnicity | Diagnostic criteria | | Cutoff scores | 28 | 59 | 45 | 42
18 | France | NR | RDC | | ≥13
| Recruitment setting | Inclusion/exclusion criteria | Timing | | | 51.7%
| Infant health clinics | Included: Living in Paris, fluent in French, 1st 4 mos PP | Up to 4 mos PP | | Instrument | Screened | | Diagnosed
| | Excluded: History of psychotic illness or PP psychosis | | Major or minor | EPDS (French version) | + | - | + | - | 73 | 95 | 14.6 | 0.28
| | | | | Cutoff scores | 33 | 54 | 45 | 42
| | | | | ≥12
| | | | | | 51.7%
| | | | | Instrument | Screened | | Diagnosed
| | | | Major or minor | EPDS (French version) | + | - | + | - | 80 | 92 | 10 | 0.22
| | | | | Cutoff scores | 39 | 48 | 45 | 42
| | | | | ≥ 11
| | | | | | 1st trim: 12.5%
Author | Sample size | Age | Instrument | | Instrument | Screened | | Diagnosed
Kitamura et al., 1994 | 120 | Mean: 28 yrs | SADS conducted by two psychiatrists blinded to results of the other screening methods | Major or minor | SDS | + | - | + | - | 90.9 | 70.0 | 3.03 | 0.13
Quality rating | Place | Race/ethnicity | Diagnostic criteria | | Cutoff scores | 108 | 98 | 12 | 96
11 | Japan | Japanese | RDC | | ≥22
| Recruitment setting | Inclusion/exclusion criteria | Timing | | | 3rd trim: 10%
| Dept. of obstetrics of a general hospital | Included: Pregnant women attending prenatal clinic | Directly following each screen conducted: | | Instrument | Screened | | Diagnosed
| | Excluded: At or over 12 wks GA | • early pregnancy | Major or minor | SDS | + | - | + | - | 70.0 | 76.1 | 2.93 | 0.39
| | | • late pregnancy | | Cutoff scores | 98 | 88 | 10 | 88
| | | • 5 days PP | | ≥22
| | | • 1 mo PP | | | PP day 5: 7.1%
| | | | | Instrument | Screened | | Diagnosed
| | | | Major or minor | SDS | + | - | + | - | 27.3 | 85.0 | 1.82 | 0.85
| | | | | Cutoff scores | 11 | 80 | 6 | 85
| | | | | ≥22
| | | | | | PP mo 1: 7.4%
| | | | | Instrument | Screened | | Diagnosed
| | | | Major or minor | SDS | + | - | + | - | 44.9 | 88.0 | 3.74 | 0.63
| | | | | Cutoff scores | 9 | 92 | 7 | 94
| | | | | ≥22
| | | | | | NR%
Author | Sample size | Age | Instrument | | Instrument | Screened | | Diagnosed
Lawrie et al., 1998 | 103 | 28.1 yrs | Structured interview and MADRS | Major or minor | EPDS | + | - | + | - | 87.5 | 72.3 | 3.16 | 0.17
Quality rating | Place | Race/ethnicity | Diagnostic criteria | | Cutoff scores | 7 | 96 | NR | NR
20 | South Africa | Black | DSM-IV | | ≥13
| Recruitment setting | Inclusion/exclusion criteria | Timing | | | NR%
| PP clinic | Included: Women who had obsterical complications, cesareans, or requested sterilization | Starting at 6 wks PP over 3-mo period | | Instrument | Screened | | Diagnosed
| | | | Major or minor | EPDS | + | - | + | - | 100.0 | 58.5 | 2.41 | NA
| | | | | Cutoff scores | NR | NR | NR | NR
| | | | | ≥10
| | | | | | NR%
| | | | | Instrument | Screened | | Diagnosed
| | | | Major or minor | EPDS | + | - | + | - | 100.0 | 51.1 | 2.04 | NA
| | | | | Cutoff scores | NR | NR | NR | NR
| | | | | ≥ 9
| | | | | | 6.1%
Author | Sample size | Age | Instrument | | Instrument | Screened | | Diagnosed
Lee et al., 2001 | 781 | Mean: 29 yrs | SCID (all women who had ≥5 on GHQ and 10% of women with <5) | Major | GHQ | + | - | + | - | NR | NR | NR | NR
Quality rating | Place | Race/ethnicity | Diagnostic criteria | | Cutoff scores | NR | NR | 26 | 127
14 | Hong Kong | Chinese | DSM-III-R | | ≥5
| Recruitment setting | Inclusion/exclusion criteria | Timing | | | 11.2%
| Prenatal clinic of a univ. hospital | Excluded: Not of Chinese ethnicity, no long-term residential rights | 3 mos PP | | Instrument | Screened | | Diagnosed
| | | | Major or minor | GHQ | + | - | + | - | 95 | 68 | 2.97 | 0.07
| | | | | Cutoff scores | 1 | 62 | 45 | 82
| | | | | ≥5
| | | | | | 12%
Author | Sample size | Age | Instrument | | Instrument | Screened | | Diagnosed
Lee et al., 2000 | 145 | Mean: 29 yrs | SCID-NP (nonpatient version; Chinese) | Major or minor | EPDS | + | - | + | - | 82 | 86 | 5.86 | 0.21
| | Range: 16 to 42 yrs | | | Cutoff scores | 32 | 113 | 17 | 128
Quality rating | Place | Race/ethnicity | Diagnostic criteria | | ≥10
16 | Hong Kong | Chinese | DSM-III-R | | | 12%
| Recruitment setting | Inclusion/exclusion criteria | Timing | | Instrument | Screened | | Diagnosed
| PP ward of a university hospital | Included: All Chinese women admitted to PP ward of Dept. of ob/gyn from 11/1996 to 1/1997 | 6 wks PP | Major or minor | GHQ | + | - | + | - | 88 | 89 | 8.00 | 0.13
| | Excluded: Non-Chinese women and those who did not have permanent residency in Hong Kong | | | Cutoff scores | 29 | 16 | 17 | 128
| | | | | ≥5
| | | | | | 12%
| | | | | Instrument | Screened | | Diagnosed
| | | | Major or minor | BDI-II | + | - | + | - | 0.94 | 0.86 | 6.71 | 0.07
| | | | | Cutoff scores | 34 | 111 | 17 | 128
| | | | | ≥10
| | | | | | 12%
Author | Sample size | Age | Instrument | | Instrument | Screened | | Diagnosed
Lee et al., 1998 | 330 eligible, 220 (67%) agreed to participate, 145 (66 % participants) completed 6-wk followup assessment | Mean: 29 yrs | Chinese nonpatient version of SCID modified to allow diagnosis of DSM IV-minor depressive disorder and to make “6-wk” rather than “1-wk” diagnoses | Major or minor | Chinese version of the EPDS | + | - | + | - | 82 | 86 | 5.86 | 1.16
| | Range: 16 to 42 yrs | | | Cutoff Scores | 32 | 113 | 17 | 128
Quality rating | Place | Race/ethnicity | Diagnostic criteria | | ≥10
20 | Hong Kong | Asian | DSM-IV | | | 12%
| Recruitment setting | Inclusion/exclusion criteria | Timing | | Instrument | Screened | | Diagnosed
| PP wards of the Prince of Wales Hospital in Hong Kong from 11/1996 to 1/1997 | Included: Chinese women admitted to PP wards | Interviewed at 6 wks PP Screened 2 days PP and 6 wks PP | Major or minor | GHQ | + | - | + | - | 88 | 89 | 8.0 | 0.13
| | Excluded: Non-Chinese nonpermanent Hong Kong residents (i.e., illegal immigrants) | | | Cutoff scores | 31 | 116 | 19 | 128
| | | | | ≥5
| | | | | | 12%
Author | Sample size | Age | Instrument | | Instrument | Screened | | Diagnosed
Muzik et al., 2000 | 50 | Mean: 28 yrs | SCID-German version by psychiatrist | Major | EPDS | + | - | + | - | 66 | 92 | 8.25 | 0.37
| | Range: 21 to 40 yrs | | | Cutoff scores | 10 | 40 | 10 | 40
Quality rating | Place | Race/ethnicity | Diagnostic criteria | | ≥11
10 | Austria | NR | DSM-III-R | | | 12%
| Recruitment setting | Inclusion/exclusion criteria | Timing | | Instrument | Screened | | Diagnosed
| Prior study participants | Included: Women in a larger study with EPDS ≥7 at either 3 or 6 mos PP | 3 or 6 mos PP (did not clarify, implies near time of screen) | Major | SDS | + | - | + | - | 89 | 77 | 3.87 | 0.14
| | | | | Cutoff scores | 18 | 32 | 10 | 40
| | | | | ≥50
| | | | | | 12%
| | | | | Instrument | Screened | | Diagnosed
| | | | Major | SCLR-90 | + | - | + | - | 78 | 87 | 6.00 | 0.25
| | | | | Cutoff scores | 13 | 37 | 10 | 40
| | | | | ≥50
| | | | | | 44%
Author | Sample size | Age | Instrument | | Instrument | Screened | | Diagnosed
Wickberg and Hwang. 1996 | 128 women used in validation study drawn from a sample of 1655 women screened | Mean: 28.1 yrs | MADRS | Major | EPDS | + | - | + | - | 85 | 63 | 2.27 | 0.25
| | Range: 18 to 42 yrs | | | Cutoff scores | 47 | 45 | 56 | 72
Quality rating | Place | Race/ethnicity | Diagnostic criteria | | ≥13
18 | Sweden | NR | DSM-III-R | | | 44%
| Recruitment setting | Inclusion/exclusion criteria | Timing | | Instrument | Screened | | Diagnosed
| 17 child health clinics near Göteberg, Sweden, and Möindal | Included: Swedish speaking, completed both screenings, score > 11.5 on both or 2nd screening or else randomly chosen to be one of 37 who scored less than 12 | 1 to 2 wks after completing the EPDS screen, which was conducted 2 and 3 mos PP | Major | EPDS | + | - | + | - | 96 | 49 | 1.89 | 0.08
| | Excluded: Already seeing a GP/psych for depression, refusal to participate | | | Cutoff scores | 128 | 37 | 56 | 72
| | | | | ≥12
| | | | | | NR%
Author | Sample size | Age | Instrument | | Instrument | Screened | | Diagnosed | | T1:82 | T1:95 | T1:16.4 | T1:0.19
Yamashita et al., 2000 | 88 | Mean: 31 yrs | SADS conducted by psychiatrists | Major or minor | EPDS | + | - | + | - | T2:NR | T2:NR | T2:NR | T2:NR
| | Range: 19 to 41 yrs | | | Cutoff scores | T1:12 | T1:64 | T1:11 | T1:64
Quality rating | Place | Race/ethnicity | Diagnostic criteria | | ≥9 | T2:NR | T2:71 | T2:15 | T2:78
8 | Japan | Asian | RDC
| Recruitment setting | Inclusion/exclusion criteria | Timing
| Maternity ward of a university hospital | Included: Pregnant, Japanese | Screening was conducted at 1 mo PP (T1) visit and by mail 3 mos PP (T2)
| | | | | | 12%
Author | Sample size | Age | Instrument | | Instrument | Screened | | Diagnosed
Yoshida et al., 1997 | 98 | Mean: 30 yrs | SADS | Major or minor | EPDS | + | - | + | - | 25 | 96 | 6.25 | 0.78
Quality rating | Place | Race/ethnicity | Diagnostic criteria | | Cutoff scores | 6 | 91 | 8 | 89
12 | England | Asian | RDC | | ≥9
| Recruitment setting | Inclusion/exclusion criteria | Timing | | | 12%
| • Prenatal classes for pregnant women | Included: Pregnant, Japanese | 3 mos PP (covered retrospective diagnosis at 1 mo as well as current diagnosis at 3 mos | | Instrument | Screened | | Diagnosed
| • Advertisement in a maternity guidebook for pregnant Japanese women in UK | | | Major or minor | EPDS | + | - | + | - | 50 | 80 | 2.50 | 0.63
| | | | | Cutoff scores | 22 | 75 | 8 | 89
| | | | | ≥7

Evidence Table 4. Key Question 3: Studies of screening interventions for perinatal depression: Screening during pregnancy

Author, Year | Study Characteristics | Population Description | Treatment | Assessment Timing | Depression Outcomes | Other Outcomes
Quality Rating
Author | Place | Age | Intervention group | 3 mos PP | GHQ-D ≥ 2 | Social support
Brugha et al., 2000 | UK | Median: 19 yrs | Preparing for Parenthood Intervention—six structured, 2-hour-long prenatal classes and a PP reunion class at 8 wks PP designed to increase social support and present problem-solving skills | | Intervention: 26% | Intervention had no statistically significant impact on social support
Quality rating | Recruitment setting | Range: 16 to 38 yrs | Control group | | Control: 22%
17 | Prenatal clinic of a UK general hospital | Race/ethnicity | Routine prenatal care | | Adjusted OR: 1.19 (95% CI, 0.59 to 2.37)
| Sample size | European: 73% | | | EPDS ≥ 11
| No. randomized: Intervention: 103 | Asian and other: 27% | | | Intervention: 16%
| Control: 106 | Depression risk criteria | | | Control: 19%
| No. analyzed: | Instrument: Modified GHQ-D | | | Adjusted OR: 0.83 (95% CI, 0.39 to 1.79)
| Intervention: 94 | Cutoff scores: Presence of one of six depression items | | | Diagnosis of depression using SCAN and ICD-10 criteria
| Control: 96 | Screen timing: 12 to 20 wks GA | | | Intervention: 3%
| Design | Other inclusion criteria | | | Control: 6%
| RCT | Included: 16+ yrs of Age, 1st pregnancy, English speaking, living within travel distance of hospital | | | Adjusted OR: 0.47 (95% CI, 0.11 to 1.96)
Author | Place | Age | Intervention group | 3 mos PP and 1 yr PP | EPDS Score | NR
Elliott et al., 2000 | UK | NR | “Preparing for Parenthood” for 1st-time mothers and “Surviving Parenthood” for 2nd-time mothers, which included meetings run by a psychologist and health visitor held monthly for 5 mos during pregnancy, starting at 24 wks GA and continuing for 6 mos PP and included a mid-pregnancy health visitor visit | | 1st-time mothers at 3 mos:
Quality rating | Recruitment setting | Race/ethnicity | Control group | | Intervention: median 3.0, range 0 to 17, SD 4.48
11 | Prenatal clinic | NR | Routine prenatal and PP care | | Control: median 8.0, range 1 to 16, SD 4.53
| Sample size | Depression risk criteria | | | Mann-Whitney: 141, one-tailed P = 0.005
| Intervention: 47 | Instrument: | | | 2nd-time mothers at 3 mos:
| Control: 51 | LQ and the depression, anxiety, and somatic subscales of the CCEI | | | Intervention: median 6.5, range 1 to 247, SD 6.10
| Design | Cutoff scores: | | | Control: median 9.0, range 1 to 23, SD 6.60
| Controlled trial | • Score of 2 on any one vulnerability question on the LQ or score of 1 on more than one vulnerability question | | | Mann-Whitney: 319, one-tailed P = NS
| | -OR- | | | 1st- and 2nd-time mothers at 12 mos:
| | • Score of ≥ 10 on CCEI anxiety subscale | | | No significant differences
| | -OR- | | | CCEI & SRQ
| | • 2nd-time mothers who felt more tense or depressed than usual after birth of 1st child | | | Results were similar to those for EPDS
| | Screen timing: | | | Diagnosis of depression using the PSE
| | 1st prenatal clinic appointment | | | 1st- and 2nd-time mothers at 3 mos and 1 yr:
| | Other inclusion criteria | | | No significant differences
| | Included: 1st- and 2nd-time mothers in ongoing relationships attending the same clinic in the same 6-mo window | | | Diagnosis of borderline or case depressions using Bedford College Criteria
| | | | | 1st-time mothers at 3 mos:
| | | | | Intervention: 19% borderline or case depressions
| | | | | Control: 39% borderline or case depressions
| | | | | X ^ 2 ^(1): 2.64, one-tailed P < 0.05
| | | | | 2nd-time mothers at 3 mos:
| | | | | No significant differences
Author | Place | Age | Intervention group | 6 wks, 12 wks, and 6 mos | EPDS > 9 (6 wks) | NR
Stamp et al., 1995 | Australia | Intervention: mean 25.6 (SD 4.4) yrs | 2 prenatal groups at 32 and 26 wks GA plus 1 PP group held at 6 wks. Groups were a combination of education and social and psychological support | | Intervention: 34%
Quality rating | Recruitment setting | Control: mean 27.5 (SD 5.2) yrs | Control group | | Control: 34%
13 | Prenatal clinics of a tertiary referral Women's and Children's Hospital (no privately insured women attend these clinics) | Race/ethnicity | Routine prenatal care | | OR: 1.00 (95% CI, 0.45 to 2.21)
| Sample size | NR | | | EPDS > 9 (12 wks)
| Intervention: 64 | Depression risk criteria | | | Intervention: 22%
| Control: 65 | Instrument: Modified prenatal screening questionnaire | | | Control: 26%
| Design | Cutoff scores: ≥ 2 | | | OR: NR
| RCT | Screen timing: ≤ 24 wks GA | | | EPDS > 9 (6 mos)
| | Other inclusion criteria | | | Intervention: 23%
| | Included: English speaking, singleton pregnancy, live in the metropolitan area | | | Control: 16%
| | | | | OR: 1.55 (95% CI, 0.58 to 4.22)
| | | | | EPDS > 12 (6 wks)
| | | | | Intervention: 13%
| | | | | Control: 17%
| | | | | OR: 0.69 (95% CI, 0.23 to 2.03)
| | | | | EPDS > 12 (12 wks)
| | | | | Intervention: 11%
| | | | | Control: 15%
| | | | | OR: 0.69 (95% CI, 0.22 to 2.14)
| | | | | EPDS > 12 (6 mos)
| | | | | Intervention: 15%
| | | | | Control: 10%
| | | | | OR: 1.62 (95% CI, 0.47 to 5.91)
Author | Place | Age | Intervention group | 3 mos | Pre vs. post BDI scores | NR
Zlotnick et al., 2001 | USA | Mean: 23.4 (SD 4.41) yrs | 4 weekly hour-long interpersonal-therapy-oriented survival skills group sessions | | Intervention: 13.0 (SD 6.9) vs. 8.4 (SD 7.8)
Quality rating | Recruitment setting | Range: 18 to 38 yrs | Control group | | Control: 9.2 (SD 6.5) vs. 11.3 (SD 4.8)
12 | Prenatal clinic at a general hospital in the Northeast | Race/ethnicity | Routine care | | t-test(33): 3.50, P = 0.001
| Sample size | Caucasian: 46% | | | Diagnosis of Depression using SCID for DSM-IV
| Intervention: 17 | Other: 54% | | | Intervention: 0%
| Control: 18 | Depression risk criteria | | | Control: 33%
| Design | Instrument: Survey assessing risk factors for perinatal depression | | | X ^ 2 ^(1): P = 0.02
| RCT | Cutoff score: At least 1 risk factor
| | Screen timing: 20 to 32 wks GA
| | Other inclusion criteria
| | Included: Receipt of public assistance, not depressed at screening according to SCID for DSM-IV

Evidence Table 5. Key Question 3: Studies of screening interventions for perinatal depression: Screening during postpartum

Author, Year | Study Characteristics | Population Characteristics | Treatment | Assessment Timing | Depression Outcomes | Other Outcomes
Quality Rating | | Inclusion Criteria
Author | Place | Age | Intervention group | 6 wks PP | Mean EPDS scores | Child health (30-item self-report)
Armstrong et al., 1999 | Australia | < 18 yrs: 6.6% | Home visits by child health nurse—weekly for 1st 6 wks, fortnightly for wks 7 to 13, and monthly for mos 4 to 6 | | Intervention: 5.67 (SD 4.14) | No significant differences in rate of breastfeeding, knowledge or practice of SIDS risk minimizing, or use of health services
Quality rating | Recruitment setting | Race/ethnicity | Control group | | Control: 7.90 (SD 5.89) | Parenting Stress Index (child reinforces parent subscale)
19 | Hospital maternity ward | Aboriginal or Torres Strait Islander: 5.6% intervention and 9.0% control | Routine primary care | | F(1, 169): 7.35, P = 0.004 | Intervention: 9.59 (SD 2.92)
| Sample size | Depression risk criteria | | | EPDS > 12 | Control: 11.12 (SD 3.78)
| Intervention: 90 | Instrument: Adverse family characteristics identified with the Brisbane Evaluation of Needs Questionnaire | | | Intervention: 5.8% | F(1, 169): 8.72, P = 0.004
| Control: 91 | Cutoff score: | | | Control: 20.7% | High scores indicate that parent-child interactions are damaging to parental perception of their competence
| Design | • 1 or more of 1st tier risk factors | | | X ^ 2 ^(1): 8.30, P = 0.003 | HOME Inventory (45 items)
| RCT | -OR- | | | Impact of change in EPDS scores over time was concentrated among the primiparous women | Intervention: 28.34 (SD 2.90)
| | • 3 or more of 2nd tier risk factors | | | | Control: 25.51 (SD 0.59)
| | Screen timing: Immediately following birth | | | | F(1, 169): P < 0.001
| | Other inclusion criteria | | | | Intervention group had significantly better home environment than Control group
| | Included: Good English literacy skills | | | | Patient satisfaction (10 items on health care)
| | | | | | Greater satisfaction was found for the home-based program compared with standard services
Author | Place | Age | Intervention group | 1st intervention: | EPDC ≥ 11 (4 to 6 wks PP) | NR
Chabrol et al., 2002 | France | Intervention: mean 30.4 (SD 4) yrs | 1st intervention: 1-hr educational, supportive and cognitive behavioral session during hospitalization | 4 to 6 wks PP | Intervention: 30.2% depressed
Quality rating | Recruitment setting | Control: mean 29.6 (SD 5) yrs | 2nd intervention: Patients in the Intervention group with EPDS ≥ 11 and depression determined by DSM-IV with MINI after 4 to 6 wks received additional 5 to 8 sessions of an at-home cognitive behavioral therapy program | 2nd intervention: | Control: 48.2% depressed
15 | Hospital maternity ward | Race/ethnicity | Control group | 10 to 12 wks PP | X ^ 2 ^(1): 7.36, P = 0.0067
| Sample size | Caucasian: 100% | Routine primary care | | Mean EPDS scores (4 to 6 wks PP)
| 1st intervention: | Depression risk criteria | | | Intervention: 8.5 (SD 4.0)
| Intervention: 97 | Instrument: EPDS | | | Control: 10.3 (SD 4.4)
| Control: 114 | Cutoff score: ≥ 9 | | | t-test(209): 3.06, P = 0.0024
| 2nd intervention: | Screen timing: Majority at the 2nd and 3rd day PP | | | Mean HDRS scores (10 to 12 wks)
| Intervention: 18 | Other inclusion criteria | | | Intervention: 5.7 (SD 3.3)
| Control: 30 | Included: No current treatment with psychiatrists or psychologists, good French language skills | | | Control: 16.2 (SD 4.5)
| Design | | | | t-test(49): 8.4, P < 0.0001
| Quasi-randomized controlled trial (no randomization for screening, only for treatment) | | | | Mean BDI scores (10 to 12 wks)
| | | | | Intervention: 4.7 (SD 3.0)
| | | | | Control: 15.7 (SD 4.4)
| | | | | t-test(49): 9.0, P < 0.0001
| | | | | Mean EPDS scores (10 to 12 wks)
| | | | | Intervention: 5.9 (SD 2.7)
| | | | | Control: 13.7 (SD 3.6)
| | | | | t-test(49): 7.7, P < 0.0001
| | | | | Recovery rate: HDRS < 7 (10 to 12 wks)
| | | | | Intervention: 66.6%
| | | | | Control: 6.6%
| | | | | X ^2^(1): 16.8, P < 0.0001
| | | | | Recovery rate: BDI < 4 (10 to 12 wks)
| | | | | Intervention: 61.1%
| | | | | Control: 3.3%
| | | | | X ^2^(1): 17.7, P < 0.0001
Author | Place | Age | Intervention group | 15 wks PP | Mean change in BDI score | Mean change in Perceived Stress Scale
Chen et al., 2000 | Taiwan | Mean: 29.1 (SD 4.2) yrs | Support groups of 5 to 6 mothers with their infants and a registered nurse met for 4 weekly sessions of 1.5 to 2 hrs duration | | Intervention: -6.60 (SD 5.89) | Intervention: -3.75 (SD 4.53)
Quality rating | Recruitment setting | Range: 19 to 40 yrs | Control group | | Control: -1.40 (SD 8.33) | Control: -1.30 (SD 4.26)
14 | Hospital maternity wards | Race/ethnicity | No support group | | BDI ≥ 10 | Mean change in Interpersonal Support Evaluation List
| Sample size | NR | | | Intervention: 33.3% | Intervention: 2.60 (SD 5.08)
| Intervention: 30 | Depression risk criteria | | | Control: 60.0% | Control: 0.00 (SD 5.14)
| Control: 30 | Instrument: Taiwanese BDI | | | Significance tests for within-group changes over time were conducted but not for between-group differences in changes over time. (Both groups started out with 100% BDI ≥ 10) | Mean change in Self-Esteem Inventory
| Design | Cutoff score: ≥ 10 | | | | Intervention: 1.03 (SD 4.57)
| RCT | Screen timing: 3 wks PP | | | | Control: 1.03 (SD 2.97)
| | Other inclusion criteria
| | Included: > 18 yrs of age, survival of infant, at least HS education
Author | Place | Age | Intervention group | 4 and 8 wks post-randomization, which occurred 8 to 12 wks PP | EPDS > 9 (after 4 wks of support) | Mean maternal self-esteem score (after 8 wks of support)
Dennis, 2003 | Canada | 18 to 24 yrs: 14% | Lay peer support in the form of a paired peer volunteer (mother who previously had PP depression and attended a 4-hr training) who provided telephone-based peer support | | Intervention: 45.0% | Intervention: 30.00 (SD 4.21)
Quality rating | Recruitment setting | 25 to 34 yrs: 76% | Control group | | Control: 72.7% | Control: 28.57 (SD 3.83)
22 | Child immunization clinics | 35 yrs or over: 10% | Standard community PP services only | | OR: 3.26 (95% CI, 0.90 to 11.81) | Difference not statistically significant
| Sample size | Race/ethnicity | | | EPDS > 9 (after 8 wks of support) | Mean child care stress score (after 8 wks of support)
| Intervention: 20 | NR | | | Intervention: 35.0% | Intervention: 4.95 (SD 2.68)
| Control: 22 | Depression risk criteria | | | Control: 76.2% | Control: 6.48 (SD 3.63)
| Design | Instrument: EPDS | | | OR: 5.94 (95% CI, 1.52 to 23.18) | Difference not statistically significant
| RCT (for intervention, not for screening) | Cutoff score: > 9 | | | EPDS > 12 (after 4 wks of support) | Mean maternal loneliness score (after 8 wks of support)
| | Screen timing: 8 to 12 wks PP | | | Intervention: 10.0% | Intervention: 20.37 (SD 5.23)
| | Other inclusion criteria | | | Control: 40.9% | Control: 23.91 (SD 6.07)
| | Included: At least 18 yrs of age, singleton birth, English-speaking, able to access phone calls, birth at 37 wks GA or more, resided in surrounding region | | | OR: 6.23 (95% CI, 1.15 to 33.77) | Difference not statistically significant
| | | | | X ^2^(1): 5.18, P = 0.02 | Note that baseline measures are also provided but the significance of the difference in changes over time is not computed
| | | | | EPDS > 12 (after 8 wks of support)
| | | | | Intervention: 15.0%
| | | | | Control: 52.4%
| | | | | OR: 6.23 (95% CI, 1.40 to 27.84)
| | | | | Adjusted OR: 4.7 (95% CI, 0.91 to 25.46)
| | | | | X ^2^(1): 6.37, P < 0.01
| | | | | Mean EPDS score (after 4 wks of support)
| | | | | Intervention: 8.5 (SD 3.7)
| | | | | Control: 12.1 (SD 4.6)
| | | | | t-test(40): 2.8, P = 0.008
| | | | | Mean EPDS score (after 8 wks of support)
| | | | | t-test(39): 2.9, P = 0.006
Author | Place | Age | Intervention group | 6 wks and 5 mos | CES mood score | Negative self image
Fleming et al., 1992 | Canada | Range: 22 to 36 yrs | PP social support group meeting for 2 hrs weekly for 8 wks | | No statistically significant effects of the social support intervention compared to either the mail or no Intervention groups | Social support intervention had a statistically significant negative impact
Quality rating | Recruitment setting | Race/ethnicity | Control group 1 | | | Attachment to infant
11 | Hospital maternity ward | NR | Group-by-mail sent weekly information on PP depression on the same topics and schedule as the support group meetings | | | No statistically significant effects of the social support intervention
| Sample size | Depression risk criteria | Control group 2 | | | Maternal-infant interaction
| Intervention: 44 | Instruments: CES, EPDS, MAACL | No intervention | | | Social support intervention had a statistically significant increase in number of approaches to the infant
| Control 1: 15 | Cutoff scores: CES ≥ 35 and either EPDS ≥ 13 or MAACL ≥ 21 | | | | Non-cry vocalizations
| Control 2: 83 | Screen timing: 2 wks PP | | | | Babies of social support women decreased crying from 6 wks to 5 mos whereas those of the other groups either had no change or increased crying
| Design | Other inclusion criteria
| Controlled trial, no randomization | Included: Primiparous, married or cohabiting, full-term vaginal deliveries, no known past or current serious psychiatric or gynecologic histories, English speaking
Author | Place | Age | Intervention group | 2 mos and 4 mos after randomization, which occurred 7 to 9 mos PP | Mean change in EPDS (baseline to 2 mos) | Infant's sleep problems resolved (baseline to 2 mos)
Hiscock and Wake, 2002 | Australia | Intervention: 34.1 (SD 3.6) yrs | Infant Sleep Intervention, comprised three private sessions (one session every 2 wks) held at the local maternal and child health center where sleep management plans included an emphasis on “controlled crying”; (parents were encouraged to respond to their infant's cry at increasing time intervals, allowing the infant to fall asleep by itself) | | Intervention: -6.0 (95% CI, -7.5 to -4.0) | Intervention: 26/33
Quality rating | Recruitment setting | Control: 33.3 (SD 5.6) yrs | Control group | | Control: -3.7 (95% CI, -4.9 to -2.6) | Control: 13/33
19 | Maternal and child health center | Race/ethnicity | Mailed single sheet describing normal sleep patterns | | t-test(64): P = 0.01 | X ^2^(1): P = 0.001
| Sample size | NR | | | Mean change in EPDS (baseline to 4 mos) | Infant's sleep problems resolved (baseline to 4 mos)
| Intervention: 33 | Depression risk criteria | | | Intervention: -6.5 (95% CI, -7.9 to -5.1) | Intervention: 21/32
| Control: 33 | Instrument: EPDS | | | Control: -4.2 (95% CI, -5.9 to -2.5) | Control: 14/30
| Design | Cutoff score: ≥ 10 | | | t-test(64): P = 0.04 | X ^2^(1): P = 0.13
| RCT | Screen timing: 7 to 9 mos PP | | | No significant differences between groups for higher cutoff points | Mother's sleep quality (baseline to 2 mos)
| | Other inclusion criteria | | | | Intervention mothers more likely to rate their own sleep quality as “very good” compared with controls
| | Included: Reported infant sleep problems, adequate English skills to complete questionnaires, not receiving treatment for PP depression, reported no thoughts of self harm, infants had no major medical or developmental problem, not receiving help for infant sleep problems | | | | X ^2^(1): 7.58, P = 0.06
| | | | | | Mother's sleep quality (baseline to 4 mos)
| | | | | | No significant differences between intervention and control women
| | | | | | Mothers report having enough sleep (baseline to 2 mos)
| | | | | | Intervention mothers more likely to report having enough sleep compared with controls
| | | | | | X ^2^(1): 5.00, P = 0.09
| | | | | | Mothers report having enough sleep (baseline to 4 mos)
| | | | | | No significant differences between intervention and control women
| | | | | | Mothers report “no stress” (baseline to 2 mos and baseline to 4 mos)
| | | | | | No significant differences between intervention and control women
Author | Place | Age | Intervention group | At end of 8-wk PEG and 6 mos following end of PEG | Mean EPDS score (baseline) | Social support
Honey et al., 2002 | UK | Intervention: 29.30 (SD 5.36) yrs | PEG consisting of 8 weekly, 2-hr meetings run by health visitors | | Intervention: 19.35 (SD 4.39) | No statistically significant effect of intervention
Quality rating | Recruitment setting | Control: 26.48 (SD 5.68) yrs | Control group | | Control: 17.95 (SD 3.95) | Marital relationship
16 | Referred by health visitor | Race/ethnicity | Routine primary care | | Mean EPDS score (end of 8-wk PEG) | No statistically significant effect of intervention
| Sample size | NR | | | Intervention: 14.87 (SD 5.97) | Coping scales
| Intervention: 23 | Depression risk criteria | | | Control: 16.95 (SD 5.44) | No statistically significant effect of intervention
| Control: 22 | Instrument: EPDS | | | Mean EPDS score (6 mos after PEG)
| Design | Cutoff score: > 12 | | | Intervention: 12.55 (SD 4.62)
| RCT | Screen timing: < 12 mos PP, mean 5.98 mos PP (SD 2.34 mos) | | | Control: 15.63 (SD 7.28)
| | Other inclusion criteria | | | Mean change in EPDS scores (baseline to 6 mos after PEG)
| | Included: Attending mother and baby clinics, not exhibiting psychotic symptoms, most recent child under 12 mos | | | Intervention women had a significant greater decrease in means scores compared to control women
| | | | | F (2, 43): 3.16, P < 0.05
| | | | | EPDS ≤ 12 (end of 8-wk PEG)
| | | | | Intervention: 35%
| | | | | Control: 27%
| | | | | X ^2^(1): 0.30, P > 0.1
| | | | | EPDS ≤ 12 (6 mos after PEG)
| | | | | Intervention: 65%
| | | | | Control: 36%
| | | | | X ^2^(1): 3.75, P ≤ 0.05
Author | Place | Age | Intervention group | 4 to 8 wks PP; 10 to 14 wks PP; and 14 to 18 wks PP | Mean BDI-II score (4 to 8 wks PP) | Mother-infant responsiveness measured by mean DMC score (4 to 8 wks PP)
Horowitz, et al., 2001 | Boston, USA | Mean: 31 yrs | Interactive coaching, Designed to promote maternal-infant responsiveness; composed of three home visits when infants were 4 to 8 wks, 10 to 14 wks, and 14 to18 wks | | Intervention: 15.5 (SD 1.17) | Intervention: 8.83 (SD 1.76)
Quality rating | Recuitment setting | Range: 17 to 41 yrs | Control group | | Control: 13.24 (SD 0.92) | Control: 8.67 (SD 1.64)
15 | Hospital maternity wards | Race/ethnicity | Standard community services | | Mean BDI-II score (10 to 14 wks PP) | Mean DMC score (10 to 14 wks PP)
| Sample size | White: 68.9% | | | Intervention: 10.99 (SD 0.96) | Intervention: 9.73 (SD 1.65)
| Intervention: 60 | Black: 7.4% | | | Control: 10.10 (SD 0.84) | Control: 8.77 (SD 1.72)
| Control: 57 | Hispanic: 7.4% | | | Mean BDI-II score (14 to 18 wks PP) | Mean DMC score (14 to 18 wks PP)
| Design | Mixed: 7.4% | | | Intervention: 10.27 (SD 0.99) | Intervention: 9.55 (SD 1.77)
| RCT | Other: 4% | | | Control: 9.51 (SD 0.77) | Control: 8.80 (SD 1.86)
| | Asian: 3.3% | | | Difference in changes in mean BDI-II scores over time | Difference in changes in mean DMC scores over time
| | Native American: 1.6% | | | F (2, 115): 0.36, P = 0.67 | F (2, 115): 2.14, P = 0.121
| | Depression risk criteria
| | Instrument: EPDS
| | Cutoff score: ≥ 10
| | Screen timing: 2 to 4 wks PP
| | Other inclusion criteria
| | None
Author | Place | Age | Intervention group | 14 wks PP | Median EPDS score (baseline) | All measures of mother-infant interaction showed significantly greater improvement in Intervention group compared with Control group
Onazawa et al., 2001 | UK | Intervention: mean 32 yrs (95% CI, 29.6 to 34.5) | Infant massage class plus support group (1-hr classes weekly for 5 wks). Infant massage class Designed to teach parents the techniques of infant massage by encouraging parents to observe and respond to their infant's body language and cues and to adjust touch accordingly | | Intervention: 15.0 (95% CI, 14.0 to 18.1)
Quality rating | Recruitment setting | Control: mean 33 yrs (95% CI, 31.2 to 35.9) | Control group | | Control: 16.0 (95% CI, 14.7 to 18.7)
16 | Hospital maternity ward | Race/ethnicity | Support group only for 5 wks | | Median EPDS score (final session)
| Sample size | White: 88% | | | Intervention: 5.0 (95% CI, 2.2 to 7.8)
| Intervention: 19 | Other: 12% | | | Control: 10.0 (95% CI, 7.7 to 11.8)
| Control: 15 | Depression risk criteria | | | Change in median EPDS score
| Design | Instrument: EPDS | | | Intervention: 12.0 (94% CI, 8.0 to 14.2)
| RCT | Cutoff score: ≥ 13 | | | Control: 6.0 (95% CI, 4.6 to 9.0)
| | Screen timing: 4 wks PP | | | Z: -2.2, P = 0.03
| | Other inclusion criteria
| | Included: Primiparous, 18 to 45 yrs of age, singleton birth from 37 to 42 wks GA with no congenital abnormalities and not requiring NICU care
Author | Place | Age | Intervention group | 3 mos PP | Recurrence of DSM-III-R major depression | NR
Wisner and Wheeler, 1994 | USA | NR | PP antidepressant medication and monitoring | | Intervention: 6.7%
Quality rating | Recruitment setting | Race/ethnicity | Control group | | Control: 62.5%
12 | University-based, outpatient program for pregnant and PP women | NR | PP monitoring only | | Fisher's exact test, two-tailed: P = 0.0086
| Sample size | Depression risk criteria | | | OR: 19.2 (95% CI, 1.5 to 1,179)
| Intervention: 15 | At least one episode of PP depression in prior pregnancy
| Control: 8 | Other inclusion criteria
| Design | Included: No history of psychosis or bipolar disorder, married or in stable relationship for at least 6 mos, no major obstetrical problems
| Open controlled trial
Author | Place | Age | Intervention group | 20 wks PP | Recurrence of RDC major depression | NR
Wisner et al., 2001 | USA | NR | Nortriptyline | | Intervention: 23%
Quality rating | Recruitment setting | Race/ethnicity | Control group | | Control: 24%
18 | NR | NR | Placebo | | Fisher's exact test, two-tailed: P = 1.00
| Sample size | Depression risk criteria | | | Time to recurrence
| Intervention: 26 | At least one past episode of PP-onset major depression within past 5 yrs | | | No statistically significant difference in time to recurrence between nortriptyline and Placebo.
| Control: 25 | Other inclusion criteria | | | Exact log-rank: < 0.00, P = 0.83
| Design | Included: ≤ 35 weeks GA, 21 to 45 yrs of age, no depressive episode since the conception of index pregnancy, not exposed to antidepressants after 1st trimester, no other Axis I diagnosis except generalized anxiety or panic disorder
| RCT

## References

Affonso D D, Lovett S, Paul S M, et al. A standardized interview that differentiates pregnancy and postpartum symptoms from perinatal clinical depression. Birth. 1990;17(3):121-30. [pmid: 2222637].
Areias M E, Kumar R, Barros H, et al. Comparative incidence of depression in women and men, during pregnancy and after childbirth. Validation of the Edinburgh Postnatal Depression Scale in Portuguese mothers. Br J Psychiatry. 1996;169(1):30-5. [pmid: 8818365].
Armstrong K L, Fraser J A, Dadds M R, et al. A randomized, controlled trial of nurse home visiting to vulnerable families with newborns. J Paediatr Child Health. 1999;35(3):237-44. [pmid: 10404442].
Ballard C G, Davis R, Cullen P C, et al. Prevalence of postnatal psychiatric morbidity in mothers and fathers. Br J Psychiatry. 1994;164(6):782-8. [pmid: 7952984].
Beck C T, Gable R K. Comparative analysis of the performance of the Postpartum Depression Screening Scale with two other depression instruments. Nurs Res. 2001;50(4):242-50. [pmid: 11480533].
Berle J, Aarre T, Mykletun A, et al. Screening for postnatal depression. Validation of the Norwegian version of the Edinburgh Postnatal Depression Scale, and assessment of risk factors for postnatal depression. J Affect Disord. 2003;76(13):151-6. [pmid: 12943945].
Boyce P, Stubbs J, Todd A. The Edinburgh Postnatal Depression Scale: Validation for an Australian sample. Aust N Z J Psychiatry. 1993;27(3):472-6. [pmid: 8250792].
Brugha T S, Wheatley S, Taub N A, et al. Pragmatic randomized trial of antenatal intervention to prevent post-natal depression by reducing psychosocial risk factors. Psychol Med. 2000;30(6):1273-81. [pmid: 11097068].
Bryan T L, Georgiopoulos A M, Harms R W, et al. Incidence of postpartum depression in Olmsted County, Minnesota. A population-based, retrospective study. J Reprod Med. 1999;44(4):351-8. [pmid: 10319305].
Campbell S B, Cohn J F. Prevalence and correlates of postpartum depression in first-time mothers. J Abnorm Psychol. 1991;100(4):594-9. [pmid: 1757673].
Chabrol H, Teissedre F, Saint-Jean M, et al. Prevention and treatment of post-partum depression: A controlled randomized study on women at risk. Psychol Med. 2002;32(6):1039-47. [pmid: 12214785].
Chen C H, Tseng Y F, Chou F H, et al. Effects of support group intervention in postnatally distressed women. A controlled study in Taiwan. J Psychosom Res. 2000;49(6):395-9. [pmid: 11182431].
Cooper P J, Campbell E A, Day A, et al. Non-psychotic psychiatric disorder after childbirth. A prospective study of prevalence, incidence, course and nature. Br J Psychiatry. 1988;152:799-806. [pmid: 3167466].
Cooper P J, Murray L, Hooper R, et al. The development and validation of a predictive index for postpartum depression. Psychol Med. 1996;26(3):627-34. [pmid: 8733220].
Cox J L, Connor Y, Kendell R E. Prospective study of the psychiatric disorders of childbirth. Br J Psychiatry. 1982;140:111-7. [pmid: 7074291].
Cox J L, Murray D, Chapman G. A controlled study of the onset, duration and prevalence of postnatal depression. Br J Psychiatry. 1993;163:27-31. [pmid: 8353695].
Cox J, Chapman G, Murray D, et al. Validation of the Edinburgh Postnatal Depression Scale (EPDS) in non-postnatal women. J Affect Disord. 1996;39(3):185-9. [pmid: 8856422].
Dennis C L. The effect of peer support on postpartum depression: A pilot randomized controlled trial. Can J Psychiatry. 2003;48(2):115-24. [pmid: 12655910].
Elliott S A, Leverton T J, Sanjack M, et al. Promoting mental health after childbirth: A controlled trial of primary prevention of postnatal depression. Br J Clin Psychol. 2000;39(Pt 3):223-41. [pmid: 11033746].
Fleming A S, Klein E, Corter C. The effects of a social support group on depression, maternal attitudes and behavior in new mothers. J Child Psychol Psychiatry. 1992;33(4):685-98. [pmid: 1601943].
Garcia-Esteve L, Ascaso C, Ojuel J, et al. Validation of the Edinburgh Postnatal Depression Scale (EPDS) in Spanish mothers. J Affect Disord. 2003;75(1):71-6. [pmid: 12781353].
Georgiopoulos A M, Bryan T L, Wollan P, et al. Routine screening for postpartum depression. J Fam Pract. 2001;50(2):117-22. [pmid: 11219558].
Gotlib I H, Whiffen V E, Mount J H, et al. Prevalence rates and demographic characteristics associated with depression in pregnancy and the postpartum. J Consult Clin Psychol. 1989;57(2):269-74. [pmid: 2785127].
Guedeney N, Fermanian J. Validation study of the French version of the Edinburgh Postnatal Depression Scale (EPDS): New results about use and psychometric properties. Eur Psychiatry. 1998;13:83-9. [pmid: 19698604].
Harris B, Huckle P, Thomas R, et al. The use of rating scales to identify post-natal depression. Br J Psychiatry. 1989;154:813-7. [pmid: 2597888].
Hiscock H, Wake M. Randomised controlled trial of behavioural infant sleep intervention to improve infant sleep and maternal mood. Br Med J. 2002;324(7345):1062-5. [pmid: 11991909]. [pmcid: 104332].
Hobfoll S E, Ritter C, Lavin J, et al. Depression prevalence and incidence among inner-city pregnant and postpartum women. J Consult Clin Psychol. 1995;63(3):445-53. [pmid: 7608357].
Honey K L, Bennett P, Morgan M. A brief psycho-educational group intervention for postnatal depression. Br J Clin Psychol. 2002;41(Pt 4):405-9. [pmid: 12437794].
Horowitz J A, Bell M, Trybulski J, et al. Promoting responsiveness between mothers with depressive symptoms and their infants. J Nurs Scholarsh. 2001;33(4):323-9. [pmid: 11775301].
Kent G N, Stuckey B G, Allen J R, et al. Postpartum thyroid dysfunction: Clinical assessment and relationship to psychiatric affective morbidity. Clin Endocrinol. 1999;51(4):429-38.
Kitamura T, Shima S, Sugawara M, et al. Psychological and social correlates of the onset of affective disorders among pregnant women. Psychol Med. 1993;23:967-75. [pmid: 8134520].
Kitamura T, Shima S, Sugawara M, et al. Temporal variation of validity of self-rating questionnaires: Repeated use of the General Health Questionnaire and Zung's Self-rating Depression Scale among women during antenatal and postnatal periods. Acta Psychiatr Scand. 1994;90(6):446-50. [pmid: 7892778].
Kitamura T, Sugawara M, Shima S, et al. Temporal variation of validity of self-rating questionnaires: Improved validity of repeated use of Zung's Self-Rating Depression Scale among women during the perinatal period. J Psychosom Obstet Gynecol. 1999;20(2):112-7.
Kumar R, Robson K M. A prospective study of emotional disorders in childbearing women. Br J Psychiatry. 1984;144:35-47. [pmid: 6692075].
Lawrie T, Hofmeyr G, de Jager M, et al. Validation of the Edinburgh Postnatal Depression Scale on a cohort of South African women. S Afr Med J. 1998;88(10):1340-4. [pmid: 9807193].
Lee D, Yip A, Chiu H, et al. A psychiatric epidemiological study of postpartum Chinese women. Am J Psychiatry. 2001;158(2):220-6. [pmid: 11156804].
Lee D, Yip A, Chiu H, et al. Screening for postnatal depression using the double-test strategy. Psychosom Med. 2000;62(2):258-63. [pmid: 10772406].
Lee D, Yip A, Chiu H, et al. Screening for postnatal depression: Are specific instruments mandatory?. J Affect Disord. 2001;63(13):233-8. [pmid: 11246101].
Lee D, Yip S, Chiu H, et al. Detecting postnatal depression in Chinese women. Validation of the Chinese version of the Edinburgh Postnatal Depression Scale. Br J Psychiatry. 1998;172:433-7. [pmid: 9747407].
Leverton T J, Elliott S A. Is the EPDS a magic wand? 1. A comparison of the Edinburgh Postnatal Depression Scale and health visitor report as predictors of diagnosis on the Present State Examination. J Reprod Infant Psychol. 2000;18(4):279-96.
Lucas A, Pizarro E, Granada M L, et al. Postpartum thyroid dysfunction and postpartum depression: Are they two linked disorders?. Clin Endocrinol. 2001;55(6):809-14.
Matthey S, Barnett B, Howie P, et al. Diagnosing postpartum depression in mothers and fathers: Whatever happened to anxiety?. J Affect Disord. 2003;74(2):139-47. [pmid: 12706515].
Murray D, Cox J L. Screening for depression during pregnancy with the Edinburgh Depression Scale (EPDS). J Reprod Infant Psychol. 1990;8(2):99-107.
Murray L, Carothers A. The validation of the Edinburgh Post-natal Depression Scale on a community sample. Br J Psychiatry. 1990;157:288-90. [pmid: 2224383].
Muzik M, Klier C, Rosenblum K, et al. Are commonly used self-report inventories suitable for screening postpartum depression and anxiety disorders?. Acta Psychiatr Scand. 2000;102(1):71-3. [pmid: 10892613].
O'Hara M W, Neunaber D J, Zekoski E M. Prospective study of postpartum depression: Prevalence, course, and predictive factors. J Abnorm Psychol. 1984;93(2):158-71. [pmid: 6725749].
O'Hara M W, Zekoski E M, Philipps L H, et al. Controlled prospective study of postpartum mood disorders: Comparison of childbearing and nonchildbearing women. J Abnorm Psychol. 1990;99(1):3-15. [pmid: 2307763].
Onozawa K, Glover V, Adams D, et al. Infant massage improves mother-infant interaction for mothers with postnatal depression. J Affect Disord. 2001;63(13):201-7. [pmid: 11246096].
Pop V J, Essed G G, de Geus C A, et al. Prevalence of post partum depression--or is it post-puerperium depression?. Acta Obstet Gynecol Scand. 1993;72(5):354-8. [pmid: 8392265].
Stamp G E, Williams A S, Crowther C A. Evaluation of antenatal and postnatal support to overcome postnatal depression: A randomized, controlled trial. Birth. 1995;22(3):138-43. [pmid: 7575861].
Watson J P, Elliott S A, Rugg A J, et al. Psychiatric disorder in pregnancy and the first postnatal year. Br J Psychiatry. 1984;144:453-62. [pmid: 6733369].
Whiffen V E. Screening for postpartum depression: A methodological note. J Clin Psychol. 1988;44(3):367-71. [pmid: 3384962].
Whiffen V. Vulnerability of postpartum depression: A prospective multivariate study. J Abnorm Psychol. 1988;97(4):467-74. [pmid: 3204233].
Wickberg B, Hwang C. The Edinburgh Postnatal Depression Scale: Validation on a Swedish community sample. Acta Psychiatr Scand. 1996;94(3):181-4. [pmid: 8891084].
Wisner K L, Perel J M, Peindl K S, et al. Prevention of recurrent postpartum depression: A randomized clinical trial. J Clin Psychiatry. 2001;62(2):82-6. [pmid: 11247106].
Wisner K L, Wheeler S B. Prevention of recurrent postpartum major depression. Hosp Community Psychiatry. 1994;45(12):1191-6. [pmid: 7868100].
Yamashita H, Yoshida K, Nakano H, et al. Postnatal depression in Japanese women. Detecting the early onset of postnatal depression by closely monitoring the postpartum mood. J Affect Disord. 2000;58(2):145-54. [pmid: 10781704].
Yonkers K A, Ramin S M, Rush A J, et al. Onset and persistence of postpartum depression in an inner-city maternal health clinic system. Am J Psychiatry. 2001;158(11):1856-63. [pmid: 11691692].
Yoshida K, Marks M, Kibe N, et al. Postnatal depression in Japanese women who have given birth in England. J Affect Disord. 1997;43(1):69-77. [pmid: 9127832].
Zlotnick C, Johnson S L, Miller I W, et al. Postpartum depression in women receiving public assistance: Pilot study of an interpersonal-therapy-oriented group intervention. Am J Psychiatry. 2001;158(4):638-40. [pmid: 11282702].