# Appendix B. Quality Rating Forms

## Quality Checklist for RCTs and Observational Studies of Prevalence and Incidence Studies

## Quality Checklist for Studies of Screening Instruments/Procedures

## Quality Checklist for RCTs and Observational Studies of Treatment Studies