# Appendix A

## Exact Search Strings

Database: MEDLINE <1966 to March Week 3 2004>

Search Strategy:

1 exp Puerperal Disorders/ (16527)

2 exp Depression/ (32747)

3 exp Depressive Disorder/ (42005)

4 2 or 3 (73267)

5 1 and 4 (1452)

6 exp Depression, Postpartum/ or perinatal depression.mp. (753)

7 5 or 6 (1467)

13 limit 7 to (human and english language) (1299)

CINAHL used these terms as well.

PsycINFO has “Depression, Postpartum” as a Major Descriptor that yields 379.

Sociofile indexes 105 records to “Postpartum Depression”.

For Key Question 1, the following terms were used:

20 exp Natural History/ (8432)

21 8 and 20 (0)

When “Natural History” yielded no results, the following terms were used:

22 exp Cohort Studies/ (466831)

23 8 and 22 (112)

24 exp Longitudinal Studies/ (438062)

25 8 and 24 (101)

26 23 or 25 (134)

CINAHL (using similar terms) = 35

PsycINFO (natural history, cohort, longitudinal) = 65

Sociofile (natural history, cohort, longitudinal) = 20

Total from all databases for Key Question 1 = 254

After duplicates, book chapters, foreign language articles and dissertations were removed, the total unduplicated count for KQ1 = 210.

For Key Question 2, Incidence, the following terms were used:

MEDLINE

19 exp INCIDENCE/ (76679)

20 8 and 19 (31)

CINAHL (Incidence) = 7

PsycINFO (Incidence) = 23

Sociofile (Incidence) = 1

Total file = 62, minus duplications, dissertations, etc = 46

For Key Question 3, Risk, the following terms were used:

16 exp Risk Factors/ (221767)

17 8 and 16 (153)

CINAHL (Risk Factors) = 32

PsycINFO (risk) = 59

Sociofile (risk) = 11

Total from all databases for Key Question 3 = 255

After duplicates, book chapters, foreign language articles and dissertations were removed, the total unduplicated count for KQ3 = 204.

For Key Question 4, Therapies, the following terms were used:

MEDLINE

12 treatment.mp. or exp Therapeutics/ (2537613)

14 8 and 12 (513)

CINAHL (Treatment) = 90

PsycINFO (Treatment) = 91

Sociofile (Treatment) = 5

Total file = 699, minus duplications, dissertations, etc = 485

For Key Questions 5 and 6, Screening Accuracy and Screening Barriers, searches focused on “screening” and will give the total pool to investigators for finer sorting between questions.

MEDLINE

9 exp mass screening/ (62902)

10 8 and 9 (67)

CINAHL (screening) = 25

PsycINFO (screening) = 28

Sociofile (screening) = 1

Total from all databases for Key Questions 5 & 6 = 121

After duplicates, book chapters, foreign language articles and dissertations were removed, the total unduplicated count for KQ 5&6 = 96.