# Appendixes

Appendix A

Appendix B. Quality Rating Forms

Appendix C. Evidence Tables

Appendix D. Excluded Articles

Appendix E. Acknowledgments